# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates intended to serve as screening levels used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

An acute-duration inhalation MRL of 0.07 ppm was derived for hydrogen sulfide. This MRL is based on a minimal LOAEL of 2 ppm for a >30% alteration in two measures of lung function that are suggestive of bronchial obstruction (airway resistance and specific airway conductance) in 2 out of 10 persons with asthma (Jappinen et al. 1990). The MRL was derived by dividing the unadjusted LOAEL by an uncertainty factor of 27 (3 for the use of a minimal LOAEL, 3 for human variability, and 3 for database deficiencies). Further details on the derivation of this MRL can be found in the MRL worksheets in Appendix A of this profile.

An intermediate-duration inhalation MRL of 0.02 ppm was derived for hydrogen sulfide. This MRL is based on a NOAEL of 10 ppm and a LOAEL of 30 ppm for olfactory neuron loss in rats exposed to hydrogen sulfide 6 hours/day, 7 days/week for 10 weeks (Brenneman et al. 2000). The MRL was derived by dividing the human equivalent concentration of the NOAEL by an uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability). Further details on the derivation of this MRL can be found in the MRL worksheets in Appendix A of this profile.

EPA has derived a chronic inhalation reference concentration (RfC) for chronic exposure to hydrogen sulfide. The RfC of 0.002 mg/m^3^ (0.001 ppm) is based on a NOAEL of 13.9 mg/m^3^ (10 ppm) and a LOAEL of 41.7 mg/m^3^ (30 ppm) for nasal lesions of the olfactory mucosa in rats (Brenneman et al. 2000). The NOAEL_HEC_ of 0.64 mg/m^3^ (0.46 ppm) was divided by an uncertainty factor of 300 (3 for interspecies extrapolation with dosimetric adjustment from rat to human, 10 for sensitive populations, and 10 for subchronic exposure) (IRIS 2003).

EPA has not derived an oral reference dose (RfD) or an inhalation RfC for chronic exposure to carbonyl sulfide (IRIS 2002).

The international and national regulations, advisories, and guidelines regarding hydrogen sulfide and carbonyl sulfide in air, water, and other media are summarized in Tables 8-1 and 8-2.

Table 8-1 Regulations and Guidelines Applicable to Hydrogen Sulfide

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2013
WHO | Air quality guidelines | No data | WHO 2010
| Drinking water quality guidelines | No data^a^ | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 1 ppm | ACGIH 2012b
| STEL | 5 ppm
AIHA | ERPG-1^b,c^ | 0.1 ppm | AIHA 2011
| ERPG-2 | 30 ppm
| ERPG-3 | 100 ppm
DOE | PAC-1^d^ | 0.51 ppm | DOE 2012
| PAC-2 | 27 ppm
| PAC-3 | 50 ppm
EPA | AEGL-1^e^ | | EPA 2013a
| 10-minutes | 0.75 ppm
| 30-minutes | 0.60 ppm
| 60-minutes | 0.51 ppm
| 4-hours | 0.36 ppm
| 8-hours | 0.33 ppm
| AEGL-2
| 10-minutes | 41 ppm
| 30-minutes | 32 ppm
| 60-minutes | 27 ppm
| 4-hours | 20 ppm
| 8-hours | 17 ppm
| AEGL-3
| 10-minutes | 76 ppm
| 30-minutes | 59 ppm
| 60-minutes | 50 ppm
| 4-hours | 37 ppm
| 8-hours | 31 ppm
| NAAQS | No data | EPA 2013d
NIOSH | REL (10-minute ceiling) | 10 ppm | NIOSH 2011
| IDLH | 100 ppm
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
| Acceptable ceiling concentration | 20 ppm | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
| Acceptable maximum peak above the acceptable ceiling concentration for an 8-hour shift | 50 ppm for 10 minutes once only if no other measured exposure occurs | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
| Highly hazardous chemicals (threshold quantity) | 1,500 pounds | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2012c; 40 CFR 116.4
| Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
| Drinking water standards and health advisories | No data | EPA 2012d
| National primary drinking water standards | No data | EPA 2009b
| National recommended water quality criteria | | EPA 2009c
| Freshwater (criterion continuous concentration) | 2.0 μg/L
| Saltwater (criterion continuous concentration) | 2.0 μg/L
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 100 pounds | EPA 2012a; 40 CFR 117.3
c. Food
FDA | EAFUS^f^ | Yes | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | No data | ACGIH 2012b
EPA | Carcinogenicity classification | Data inadequate for assessment | IRIS 2003
| RfC | 2×10^−3^ mg/m^3^
| RfD | No data
| Identification and listing of hazardous waste | U135 | EPA 2012b; 40 CFR 261, Appendix VIII
| Inert pesticide ingredients in pesticide products approved for nonfood use only | No data | EPA 2013c
| Master Testing List | No data | EPA 2013a
| RCRA waste minimization PBT priority chemical list | No data | EPA 1998; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list; Superfund, emergency planning, and community right-to-know | No data | EPA 2012e; 40 CFR 264, Appendix IX
| Designated CERCLA hazardous substance and reportable quantity pursuant to Section 311(b)(2) of the Clean Water Act and Section 3001 of RCRA | 100 pounds | EPA 2012f; 40 CFR 302.4
| Effective date of toxic chemical release reporting | 01/01/1994 | EPA 2012g; 40 CFR 372.65
| Extremely hazardous substances and its threshold planning quantity^g^ | | EPA 2012h; 40 CFR 355, Appendix A
| Reportable quantity | 100 pounds | EPA 2012h; 40 CFR 355, Appendix A
| Threshold planning quantity | 500 pounds
| TSCA chemical lists and reporting periods | No data | EPA 2012i; 40 CFR 712.30
| TSCA health and safety data reporting | No data | EPA 2012j; 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2011

a A guideline value was not established for hydrogen sulfide because it occurs in drinking-water at concentrations well below those of health concern; although it may affect acceptability of drinking water (WHO 2011).

b ERPG-1: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing other than mild transient adverse health effects or perceiving a clearly defined, objectionable odor; ERPG-2: maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing irreversible or other serious health effects or symptoms that could impair an individual’s ability to take protective action; ERPG-3: is the maximum airborne concentration below which it is believed that nearly all individuals could be exposed for up to 1 hour without experiencing or developing life-threatening health effects (AIHA 2011).

c Odor should be detectable near ERPG-1.

d PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2012).

e AEGL-1: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic, nonsensory effects; however, these effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape; AEGL-3: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening adverse health effects or death (EPA 2013a).

f The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

g Hydrogen sulfide does not meet the toxicity criteria but because of its acute lethality, high production volume, or known risk it is considered a chemical of concern.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure level; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization

Table 8-2 Regulations and Guidelines Applicable to Carbonyl Sulfide

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2013
WHO | Air quality guidelines | No data | WHO 2010
| Drinking water quality guidelines | No data | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 5 ppm | ACGIH 2012a
AIHA | ERPG-1, -2, -3 | No data | AIHA 2011
DOE | PAC-1^a^ | 5 ppm | DOE 2012
| PAC-2 | 55 ppm
| PAC-3 | 150 ppm
EPA | AEGL-1^b^ | Not recommended due to lack of warning properties | EPA 2013b
| AEGL-2
| 10-minutes | 69 ppm
| 30-minutes | 69 ppm
| 60-minutes | 55 ppm
| 4-hours | 34 ppm
| 8-hours | 23 ppm
| AEGL-3
| 10-minutes | 190 ppm
| 30-minutes | 190 ppm
| 60-minutes | 150 ppm
| 4-hours | 95 ppm
| 8-hours | 48 ppm
| Hazardous air pollutant | Yes | EPA 2009d; 42 USC 7412
| NAAQS | No data | EPA 2013d
NIOSH | REL (10-hour TWA) | No data | NIOSH 2013
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013c; 29 CFR 1910.1000, Table Z-1
| Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | No data | EPA 2012c; 40 CFR 116.4
| Drinking water contaminant candidate list | No data | EPA 2009a; 74 FR 51850
| Drinking water standards and health advisories | No data | EPA 2012d
| National primary drinking water standards | No data | EPA 2009b
| National recommended water quality criteria | No data | EPA 2009c
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2012a; 40 CFR 117.3
c. Food
FDA | EAFUS^c^ | No data | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | No data | ACGIH 2012a
EPA | Carcinogenicity classification | No data | IRIS 2002
| RfC | No data
| RfD | No data
| Identification and listing of hazardous waste | No data | EPA 2012b; 40 CFR 261, Appendix VIII
| Inert pesticide ingredients in pesticide products approved for nonfood use only | No data | EPA 2013c
| Master Testing List | Yes^d^ | EPA 2013d
| RCRA waste minimization PBT priority chemical list | No data | EPA 1998b; 63 FR 60332
| Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list; Superfund, emergency planning, and community right-to-know | No data | EPA 2012e; 40 CFR 264, Appendix IX
| Designated CERCLA hazardous substance and reportable quantity pursuant to Section 112 of the Clean Air Act | 100 pounds | EPA 2012f; 40 CFR 302.4
| Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2012g; 40 CFR 372.65
| Extremely hazardous substances and its threshold planning quantity | No data | EPA 2012h; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2012i; 40 CFR 712.30
| TSCA health and safety data reporting | No data | EPA 2012j; 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2011

a PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2012).

b AEGL-1: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic, nonsensory effects; however, these effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting, adverse health effects or an impaired ability to escape; AEGL-3: is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening adverse health effects or death (EPA 2013a).

c The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

d Testing action development underway for health effects including mutagenicity, acute and subchronic toxicity, neurotoxicity, developmental and reproductive toxicity, carcinogenicity and immunotoxicity.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization