# 3 HEALTH EFFECTS

## 3.1 INTRODUCTION

The primary purpose of this chapter is to provide public health officials, physicians, toxicologists, and other interested individuals and groups with an overall perspective on the toxicology of hydrogen sulfide and carbonyl sulfide. It contains descriptions and evaluations of toxicological studies and epidemiological investigations and provides conclusions, where possible, on the relevance of toxicity and toxicokinetic data to public health.

A glossary and list of acronyms, abbreviations, and symbols can be found at the end of this profile.

## 3.2 DISCUSSION OF HEALTH EFFECTS BY ROUTE OF EXPOSURE

To help public health professionals and others address the needs of persons living or working near hazardous waste sites, the information in this section is organized first by route of exposure (inhalation, oral, and dermal) and then by health effect (death, systemic, immunological, neurological, reproductive, developmental, genotoxic, and carcinogenic effects). These data are discussed in terms of three exposure periods: acute (14 days or less), intermediate (15–364 days), and chronic (365 days or more).

Levels of significant exposure for each route and duration are presented in tables and illustrated in figures. The points in the figures showing no-observed-adverse-effect levels (NOAELs) or lowest-observed-adverse-effect levels (LOAELs) reflect the actual doses (levels of exposure) used in the studies. LOAELs have been classified into "less serious" or "serious" effects. "Serious" effects are those that evoke failure in a biological system and can lead to morbidity or mortality (e.g., acute respiratory distress or death). "Less serious" effects are those that are not expected to cause significant dysfunction or death, or those whose significance to the organism is not entirely clear. ATSDR acknowledges that a considerable amount of judgment may be required in establishing whether an end point should be classified as a NOAEL, "less serious" LOAEL, or "serious" LOAEL, and that in some cases, there will be insufficient data to decide whether the effect is indicative of significant dysfunction. However, the Agency has established guidelines and policies that are used to classify these end points. ATSDR believes that there is sufficient merit in this approach to warrant an attempt at distinguishing between "less serious" and "serious" effects. The distinction between "less serious" effects and "serious" effects is considered to be important because it helps the users of the profiles to identify levels of exposure at which major health effects start to appear. LOAELs or NOAELs should also help in determining whether or not the effects vary with dose and/or duration, and place into perspective the possible significance of these effects to human health.

The significance of the exposure levels shown in the Levels of Significant Exposure (LSE) tables and figures may differ depending on the user’s perspective. Public health officials and others concerned with appropriate actions to take at hazardous waste sites may want information on levels of exposure associated with more subtle effects in humans or animals (LOAELs) or exposure levels below which no adverse effects (NOAELs) have been observed. Estimates of levels posing minimal risk to humans (Minimal Risk Levels or MRLs) may be of interest to health professionals and citizens alike.

A User’s Guide has been provided at the end of this profile (see Appendix B). This guide should aid in the interpretation of the tables and figures for Levels of Significant Exposure and the MRLs.

### 3.2.1 Inhalation Exposure

#### 3.2.1.1 Death

Hydrogen Sulfide. There have been numerous case reports of human deaths after acute exposure to presumably high concentrations (≥500 ppm) of hydrogen sulfide gas (Beauchamp et al. 1984). NIOSH (1977a) reported that hydrogen sulfide was the primary occupational cause of unexpected death. Snyder et al. (1995), summarizing 10 years of data (1983–1992) from the Poison Control Centers National Data Collection system, indicated that at least 29 deaths and 5,563 exposures were attributed to hydrogen sulfide during that time period. Most fatal cases associated with hydrogen sulfide exposure occurred in relatively confined spaces, such as sewers (Adelson and Sunshine 1966; Christia-Lotter et al. 2007; Knight and Presnell 2005; Yalamanachili and Smith 2008), animal processing plants (Breysse 1961), waste dumps (Allyn 1931), sludge plants (NIOSH 1985a), tanks and cesspools (Ago et al. 2008; Campanya et al. 1989; Freireich 1946; Hagley and South 1983; Morse et al. 1981; Osbern and Crapo 1981), and other closed environments (Deng and Chang 1987; Parra et al. 1991; Policastro and Otten 2007). Some cases were suicides that involved mixing household chemicals such as hydrochloric acid and lime sulfur to generate hydrogen sulfide gas (Bott and Dodd 2013; Kamijo et al. 2013; Maebashi et al. 2011; Reedy et al. 2011; Sams et al. 2013). Almost all individuals described in these reports lost consciousness quickly after inhalation of hydrogen sulfide, sometimes after only one or two breaths (the so-called "slaughterhouse sledgehammer" effect). Many of the case studies involved accidental poisonings for which the concentrations and/or duration of exposure were not known (Allyn 1931; Arnold et al. 1985; Burnett et al. 1977; Deng and Chang 1987; Freireich 1946; Hagley and South 1983; Morse et al. 1981). In some cases, the victims were exposed for a period of time ranging from a few minutes to an hour and were unable to be revived (Adelson and Sunshine 1966; Deng and Chang 1987; NIOSH 1989; Osbern and Crapo 1981).

Death occurring after acute exposure to hydrogen sulfide appears to be the result of respiratory failure or arrest, with most cases initially presenting with respiratory insufficiency, noncardiogenic pulmonary edema, coma, and cyanosis. Three men lost consciousness and died after entering a sewer containing high concentrations of hydrogen sulfide; all had the characteristic odor of hydrogen sulfide at autopsy and presented with cyanosis and pulmonary edema (Adelson and Sunshine 1966). After being exposed to hydrogen sulfide in a bathroom connected to a manure pit, a man developed nausea, vomiting, dizziness, dyspnea, and died a few hours later; hemorrhagic bronchitis and asphyxiation were noted as the cause of death (Parra et al. 1991).

Estimates of hydrogen sulfide exposure were available for some of the cases reported involving deaths. After developing decerebrate responses to painful stimuli and partial seizures, with subsequent indications of brain stem damage, a 16-year-old boy died (Hagley and South 1983). He was exposed to what was presumed to be hydrogen sulfide in a liquid manure tank; 2 weeks after exposure, hydrogen sulfide concentrations measured 30 cm below the tank manhole were >150 ppm, the detection limit of the equipment. In another incident, a 16-year-old boy was 10 meters away from an underground liquid manure storage tank (the contents of which had been agitating for 30–60 minutes) when he began coughing, vomited, lost consciousness, and died (Morse et al. 1981). Autopsy showed tracheobronchial aspiration of stomach contents, focal pulmonary hemorrhages and edema, and small petechial brain hemorrhages. Hydrogen sulfide concentrations were found to be >60 ppm (equipment detection limit) under similar conditions in the vicinity of the accident 2 days later. Although some other gases common to this environment were not detected, it is possible that there was simultaneous exposure to other compounds. A boy and his father were overcome and died after inhaling hydrogen sulfide gas from a discarded drum at a manufacturing dump (Allyn 1931). Although the concentration of the gas inside the drum at the time of exposure was not known, a crude attempt was made to estimate exposure. Gas was collected from the drum 2 weeks after the accident and diluted 1:400 with air. A rat exposed to this dilution died after 40 seconds of exposure.

Three of five men lost consciousness within a few minutes of entering a partially drained underground liquid manure storage tank and died before reaching the hospital. An autopsy showed that two of the men had massive liquid manure pulmonary aspiration, while the third man had fulminant pulmonary edema without manure aspiration (Osbern and Crapo 1981). Markedly elevated heart-blood sulfide-ion levels indicated significant hydrogen sulfide exposure. Air samples analyzed about a week after the accident detected only 76 ppm of hydrogen sulfide, but the study authors noted that the environmental conditions were probably different (e.g., warmer weather, less-concentrated manure). In another report, two maintenance workers at an animal tanning company collapsed and died no more than 45 minutes after entering a sewer manhole. A hydrogen sulfide concentration of 200 ppm was obtained just inside the manhole 6 days after the accident (NIOSH 1989). In another case, a worker at a poultry feather processing plant died after being exposed to hydrogen sulfide gas for an estimated 15–20 minutes (Breysse 1961). Testing performed later in the area where the exposure occurred indicated that hydrogen sulfide concentrations ranged from 2,000 to 4,000 ppm. Pulmonary, intracranial, and cerebral edema along with cyanosis were noted at autopsy.

Claims for acute hydrogen sulfide exposure that occurred over a 5-year period (1969–1973) in Alberta, Canada, primarily among petrochemical workers, were reviewed by Burnett et al. (1977). Acute effects noted included coma, disequilibrium, and respiratory insufficiency with pulmonary edema. Of 221 cases, there were 14 deaths. A follow-up study of 250 workers’ claims for hydrogen sulfide exposure from 1979 to 1983 in Alberta, Canada, found 7 fatalities that usually involved the central nervous and respiratory systems; hepatic congestion and cardiac petechiae were also noted (Arnold et al. 1985). The difference in fatality rate (6% down to 2.8%) was attributed to improved first aid training and an increased awareness of the dangers of hydrogen sulfide.

Only very limited information is available on mortality in humans associated with chronic exposure to hydrogen sulfide. Bates et al. (1997), taking advantage of the fact that the New Zealand city of Rotorua is in a geothermally active area, conducted a retrospective ecological epidemiologic study in which they compared the mortality for selected diseases between residents in Rotorua and the rest of New Zealand. Rotorua uses geothermal energy for industrial and domestic heating purposes. Monitoring during the 1970s found levels of hydrogen sulfide as high as 1 mg/m^3^ (710 ppb); the most reliable data provided a median concentration of 20 μg/m^3^ (14 ppb) with 35% of the measurements of >70 μg/m^3^ (50 ppb), and 10% over 400 μg/m^3^ (284 ppb). Mortality data examined were limited to the main organ systems known to be at risk in hydrogen sulfide exposure (i.e., the nervous, respiratory and cardiovascular/circulatory systems) and birth defects. Among these four mortality categories, only deaths due to diseases of the respiratory system showed a significantly elevated standardized mortality ratio (SMR=1.18; p<0.001). Because the population in the Rotorua area has markedly more Māori (indigenous people of New Zealand) than in the rest of New Zealand, and because Māori disease and mortality rates are relatively high compared with those of the non-Māori population, further analysis was carried out with an adjustment for ethnicity. When these data were stratified by sex and ethnicity, Māoris females had an SMR of 1.61 (p<0.001). Carrying the analysis to minor groupings of disease, significant increases in SMR were found for rheumatic fever and chronic rheumatic heart disease (SMR=1.51; p=0.01), hypertensive disease (SMR=1.61; p<0.001), pneumonia and influenza (SMR=1.20; p=0.008), and chronic obstructive respiratory disease and allied conditions (SMR=1.20; p=0.004). In their analysis of the data, the authors note numerous issues with regard to ecologic studies; primarily confounding exposure to other agents (e.g., smoking) and ethnicity misclassification. Despite the fact that the data indicate significant increases in SMRs, the study authors concluded that “no convincing evidence was found in this study of elevated rates of mortality in Rotorua compared with the rest of New Zealand.” They caveat this conclusion with three considerations: not all causes of deaths were considered, exposures were inadequately characterized, and ethnicity misclassification could have obscured important causes of mortality.

Studies performed using laboratory animals exposed to high concentrations of hydrogen sulfide gas have yielded results similar to those observed in humans exposed at high levels. Exposure of Sprague-Dawley rats to 1,655 ppm killed all five animals within 3 minutes (Lopez et al. 1989). All male F-344 rats exposed to 500–700 ppm hydrogen sulfide gas for 4 hours died, while no rats died when exposed to concentrations up to 400 ppm under these conditions (Khan et al. 1990; Lopez et al. 1987, 1988a, 1988b). Ten of 10 male Wistar rats died after a 12-minute exposure (mean) to 800 ppm hydrogen sulfide (Beck et al. 1979). Concentrations of 335–587 ppm causing death in 50% of the animals tested (LC_50_) have been reported in Sprague-Dawley, F-344, and Long Evans rats exposed to hydrogen sulfide gas for 2–6-hour periods (Prior et al. 1988; Tansy et al. 1981). However, there were fewer deaths in approximately the same dose range in another study using F-344 rats (Prior et al. 1990). No mortality was reported when male Wistar rats were exposed to up to 500 ppm hydrogen sulfide for 2 hours (Higuchi and Fukamachi 1977).

No deaths occurred among 30 adult female CB-20 mice exposed to 100 ppm hydrogen sulfide for 2 hours/day for 1 day (Elovaara et al. 1978), nor in 20 adult female NMRI mice exposed for 1–4 days (Savolainen et al. 1980). A third study reported that all six mice exposed to 722 ppm hydrogen sulfide for 50 minutes died; exposure of six mice to 1,872 ppm hydrogen sulfide resulted in death in 10 minutes (Smith and Gosselin 1964). Five Japanese white rabbits died within 30 minutes of exposure to 500–1,000 ppm hydrogen sulfide (Kage et al. 1992).

No mortality was noted during 90-day studies in which male and female F-344 or Sprague-Dawley rats were exposed for 6 hours/day, 5 days/week, to up to 80 ppm hydrogen sulfide (CIIT 1983b, 1983c). Similar results were obtained at the same concentrations and conditions in a companion study using B6C3F_1_ mice; although two high-dose animals were killed in extremis, and two control animals were found dead in the cage (CIIT 1983a).

Carbonyl Sulfide. Two studies in male and female rats have calculated LC_50_ values of 1,082 and 1,111 ppm for a 4-hour exposure to carbonyl sulfide (DuPont 1981; Monsanto 1985a). Clinical signs observed at the higher concentrations (≥1,096 ppm) included convulsions, hypoactivity, and breathing difficulties (Monsanto 1985a). The mortality concentration-response curve was steep, with 40% of the animals dying at 1,090 ppm, 50% at 1,160 ppm, and 100% at ≥1,210 ppm (DuPont 1981).

Repeated exposures to lower concentrations also resulted in mortality or morbidity. Rats exposed to 500 ppm 6 hours/day for 4 days or 600 ppm for 2 days were sacrificed in moribund condition (Morgan et al. 2004); however, exposure to 400 ppm (6 hours/day, 5 days/week) for as long as 12 weeks did not result in mortality or extreme morbidity (Herr et al. 2007; Morgan et al. 2004; Sills et al. 2004). Approximately 20–40% mortality was observed in rabbits continuously exposed to 54 ppm for 5 days (Hugod 1981; Hugod and Astrup 1980; Kamstrup and Hugod 1979).

All reliable LOAEL values for death in each species and duration category are recorded in Table 3-1 and plotted in Figure 3-1 for hydrogen sulfide and Table 3-2 and Figure 3-2 for carbonyl sulfide.

#### 3.2.1.2 Systemic Effects

The highest NOAEL and all reliable LOAEL values for systemic effects in each species and duration are recorded in Table 3-1 and plotted in Figure 3-1.

##### Respiratory Effects.

Hydrogen Sulfide. A variety of respiratory effects (including symptoms of respiratory irritation, altered lung function, and respiratory distress) have been observed in workers accidentally exposed to high concentrations of hydrogen sulfide, experimental subjects acutely exposed to low levels of hydrogen sulfide, chronically exposed workers, and residents living near pulp mill production facilities, hog feeding operations, or areas with high geothermal activity. It should be noted that with the exception of the experimental studies, there was concomitant exposure to a number of other compounds including ammonia, methyl mercaptan, methyl sulfides, sulfur dioxide, and particulate matter. With acute accidental hydrogen sulfide exposure, numerous respiratory effects are observed. Death usually occurs after respiratory distress or arrest from the disruption of oxidative metabolism in the brain. Respiratory distress has also been noted in individuals who survived after acute exposures (Osbern and Crapo 1981; Peters 1981; Shivanthan et al. 2013; Spolyar 1951). Respiratory distress was noted in two workers exposed to >40 ppm hydrogen sulfide for <25 minutes (Spolyar 1951). Other respiratory effects of acute hydrogen sulfide exposure include noncardiogenic pulmonary edema (Arnold et al. 1985; Burnett et al. 1977; Deng and Chang 1987; Thoman 1969; Tvedt et al. 1991a, 1991b), sore throat, cough (Burnett et al. 1977; Jaakkola et al. 1990), and dyspnea (Arnold et al. 1985; Burnett et al. 1977; Krekel 1964; Osbern and Crapo 1981; Parra et al. 1991; Ravizza et al. 1982; Stine et al. 1976; Thoman 1969). Cyanosis has been reported in a number of case reports and is believed to result from respiratory distress (Arnold et al. 1985; Shivanthan et al. 2013; Tvedt et al. 1991a, 1991b). In most studies, exposure concentrations and/or durations were unknown. Among hydrogen sulfide exposure survivors, respiratory symptoms generally subsided within several weeks of exposure, but occasionally persisted for several months or longer (Duong et al. 2001; Parra et al. 1991). Acute exposure to >500 ppm hydrogen sulfide is considered to cause rapid respiratory failure (Beauchamp et al. 1984).

Table 3-1 Levels of Significant Exposure to Hydrogen Sulfide - Inhalation

Key to^a^ Figure | Species (Strain) | Exposure/Duration/Frequency (Route) | System | NOAEL (ppm) | LOAEL | | | Comments
Key to^a^ Figure | Species (Strain) | Exposure/Duration/Frequency (Route) | System | NOAEL (ppm) | Less Serious (ppm) | Serious (ppm) | Reference Chemical Form | Comments
ACUTE EXPOSURE
Death
1 | Rat; (Wistar) | 12 min | | | | 800 M (10/10 died) | Beck et al. 1979
2 | Rat; (Fischer- 344) | 4 hr | | | | 500 M (4–6 used; all died) | Khan et al. 1990
3 | Rat; (Sprague-Dawley) | 3 min | | | | 1655 M (5/5 died) | Lopez et al. 1989
4 | Rat; (Sprague-Dawley, Fischer-344, Long Evans) | 2 hr | | | | 587 (LC50) | Prior et al. 1988
5 | Rat; (Sprague-Dawley, Fischer-344, Long Evans) | 4 hr | | | | 501 (LC50) | Prior et al. 1988
6 | Rat; (Sprague-Dawley, Fischer-344, Long Evans) | 6 hr | | | | 335 (LC50) | Prior et al. 1988
7 | Rat; (Fischer- 344) | 4 hr | | | | 375 M (2/12 died) | Prior et al. 1990
8 | Rat; (Sprague-Dawley) | 4 hr | | | | 444 (LC50) | Tansy et al. 1981
9 | Mouse; (CD-1) | 50 min | | | | 722 F (6/6 died) | Smith and Gosselin 1964
10 | Rabbit; (Japanese white) | 14–30 min | | | | 500 (5/5 died) | Kage et al. 1992
Systemic
11 | Human | >16 min | Resp | 5 M | | | Bhambhani and Singh 1991
| | | Cardio | 5 M
| | | Metab | 2 M | 5 M (increased blood lactate during exercise)
12 | Human | 15 min | Resp | 10 | | | Bhambhani et al. 1996a
13 | Human | 30 min | Resp | 5 | | | Bhambhani et al. 1994
| | | Cardio | 5
14 | Human | 2×30 min | Musc/skel | | 5 M (decrease in citrate synthase when exercising at 50% maximum aerobic power) | | Bhambhani et al. 1996b
15 | Human | 2×30 min | Cardio | 10 | | | Bhambhani et al. 1997
| | | Metab | | 10 (increase in blood lactate and decrease in oxygen uptake)
16 | Human | 2 hr | Resp | 5 | | | Fiedler et al. 2008
17 | Human | 30 min | Resp | | 2^b^ (increased airway resistance and decreased specific airway conductance in 2/10 asthmatics) | | Jappinen et al. 1990
18 | Rat; (Sprague-Dawley) | 3 hr | Resp | 80 M | 200 M (necrosis of olfactory epithelium and regeneration of respiratory epithelium in nose) | | Brenneman et al. 2002
19 | Rat; (Sprague-Dawley) | 3 hr; 5 d | Resp | 30 M | 80 M (necrosis of nasal olfactory epithelium in 5/5 rats) | | Brenneman et al. 2002
20 | Rat; (Fischer- 344) | 4 hr | Resp | | 194 M (increase in protein and lactate dehydrogenase in lavage fluid; focal areas of perivascular edema; proteinaceous material in the alveoli) | | Green et al. 1991
21 | Rat; (Wistar) | 1 hr | Resp | | 100 M (increased respiration rate) | | Higuchi and Fukamachi 1977
| | | Cardio | | 100 M (increased blood pressure, heart rate)
22 | Rat; (Fischer- 344) | 4 hr | Resp | 10 M | 50 M (15% reduction in lung cytochrome c oxidase activity) | | Khan et al. 1990
23 | Rat; (Fischer- 344) | 4 hr | Resp | 50 M | 200 M (decreased respiratory rate of pulmonary alveolar macrophages stimulated with zymosan) | | Khan et al. 1991
24 | Rat; (Wistar) | 20–60 min | Resp | | 75 M (slight congestion) | | Kohno et al. 1991
| | | Cardio | | | 75 M (cardiac arrhythmia; decreased heart rate)
25 | Rat; (Fischer- 344) | 4 hr | Resp | | 10 M (increased cellularity in nasal lavage fluid) | | Lopez et al. 1987
26 | Rat; (Fischer- 344) | 4 hr | Resp | | 83 M (mild perivascular edema) | | Lopez et al. 1988a
27 | Rat; (Fischer- 344) | 4 hr | Resp | | | 400 M (severe inflammation and necrosis of respiratory and olfactory epithelium) | Lopez et al. 1988b
28 | Rat; (Fischer- 344) | 4 hr | Ocular | 200 M | 400 M (epiphora) | | Lopez et al. 1988b
29 | Rat; (Fischer- 344) | 4 hr | Resp | | | 375 M (moderate to massive pulmonary edema) | Prior et al. 1990
30 | Gn Pig; (NS) | 11 d; 1 hr/d | Ocular | | 20 M (eye irritation) | | Haider et al. 1980
31 | Rabbit; (mixed breeds) | 1.5 hr; or; 5 d; 0.5hr/d | Cardio | | | 72 (changes in ventricular repolarization; cardiac arrhythmia) | Kosmider et al. 1967
Immuno/ Lymphoret
32 | Rat; (Fischer- 344) | 4 hr | | 50 M | 200 M (decreased respiratory rate of pulmonary alveolar macrophages stimulated with zymosan) | | Khan et al. 1991
Neurological
33 | Human | 2 hr | | 5 | | | Fiedler et al. 2008
34 | Human | 30 min | | | 2 (headache in 3/10 asthmatics) | | Jappinen et al. 1990
35 | Rat; (Wistar) | 20 min | | | | 800 M (unconsciousness) | Beck et al. 1979
36 | Rat; (Wistar) | 2 hr | | 100 M | 200 M (decreased response rate in conditioned avoidance task) | | Higuchi and Fukamachi 1977
37 | Rat; (Fischer- 344) | 4 hr | | 200 M | 400 M (lethargy) | | Lopez et al. 1988b
38 | Rat; (CD) | 3 hr/d; 5 d | | 30 M | 80 M (decreased spontaneous motor activity) | | Struve et al. 2001
39 | Gn Pig; (NS) | 11 d; 1 hr/d | | | 20 M (decreased cerebral hemisphere and brain stem total lipids and phospholipids) | | Haider et al. 1980
40 | Rabbit; (mixed breeds) | 1.5 hr | | | | 72 (unconsciousness) | Kosmider et al. 1967
INTERMEDIATE EXPOSURE
Systemic
41 | Rat; (Sprague-Dawley) | 6 hr/d; 7 d/wk; 10 wk | Resp | 10^c^ M | 30 M (olfactory neuron loss and basal cell hyperplasia in nasal olfactory epithelium) | | Brenneman et al. 2000
42 | Rat; (Fischer- 344) | 90 d; 5 d/wk; 6 hr/d | Resp | 10 | 30 (olfactory neuron loss in the nasal olfactory epithelium) | | CIIT 1983b
| | | Cardio | 80
| | | Gastro | 80
| | | Hemato | 80
| | | Musc/skel | 80
| | | Hepatic | 80
| | | Renal | 80
| | | Endocr | 80
| | | Dermal | 80
| | | Ocular | 80
| | | Bd Wt | 80
43 | Rat; (Sprague-Dawley) | 90 d; 5 d/wk; 6 hr/d | Resp | 10 | 30 (olfactory neuron loss in the nasal olfactory epithelium and bronchiolar epithelial hyperplasia) | | CIIT 1983c
| | | Cardio | 80
| | | Gastro | 80
| | | Hemato | 80
| | | Musc/skel | 80
| | | Hepatic | 80
| | | Renal | 80
| | | Endocr | 80
| | | Dermal | 80
| | | Ocular | 80
| | | Bd Wt | 30.5 F | 80 F (10% decrease in body weight)
44 | Rat; (Sprague-Dawley) | Gd 1- Ppd 21; 7 hr/d | Metab | | 20 F (50% increase in circulating glucose levels in dams) | | Hayden et al. 1990a
45 | Rat; (Sprague-Dawley) | Gd 1- Ppd 21; 7 hr/d | Hepatic | 50 F | 75 F (increased maternal liver cholesterol levels) | | Hayden et al. 1990b
46 | Rat; (Sprague-Dawley) | Gd 6–20; 6 hr/d | Bd Wt | 100 F | 150 F (pregnant rats lost weight) | | Saillenfait et al. 1989
47 | Mouse; (B6C3F1) | 90 d; 5 d/wk; 6 hr/d | Resp | 10 | 80 (inflammation of nasal mucosa) | | CIIT 1983a
| | | | | 30 (olfactory neuron loss in the nasal olfactory epithelium)
| | | Cardio | 80
| | | Gastro | 80
| | | Hemato | 80
| | | Musc/skel | 80
| | | Hepatic | 80
| | | Renal | 80
| | | Endocr | 80
| | | Dermal | 80
| | | Ocular | 80
| | | Bd Wt | 30.5 | 80 (7–14% decrease in body weight)
48 | Pig; (Crossbred) | 17 d; 24 hr/d | Resp | 8.5 | | | Curtis et al. 1975
| | | Gastro | 8.5
| | | Hepatic | 8.5
| | | Renal | 8.5
| | | Ocular | 8.5
| | | Bd Wt | 8.5
Immuno/ Lymphoret
49 | Rat; (Fischer- 344) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983b
50 | Rat; (Sprague-Dawley) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983c
51 | Mouse; (B6C3F1) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983a
Neurological
52 | Rat; (Fischer- 344) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983b
53 | Rat; (Sprague-Dawley) | 90 d; 5 d/wk; 6 hr/d | | 30.5 M | 80 M (5% decrease in brain weight) | | CIIT 1983c
54 | Rat; (Sprague-Dawley) | 25 wk; 5 d/wk | | 50 M | | | Gagnaire et al. 1986
55 | Rat; (Sprague-Dawley) | 4 hr/d; 5 d/wk; 5–11 wk | | | 125 M (impaired learning of new tasks on a radial arm maze) | | Partlo et al. 2001
56 | Mouse; (B6C3F1) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983a
Reproductive
57 | Rat; (Fischer- 344) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983b
58 | Rat; (Sprague-Dawley) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983c
59 | Rat; (Sprague-Dawley) | 6 hr/d; 7 d/wk; 60–70 d | | 80 | | | Dorman et al. 2000
60 | Mouse; (B6C3F1) | 90 d; 5 d/wk; 6 hr/d | | 80 | | | CIIT 1983a
Developmental
61 | Rat; (Sprague-Dawley) | 6 hr/d; 7 d/wk; 60–70 d | | 80 | | | Dorman et al. 2000
62 | Rat; (Sprague-Dawley) | Gd 5 - Ppd 21; 7 hr/d | | | 20 F (severe alterations in architecture and growth characteristics of Purkinje cell dendritic fields which may be indicative of neurotoxicity) | | Hannah and Roth 1991
63 | Rat; (Sprague-Dawley) | Gd 5 - Ppd 21; 7 hr/d | | 50 | 75 (decreases in brain amino acid levels of pups) | | Hannah et al. 1989, 1990
64 | Rat; (Sprague-Dawley) | Gd 1- Ppd 21; 7 hr/d | | 75 F | | | Hayden et al. 1990a
65 | Rat; (Sprague-Dawley) | Gd 1- Ppd 21; 7 hr/d | | 75 F | | | Hayden et al. 1990b
66 | Rat; (Sprague-Dawley) | Gd 6–20; 6 hr/d | | 150 F | | | Saillenfait et al. 1989
67 | Rat; (Sprague-Dawley) | Gd 5 - Ppd 21; 7 hr/d | | | 20 F (decreases in norepinephrine in the frontal cortex, increase in serotonin in the frontal cortex of pups) | | Skrajny et al. 1992

a The number corresponds to entries in Figure 3-1.

b Used to derive an acute-duration Minimal Risk Level (MRL) of 0.07 ppm; concentration divided by an uncertainty factor of 27 (3 for use of a minimal LOAEL, 3 for human variability, and 3 for database deficiencies).

c Used to derive an intermediate-duration Minimal Risk Level (MRL) of 0.02 ppm. The NOAEL was adjusted for intermittent exposure and multiplied by the regional gas dose ratio (RGDR) for extrathoracic effects to calculate a human equivalent concentration (HEC). The NOAELHEC was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Bd Wt = body weight; Cardio = cardiovascular; d = day(s); Endocr = endocrine; F = Female; Gastro = gastrointestinal; Gd = gestational day; Gn pig = guinea pig; Hemato = hematological; hr = hour(s); Immuno/Lymphoret = immunological/lymphoreticular; LC50 = lethal concentration, 50% kill; LOAEL = lowest-observed-adverse-effect level; M = male; min = minute(s); Metab = metabolism; Musc/skel = musculoskeletal; NOAEL = no-observed-adverse-effect level; NS = not specified; Ppd = post-parturition day; ppm = parts per million; Resp = respiratory; wk = week(s)

Figure 3-1 Levels of Significant Exposure to Hydrogen Sulfide - Inhalation

Acute (≤14 days)

Acute (≤14 days)

Intermediate (15-364 days)

Intermediate (15-364 days)

Intermediate (15-364 days)

As discussed in more detail in Section 3.2.1.1, Bates et al. (1997) found a significant increase in mortality from diseases of the respiratory system for residents of the Rotorua area of New Zealand for the period of 1981–1990. Rotorua is in an area of high geothermal activity; sampling from a campaign in 1978 indicated a median concentration for hydrogen sulfide of about 20 μg/m^3^ with 35% of the measurements >70 μg/m^3^ and 10% of the measurements >400 μg/m^3^. Problems with the analysis, however, led these authors to conclude that there were no clear indications of excess mortality. In a follow-up to this study, Bates et al. (2002) used hospital discharge records for 1993–1996 to assess the incidence of respiratory disease; unlike the previous study, exposure was classified as high, medium, or low, based on residence at the time of discharge. A statistically significant (p<0.001), exposure-related trend for increased incidence of respiratory disease was found. The incidence of minor respiratory disease groups was also significantly (p<0.01) increased. In general, the incidence of respiratory disease was significantly elevated in the high exposure group, but not at lower exposure levels; however, the incidences of other diseases of the upper respiratory tract category were increased in all three exposure groups. The standardized incidence ratios (SIRs) (and 95% confidence limits) for this category were 1.48 (1.34–1.63), 1.68 (1.39–2.01), and 1.98 (1.58–2.45) in the low, medium, and high exposure groups, respectively. Limitations in the design of this study, such as lack of exposure monitoring data, lack of data on potential confounding factors (e.g., smoking, differences in socioeconomic status in the different exposure groups), lack of residence history data, and lack of information on potential exposure at work, limit the interpretation of these data. Subsequent follow-up studies of this population did not find associations between hydrogen sulfide exposure and respiratory effects. A study of >1,600 residents living in Rotorua for at least 3 years showed a significant trend for decreasing self-reported wheezing as time-weighted average (TWA) or maximum hydrogen sulfide levels increased (Bates et al. 2013); no association was found with self-reported, doctor-diagnosed asthma. Hydrogen sulfide levels were monitored for 2 weeks in the summer and winter using at least 50 passive monitoring devices located in the city. The median and mean concentrations were 20.3 and 20.8 ppb, respectively, for residents and 26.4 and 27.0 ppb, respectively, for current workplaces. Spirometry testing conducted in approximately 1,200 subjects did not find significant associations between TWA or maximum hydrogen sulfide levels and spirometry results (Bates et al. 2015). Dividing the subjects into groups based on whether they ever had asthma, chronic obstructive pulmonary disease (COPD), or smoking results did not alter the results. The investigators noted there was some evidence of better lung function when subjects with current high exposure were compared to subjects with low current exposure.

ATSDR (Campagna et al. 2004) examined the possible relationship between ambient levels of hydrogen sulfide and total reduced sulfur and hospital visits among residents of Dakota City and South Sioux City, Nebraska. Total reduced sulfur is the combined concentrations of hydrogen sulfide, methyl mercaptan, dimethyl sulfide, and dimethyl disulfide; air monitoring data indicate that hydrogen sulfide was the primary constituent of the total reduced sulfur. The primary sources of total reduced sulfur were a beef slaughter facility and a leather tanning facility. Among children under 18 years of age, positive associations were found between hospital visits for all respiratory disease (including asthma) and the high hydrogen sulfide level the previous day and the high levels of total reduced sulfur on the previous day. Positive associations were found between hospital visits for asthma and the previous day’s high hydrogen sulfide level in adults and total reduced sulfur in children. A high total reduced sulfur or hydrogen sulfide level was defined as a 30-minute rolling average of ≥30 ppb. Another study found a weak association between the 3-day moving average hydrogen sulfide atmospheric levels in Reykjavik Iceland and the number of individuals who were dispensed drugs for the treatment of asthma 3–5 days after the increased pollution; the excess risk was 2.0% (95% confidence interval [CI] of 0.4–3.6) (Carlsen et al. 2012). The study also found a weak association for PM_10_ levels.

An increase in symptoms of upper and lower respiratory irritation was observed in healthy, young adults exposed to 5 ppm hydrogen sulfide for 2 hours; however, the change was only 1–2 points on a 100-point scale and was not considered clinically significant (Fiedler et al. 2008).

The results of the South Karelia Air Pollution Study, which began in 1986 to evaluate the effects of air pollution on human health and the environment, was reported by several investigators: Jaakkola et al. (1990), Haahtela et al. (1992), Marttila et al. (1994a, 1994b, 1995), and Partti-Pellinen et al. (1996). In the early studies of this series (Haahtela et al. 1992; Jaakkola et al. 1990; Marttila et al. 1994b), levels of hydrogen sulfide, sulfur dioxide, particulates, and methyl mercaptan were individually reported. In the later studies (Marttila et al. 1994a, 1995; Partti-Pellinen et al. 1996), a complex mixture of ‘malodorous sulfur components’ (that included hydrogen sulfide, methyl mercaptan, and methyl sulfides) was monitored as total reduced sulfur (TRS). It is not possible, from the information provided, to determine precisely what proportion of the TRS is actually hydrogen sulfide, although the authors indicate that it is about two-thirds (Marttila et al. 1994b). The fact that in virtually all of these studies, effects were linked to exposures to mixtures, even though hydrogen sulfide appears to have been the dominant sulfur compound, complicates interpretation of these results. It is probably reasonable to conclude that these studies demonstrate that low levels of hydrogen sulfide in combination with other sulfur-containing pollutants (and possibly due to combination with particulates and/or sulfur dioxide) can have an adverse effect on respiratory health. However, it is not possible at this time to determine whether it is the low annual average values of 1–2 μg/m^3^ TRS, or the daily average concentrations (56 μg/m^3^ TRS) that are associated with these findings.

In the Jaakkola et al. (1990) study, the responses of populations from three communities (a non-polluted community, a moderately polluted community, and a severely polluted community) were compared. Initial exposure estimates were derived from dispersion modeling; these estimates were subsequently confirmed with measurements taken from monitoring stations located in the two polluted communities. These measurements indicated that both the mean and the maximum 4-hour concentrations of hydrogen sulfide were higher in the more severely polluted community (4 and 56 μg/m^3^; 2.9 and 40 ppb) than in the moderately polluted one (2 and 22 μg/m^3^; 1.4 and 16 ppb). Particulate measurements made concurrently, and sulfur dioxide measurements made subsequently, also showed higher levels in the severely polluted community. A cross-sectional, self-administered questionnaire was used to gather data on the occurrence (i.e., often or constantly) of a variety of respiratory symptoms and effects during two time periods (the past 4 weeks and the previous 12 months). The occurrences of nasal symptoms and cough were found to be significantly greater in the subjects living in the two polluted communities when compared to those in the nonpolluted community. Breathlessness/wheezing was also increased, although not to the level of statistical significance. All three of these end points showed a dose-related increase; that is, the greatest occurrence of symptoms occurred in the more highly-polluted community, followed by the less polluted, and then the nonpolluted communities. Because of the mixed exposures, however, the role of hydrogen sulfide in these effects is unclear.

A subsequent report by Marttila et al. (1994b) examined the impact of long-term exposure to the same mixture of malodorous sulfur compounds on children from these same three communities. The findings in children (i.e., nasal symptoms and cough) in the most severely polluted community were similar to those reported in the Jaakkola et al. (1990) study and showed increased risks both for the 4-week and the 12-month intervals, although none of these risks reached statistical significance. Haahtela et al. (1992) reported a significant increase in the number of residents reporting breathlessness (35%) during a period of unusually high hydrogen sulfide levels. The maximum concentration was 135 µg/m^3^ (0.096 ppm) with 24-hour average concentrations on 2 days of 35 and 43 µg/m^3^ (0.025 and 0.031 ppm). The number of residents reporting breathlessness was 2% 4 months later when the concentrations were lower (levels ranged from 0.1 to 3.5 µg/m^3^ [0.00007–0.0025 ppm] during a 4-hour period).

Marttila et al. (1995) also examined the relationship between daily exposure to malodorous sulfur compounds (measured TRS) from pulp production and reporting of symptoms in a small population living in the vicinity of a pulp mill. During the study period, daily mean TRS concentrations varied from 0 to 82 μg/m^3^, and monthly mean concentrations varied from 3 to 19 μg/m^3^. Following a baseline questionnaire, the study was conducted with six consecutive questionnaires after three predefined levels of exposure to TRS (daily mean <10 μg/m^3^, medium exposure 10–30 μg/m^3^, and high exposure >30 μg/m^3^). The study found a dose-related increase in the probability of both nasal (i.e., stuffy or runny nose) and pharyngeal irritation. For nasal symptoms, the probability ratios were 3.13 (95% CI=1.25–7.25) and 8.50 (95% CI=3.19–18.64) for medium and high exposure, respectively. For pharyngeal symptoms, the probability ratios were 2.0 (95% CI=0.92–4.14) and 5.20 (95% CI=1.95–11.99) for the medium and high exposure levels, respectively.

Partti-Pellinen et al. (1996) used a cross-sectional, self-administered questionnaire to assess the eye, respiratory tract, and central nervous system symptoms experienced by adults in a slightly polluted and a reference community. In the polluted community, the mean annual TRS concentrations were 2–3 μg/m^3^, the 24-hour average concentrations varied between 0 and 56 μg/m^3^, and the maximum 1-hour concentration was 155 μg/m^3^; there was no TRS detected in the reference community. In the polluted community, the sulfur dioxide annual mean concentration was 1 μg/m^3^, the 24-hour average concentrations varied between 0 and 24 μg/m^3^, and the maximum 1-hour concentration was 152 μg/m^3^. In the reference community, the annual mean sulfur dioxide level was 1 μg/m^3^ and the maximum 1-hour concentration was 30 μg/m^3^. Symptoms evaluated over the previous 4 weeks and previous 12 months included eye irritation, nasal irritation, cough, breathlessness or wheezing, and headache or migraine. After adjusting for age, sex, smoking, history of allergic diseases, education, and marital status, increased odds ratios were seen for all of these symptoms at both time periods (i.e., previous 4 weeks and previous 12 months). However, significant increases in odds ratios were seen only for headache or migraine in the previous 4 weeks (OR=1.82; 95% CI=1.06–31.5) and in the past 12 months (OR=1.70; 95% CI=1.05–2.73) and cough in the past 12 months (OR=1.64; 95% CI=1.01–2.64). These findings led the authors to conclude that the adverse health effects of TRS occur at lower concentrations than previously reported. However, this conclusion is confounded by daily average levels of TRS as high as 56 μg/m^3^ and by the presence of sulfur dioxide which, though occurring at the same mean annual concentration in the two communities, showed much higher peaks in the polluted community. Furthermore, no information was provided on particulate levels, which could also impact the interpretation of these findings.

A significant increase in respiratory symptoms (OR=11.92; 95% CI=4.37–12.42) was reported by residents living in two communities (Odessa, Texas and Puna, Hawaii) with chronic low levels of industrial sources of hydrogen sulfide, as compared to residents living in two comparable communities without known sources of hydrogen sulfide pollution (Legator et al. 2001). The most commonly reported respiratory symptoms were wheezing (25–30%), shortness of breath (40–45%), and persistent cough (10%); each of these effects had an incidence of approximately 5% in the referent communities. Increases in similar respiratory symptoms were also observed in residents of communities where toxic waste containing high levels of hydrogen sulfide were illegally dumped in Côte d’Ivoire (Dongo et al. 2012), in residents living near sour gas/oil fields (sour gas is natural gas containing significant amounts of hydrogen sulfide) in southeast New Mexico (Kilburn et al. 2010), and in communities near swine feeding operations in east North Carolina (Schinasi et al. 2011). A positive association was found between 12-hour mean hydrogen sulfide atmospheric concentrations and the incidence of self-reported signs of respiratory effects (particularly runny nose, wheezing, and difficulty breathing and nasal irritation) (Schinasi et al. 2011).

Bhambhani and associates conducted a number of studies in young healthy volunteers exposed to hydrogen sulfide during exercise via a mouthpiece; the subjects were unable to smell the hydrogen sulfide and their eyes were not exposed to the gas. Male volunteers were exposed to hydrogen sulfide concentrations up to 5 ppm for >16 minutes after graded exercise that was performed to exhaustion (Bhambhani and Singh 1991). No effects on expired ventilation or maximum power output were noted, but exposure to 5 ppm resulted in a significant increase in maximum oxygen uptake compared to controls. Since there were no alterations in maximum cardiac output, the study authors concluded that the increase in oxygen uptake was likely due to oxygen being utilized to oxidize sulfide to sulfate rather than an increase in the amount of oxygen being utilized by exercising muscles. At exposures to 2 and 5 ppm, the respiratory exchange ratio was decreased significantly compared to controls. The study authors attributed this to a nonsignificant trend toward increased oxygen uptake and decreased carbon dioxide output compared to controls (Bhambhani and Singh 1991). Another study examined the effects of inhalation of 5 ppm hydrogen sulfide on respiratory physiological parameters and found no changes in the partial pressure of oxygen, partial pressure of carbon dioxide, oxygen uptake, percentage of oxygen uptake, uptake of carbon dioxide and minute volume, or respiratory exchange ratio in male or female volunteers during 30 minutes of submaximal exercise (Bhambhani et al. 1994). Exposure to 10 ppm of hydrogen sulfide for 15 minutes during submaximal exercise did not result in significantly altered pulmonary function test results in men and women (Bhambhani et al. 1996a) or changes in oxygen partial pressure, carbon dioxide partial pressure, oxygen saturation, or pH in men or women (Bhambhani et al. 1997). However, exposure to 10 ppm hydrogen sulfide did significantly reduce oxygen uptake, but had no effect on carbon dioxide uptake or minute volume. The magnitude in the decrease in oxygen uptake was small (5–18%), but was observed in ≥70% of the subjects.

Pulmonary function tests were performed on persons with asthma exposed to 2 ppm of hydrogen sulfide for 30 minutes in a sealed chamber (Jappinen et al. 1990). Although no significant changes were noted in airway resistance or specific airway conductance as a group, 2 of 10 subjects showed changes in excess of 30% in both airway resistance and specific airway conductance (suggestive of bronchial obstruction). No statistically significant changes were noted in forced vital capacity (FVC), forced expiratory volume in 1 second (FEV_1_), and forced expiratory flow (Jappinen et al. 1990). Pulmonary function was unaffected following the same exposure protocol in 26 male pulp mill workers who had previously had daily hydrogen sulfide exposures, usually to <10 ppm (Jappinen et al. 1990). No significant changes were noted in FVC, FEV_1_, or bronchial responsiveness to histamine challenge in this group of workers (which included subgroups of smokers, workers with previous allergies, and atopic individuals).

In a study of residents living near a hog manure lagoon, an increased frequency of shortness of breath while climbing stairs was observed when compared to residents living 3 km from the lagoons or residents living in another state. However, there were no increases in the frequency of shortness of breath while at rest or while walking (Kilburn 2012). Expiratory flows and vital capacity were also significantly decreased in the exposed residents; a higher incidence of chest tightness, dry mouth, and throat tightness was also reported. The hydrogen sulfide exposure levels were poorly quantified and the residents were likely exposed to other contaminants. The investigators noted that the levels of hydrogen sulfide in indoor air samples from 12 homes ranged from 0 to 2,100 ppb and that the levels of two outdoor samples were >1,000 ppb.

Hessel et al. (1997) examined the pulmonary health effects of hydrogen sulfide exposure in a group of Canadian oil and gas workers. Exposure to hydrogen sulfide was assessed by questionnaire as was the occurrence of respiratory symptoms. In addition, smoking and occupational histories were conducted. Lung health was assessed via spirometric testing and by skin prick testing for six common antigens. The workers were divided into three exposure groups: no hydrogen sulfide exposure, hydrogen sulfide exposure sufficient to produce symptoms, and hydrogen sulfide exposure high enough to cause unconsciousness (knockdown). None of the lung function indicators (FEV_1_, FVC, or FEV_1_/FVC) differed significantly among the three groups. Significantly increased odds ratios (ORs) were seen only in those in the knockdown group who showed significant excesses for several symptoms including shortness of breath (OR=3.55; 95% CI=1.02–12.4), wheeze with chest tightness (OR=5.15; 95% CI=1.29–20.6), and attacks of wheeze (OR=5.08; 95% CI=1.28–20.6).

In a cross-sectional study of sewer and water treatment workers, Richardson (1995) evaluated the association of hydrogen sulfide exposures to reduced lung function using spirometric testing. Job titles were used to categorize sewer workers into high, medium, and low exposure groups; however, there was no quantification of hydrogen sulfide levels. Water treatment workers who were not occupationally exposed to hydrogen sulfide were chosen as a comparison group. Findings included significant differences between spirometric values (FEV_1_/FVC) of sewer and water treatment workers across a number of age strata, irrespective of smoking status (although smoking status reduced the impact somewhat). When stratified by presumed exposure to hydrogen sulfide, only those sewer workers with presumed high exposure showed a significant difference from water treatment workers (although a dose-related trend in lung function at both medium and high exposures was observed). In addition, the prevalence OR for obstructive lung disease was 21.0 (95% CI=2.4–237.8) in nonsmoking sewer workers with presumed high hydrogen sulfide exposure when compared to nonsmoking water treatment workers. The prevalence odds ratio for sewer workers who smoked versus water treatment workers who smoked was 1.7 (95% CI=0.2–13.6).

In addition to an increase in respiration rate that was noted in Wistar rats exposed to 100–200 ppm hydrogen sulfide for 1 hour (Higuchi and Fukamachi 1977), a number of histological and biochemical changes have been noted in the respiratory tissues and fluids of animals acutely exposed to hydrogen sulfide. Cytotoxicity to both nasal or bronchioalveolar lavage and pulmonary cells was demonstrated in a study of male F-344 rats exposed to 0, 10, 200, or 400 ppm hydrogen sulfide for 4 hours and examined at 1, 20, or 44 hours postexposure (Lopez et al. 1987). Cellularity of nasal lavage fluid was increased at all exposure concentrations (due to either exfoliation of degenerated epithelial cells at 1 hour, or exudation of polymorphonuclear leukocytes (PMNs) at 20 hours postexposure) which served as an indicator of cell damage. Altered pulmonary vascular permeability (indicated by increased protein in nasal lavage fluids) was observed in animals exposed to airborne concentrations of 400 ppm; this condition resolved by 20 hours postexposure. The increased lactate dehydrogenase activity (at exposure levels of 200 and 400 ppm) and alkaline phosphatase activity (with exposure to 400 ppm) in bronchoalveolar lavage fluid were indicative of toxic effects on the pulmonary epithelium. In addition, pulmonary alveolar macrophages from animals exposed to 200 or 400 ppm hydrogen sulfide had some increase in cytoplasmic vacuolation, but the bronchoalveolar epithelium did not show signs of cellular degeneration or ciliocytophthoria (Lopez et al. 1987).

In similar experiments, Green et al. (1991) exposed male F-344 rats to 200 and 300 ppm hydrogen sulfide for 4 hours and evaluated the impact on lung lavage fluid surface tension, protein concentrations, and lactate dehydrogenase activity. These authors found significant increases in protein concentrations and lactate dehydrogenase activity at both exposure concentrations, but a significant change in the surface tension of lavage fluids only at the higher dose. Focal areas of perivascular edema and proteinaceous material in the alveoli were also seen in the lungs of the animals exposed to 200 or 300 ppm.

Histopathological changes have been reported in the nasal cavity of F-344 rats (Lopez et al. 1988b). Male rats were exposed to 0, 10, 200, or 400 ppm hydrogen sulfide for 4 hours. Necrosis and exfoliation of the respiratory and olfactory mucosal cells were observed 1 hour postexposure at concentrations >200 ppm. By 20 hours postexposure, the respiratory epithelium was covered by a layer of deeply basophilic cells containing mitotic figures and a severe inflammatory response was noted. The necrosis ultimately ulcerated the respiratory epithelium, causing exposure of the basement membrane (Lopez et al. 1988b). Although some histological changes were observed at 10 and 200 ppm hydrogen sulfide, no dose response was evident; it appears that a concentration >200 ppm is necessary to induce these lesions (Lopez et al. 1988b).

Similarly, Brenneman et al. (2002) observed bilateral symmetrical mucosal necrosis in the nasal olfactory epithelium and respiratory epithelial regeneration in rats exposed to 200 or 400 ppm hydrogen sulfide for 3 hours; the NOAEL for these effects is 80 ppm. However, the respiratory epithelium was not adversely affected in rats similarly exposed 3 hours/day for 5 days (Brenneman et al. 2002). In these rats, necrotic olfactory epithelium and hyperplastic basal cells were observed when exposed to 80, 200, or 400 ppm, but not at 30 ppm. A partial regeneration of the olfactory epithelium was observed 2 weeks after exposure termination and a complete regeneration was observed 6 weeks postexposure.

In another study, bilaterally symmetrically, mild respiratory epithelial damage was also observed in rats exposed to 200 ppm hydrogen sulfide for 3 hours (Roberts et al. 2008). Infiltration with inflammatory cells was observed 3 hours postexposure, epithelial sloughing and loss of the basal cellular structure were observed 6 hours postexposure, and epithelial regeneration was observed at 24 hours postexposure. A complete recovery of the epithelial damage was observed after 5 consecutive days of exposure to 200 ppm for 3 hours/day (Roberts et al. 2008).

Cytochrome c oxidase activity in lung mitochondria of F-344 rats was significantly decreased at 50 ppm (15%), 200 ppm (43%), and 400 ppm (68%) hydrogen sulfide compared to controls after a 4-hour exposure (Khan et al. 1990). By 24 hours postexposure, cytochrome c oxidase activity had returned to normal for animals exposed to 200 ppm, but not for those exposed to 400 ppm. Succinate oxidase activity was reduced at 200 ppm (40%) and 400 ppm (63%), but was not affected at 50 ppm (Khan et al. 1990). A 5-week exposure to 10 or 100 ppm hydrogen sulfide (8 hours/day, 5 days/week) also resulted in significant decreases in cytochrome oxidase activity in lung mitochondria (Khan et al. 1998); exposure to 1 ppm did not result in significant alterations.

Significant decreases in numbers of viable pulmonary alveolar macrophages were noted in the lung lavage fluid of male rats exposed for 4 hours to 400 ppm hydrogen sulfide (Khan et al. 1991). This study also showed complete abolition of zymosan-induced stimulation of respiratory rates of pulmonary alveolar macrophages in animals exposed to 200 or 400 ppm. No changes were noted after exposure to 50 ppm hydrogen sulfide.

Histological changes were characterized in the lungs of male F-344 rats exposed to 83 or 439 ppm for 4 hours (Lopez et al. 1988a). At the lower concentration, mild perivascular edema was found. At the higher concentration, numerous changes were observed including severe but transient pulmonary edema and fibrocellular alveolitis in proximal alveoli, cytoplasmic blebs in the alveolar endothelium; increased numbers of mitotic figures in the bronchiolar epithelium, minor changes in the alveolar epithelium, and necrosis of the ciliated bronchiolar cells. Other studies found slight pulmonary congestion in male Wistar rats exposed to 75 ppm hydrogen sulfide for 1 hour (Kohno et al. 1991) and moderate-to-massive pulmonary edema in male F-344 rats exposed to 375 or 399 ppm for 4 hours (Prior et al. 1990).

The effects of intermediate-duration exposures to hydrogen sulfide have been examined in rats, mice, and pigs. Respiratory effects were not observed in F-344 (CIIT 1983b) or Sprague-Dawley (CIIT 1983c) rats exposed to hydrogen sulfide at concentrations up to 80 ppm 6 hours/day, 5 days/week for 90 days. However, a re-examination of the histologic specimens from this study (Dorman et al. 2004) found significant increases in the incidence of olfactory neuron loss in Sprague-Dawley and F-344 rats exposed to 30 or 80 ppm and in male rats exposed to 80 ppm; the no-effect levels in these strains were 10 and 30 ppm, respectively. In addition, increases in the incidence of bronchiolar epithelial hypertrophy and hyperplasia were observed in the female Sprague-Dawley rats exposed to 30 or 80 ppm hydrogen sulfide and in male Sprague-Dawley and F-344 rats exposed to 80 ppm. These findings are similar to those of Brenneman et al. (2000) who found significant increases in the incidence and severity of nasal lesions in male Sprague-Dawley rats exposed to hydrogen sulfide for 6 hours/day, 7 days/week for 10 weeks. The nasal lesions, which were limited to the olfactory mucosa, consisted of multifocal, bilaterally symmetrical olfactory neuron loss, and basal cell hyperplasia. The olfactory neuron loss and basal cell hyperplasia was found in most animals exposed to 30 or 80 ppm, but was not found in controls or rats exposed to 10 ppm. At 30 ppm, the severity of the olfactory neuron loss and basal cell hyperplasia was graded as mild to moderate. At 80 ppm, the severity of the olfactory neuron loss was moderate to severe and the basal cell hyperplasia was scored as mild.

Inflammation of the nasal mucosa described as minimal to mild rhinitis was observed in B6C3F_1_ mice exposed to hydrogen sulfide at 80 ppm for 6 hours/day, 5 days/week for 90 days (CIIT 1983a); these lesions were not observed at 30 ppm. A re-examination of the histological specimens from this study confirmed these results (Dorman et al. 2004) and also found significant increases in the incidence of olfactory neuron loss in the nasal olfactory epithelium of male and female mice exposed to 30 or 80 ppm, but not at 10 ppm.

Three crossbred pigs of unspecified sex were continuously exposed to 0 or 8.5 ppm hydrogen sulfide in inhalation chambers for 17 days (Curtis et al. 1975). No significant changes in body weight gain and no histopathological changes in the respiratory tract (including turbinates, trachea, and lungs) were noted. This study is limited by the number of animals used and because only one exposure concentration was used.

In summary, short- and long-term studies in humans and animals provide strong evidence that the respiratory tract is a sensitive target of hydrogen sulfide toxicity. Studies in communities living near a source of hydrogen sulfide pollution have found increases in respiratory symptoms, particularly signs of nasal irritation, cough, and shortness of breath (Haahtela et al. 1992; Jaakkola et al. 1990; Legator et al. 2001; Marttila et al. 1995; Partti-Pellinen et al. 1996; Schinasi et al. 2011), worsening of asthma symptoms (Campagna et al. 2004; Carlsen et al. 2012), and alterations in lung function (Kilburn 2012). Occupational exposure studies have found altered lung function and increased odds of obstructive lung disease among sewer workers with presumed high exposure (Richardson 1995) and increased prevalence of shortness of breath and wheezing without an effect on lung function among oil and gas workers with the highest exposure to hydrogen sulfide (Hessel et al. 1997). A major limitation of the community and occupational exposure studies is the lack of reliable hydrogen sulfide exposure data and concomitant exposure to other substances, including other sulfur compounds and particulate matter. Human experimental studies have not found alterations in lung function in healthy exercising subjects exposed to 5 ppm for 16 or 30 minutes or 10 ppm for 15 minutes (Bhambhani and Singh 1991; Bhambhani et al. 1994, 1996a). A decrease in airway resistance and conductance was observed in 20% of asthmatics exposed to 2 ppm for 10 minutes, although the change in the whole group was not significantly different from controls (Jappinen et al. 1990). In rats, a 3- or 4-hour exposure to ≥200 ppm resulted in necrosis and exfoliation of the nasal respiratory and olfactory epithelial cells (Brenneman et al. 2002; Lopez et al. 1988b; Roberts et al. 2008); the NOAEL for these effects was 80 ppm (Brenneman et al. 2002). Exposure to ≥75 ppm for 1–4 hours resulted in pulmonary edema with increasing severity as exposure levels increased (Kohno et al. 1991; Lopez et al. 1988a; Prior et al. 1990). Repeated exposure to ≥30 ppm resulted in olfactory neuronal loss in the nasal cavity of rats and mice (Brenneman et al. 2000; CIIT 1983a, 1983b, 1983c; Dorman et al. 2004); the NOAEL was 10 ppm.

Carbonyl Sulfide. No studies were located regarding respiratory effects in humans after inhalation exposure to carbonyl sulfide.

Only one study has examined the respiratory tract in animals following inhalation exposure to carbonyl sulfide. No morphological alterations were observed in the lungs of rabbits continuously exposed to 54 ppm for 7 weeks (Kamstrup and Hugod 1979).

##### Cardiovascular Effects.

Hydrogen Sulfide. Cardiovascular effects have been noted after acute exposures to high concentrations of hydrogen sulfide via inhalation (Arnold et al. 1985). Slight blood pressure increases were noted in several workers exposed to hydrogen sulfide in a pelt room, however, their electrocardiograms (EKGs) were normal (Audeau et al. 1985). In other instances of hydrogen sulfide poisoning that occurred after a short exposure to high concentrations, no changes in blood pressure were noted despite other cardiac irregularities (Ravizza et al. 1982). Hemodynamic instability was noted in one of two men who survived acute exposure to an unknown concentration of hydrogen sulfide and also swallowed large amounts of manure after entering a partially drained liquid manure pit (Osbern and Crapo 1981). Sinus tachycardia has been noted in men who completely recovered after exposure to hydrogen sulfide (Peters 1981; Ravizza et al. 1982). Supraventricular tachycardia and left bundle branch block were noted in a worker exposed to hydrogen sulfide generated from a sodium sulfide waste solution dumped onto acid waste material; the effects were temporary (Stine et al. 1976). Extreme tachycardia and hypotension were noted in a woman who attempted to clean a well with muriatic acid and was exposed to an unknown concentration of hydrogen sulfide gas; hypertension was noted in a man exposed during this same incident (Thoman 1969).

EKGs taken on two workers about 2.5 hours after an acute exposure to hydrogen sulfide showed cardiac arrhythmias (Krekel 1964). The workers were exposed for <5 minutes after a spill of sodium sulfide that broke down to release hydrogen sulfide. In one individual, a negative P wave (also referred to as an inverted P wave) likely indicative of an ectopic atrial rhythm was noted; in the other individual, a continuous arrhythmia due to atrial flutter was found. EKGs for both men returned to normal within 24 hours.

No adverse cardiovascular effects were found when healthy male volunteers were exposed to hydrogen sulfide concentrations up to 5 ppm for >16 minutes after graded exercise performed to exhaustion (Bhambhani and Singh 1991). A study that examined the effects of inhalation of 5 ppm hydrogen sulfide on physiological parameters found no changes in heart rate, blood pressure, percent hemoglobin saturation, perceived exertion, or other parameters in healthy male and female volunteers during 30 minutes of submaximal exercise (Bhambhani et al. 1994). A subsequent study examining the effects of inhaling 10 ppm hydrogen sulfide during two 30-minute sessions of submaximal exercise found no significant changes in cardiovascular responses under these conditions (Bhambhani et al. 1997).

In a retrospective epidemiologic study using hospital discharge data from 1981 to 1990, Bates et al. (1998) evaluated the risk of disease to known target organ systems of hydrogen sulfide toxicity in residents of Rotorua, a New Zealand city that uses geothermal energy for industrial and domestic heating purposes. A significant increase in incidence was found for diseases of the circulatory system (SIR=1.05; p=0.001) among Rotorua residents as compared to all other New Zealand residents. Although previous monitoring information from Rotorua in 1978 showed a median concentration of hydrogen sulfide of 20 μg/m^3^, with 35% of the measurements over 70 μg/m^3^ and 10% over 400 μg/m^3^ (Bates et al. 1997), the lack of monitoring information in the Bates et al. (1998) study precludes conclusions with regard to a causal relationship between circulatory system disease and hydrogen sulfide exposures. Using hospital discharge records for 1993–1996, Bates et al. (2002) attempted to examine exposure-related trends for cardiovascular disease among residents of Rotorua. Residents were divided into three exposure categories (low, medium, and high) based on surrogate exposure data. A statistically significant (p<0.001) trend for exposure-related increases in the incidence of circulatory system disease was observed. When the circulatory system disease category was further divided into minor disease categories, significant (p<0.01) exposure-related trends for cerebrovascular disease and diseases of arteries, arterioles, and capillaries were found. However, no significant increases in SIRs were found for the cerebrovascular disease category. For artery, arteriole, and capillary disease category, the SIRs were significantly elevated for the medium (SIR=1.58, 95% confidence level of 1.17–2.08) and high (SIR=1.66, 95% CI of 1.30–2.09) exposure groups. The lack of exposure data, the assumption that hydrogen sulfide exposure only occurred at home, and the lack of control for potential confounding factors such as smoking and socioeconomic status limit the interpretation of these data.

Studies in experimental animals have reported EKG alterations (e.g., cardiac arrhythmia) following acute-duration exposure to 72–75 ppm for 1.5 hours or less (Kohno et al. 1991; Kosmider et al. 1967); however, the lack of statistical analysis precludes interpretation of these studies. Alterations in heart rate have also been reported. A decrease in heart rate (10–27% of controls) was observed in rats exposed to 75 ppm for 60 minutes (Kohno et al. 1991). In contrast, another study found an increase in heart rates in rats exposed to 100–200 ppm for 1 hour (Higuchi and Fukamachi 1977). The differences may be reflective of the different exposure levels. Significant increases in serum cardiac enzyme levels (aspartate aminotransferase [AST], creatinine kinase, lactate dehydrogenase) and cardiac troponin I activity was observed in rats exposed to 300 ppm hydrogen sulfide for 60 minutes (Wu et al. 2011).

Data on the cardiotoxicity of hydrogen sulfide following longer-term exposure is limited to a study by CIIT (1983a, 1983b, 1983c). This study found no treatment-related histopathological alterations in the cardiovascular system of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed via inhalation to time-weighted-average concentrations of 10, 30, or 80 ppm hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c).

Carbonyl Sulfide. No studies were located regarding cardiovascular effects in humans after inhalation exposure to carbonyl sulfide.

No morphological alterations were observed in the coronary arteries, aortic arch, descending thoracic aorta, or pulmonary arteries (Hugod and Astrup 1980; Kamstrup and Hugod 1979) and no myocardial ultrastructural changes (Hugod 1981) were found in rabbits continuously exposed to 54 ppm carbonyl sulfide for 7 weeks.

##### Gastrointestinal Effects.

Hydrogen Sulfide. Nausea and vomiting have been noted in several cases of human inhalational hydrogen sulfide poisoning (Allyn 1931; Audeau et al. 1985; Deng and Chang 1987; Krekel 1964; Osbern and Crapo 1981; Thoman 1969).

In two evaluations of the acute health effects associated with communities experiencing episodes of high emissions containing hydrogen sulfide, significant increases in nausea were reported (Haahtela et al. 1992; Marttila et al. 1995). In the first study, increased emissions from a pulp mill resulted in increased concentrations of hydrogen sulfide over 2 days. The highest 4-hour concentration of hydrogen sulfide was 135 μg/m^3^ (96.4 ppb) and the 24-hour averages for the 2 days were 35 and 43 μg/m^3^ (25 and 31 ppb). Following the high exposure, and then after a low exposure period (hydrogen sulfide level of 0.1 to 3.5 μg/m^3^ [0.07–2.5 ppb] for 4 hours), community responses were evaluated with a questionnaire. It was noted that the sulfur dioxide levels were the same at both the higher and lower hydrogen sulfide exposure levels. A significant increase in the incidence of reported nausea was found during the high exposure period (23%) as compared to the incidence during the low exposure period (5%). In the second study, Marttila et al. (1995) compared community responses using six consecutive questionnaires after three predefined levels of exposure. The three exposure levels were expressed as μg/m^3^ of TRS as a way to summarize the complex pollution mixture of hydrogen sulfide, methyl mercaptan, and methylsulfides produced by pulp mills using the sulfate pulping method. The three categories of exposure were low (daily mean of TRS <10 μg/m^3^), medium (10–30 μg/m^3^), and high exposure (>30 μg/m^3^). An increase in reports of nausea was significant only with the highest level of exposure. Interpretation of these results is complicated by the presence of multiple sulfur compounds as well as other air pollutants. Earlier work indicated that hydrogen sulfide represented two-thirds of the TRS (Marttila et al. 1994a). Concurrent measurements of sulfur dioxide, total suspended particles, and nitrogen oxides for the periods covered by each of the questionnaires indicated that only sulfur dioxide appeared to co-vary with TRS.

No treatment-related histopathological changes were detected in the gastrointestinal tract of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed via inhalation to TWA concentrations of 10, 30, or 80 ppm hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). No gastrointestinal effects were reported in crossbred pigs exposed to 8.5 ppm hydrogen sulfide for 24 hour s/day for 17 days (Curtis et al. 1975).

Carbonyl Sulfide. No studies were located regarding gastrointestinal effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Hematological Effects.

Hydrogen Sulfide. The cyanosis that has been reported in a number of cases of accidental exposure to hydrogen sulfide is believed to result from respiratory distress (Arnold et al. 1985; Burnett et al. 1977; Deng and Chang 1987; Peters 1981; Ravizza et al. 1982; Stine et al. 1976; Tvedt et al. 1991a, 1991b).

Complete blood counts were within normal limits in four individuals overcome by unknown concentrations of hydrogen sulfide gas in a pelt room (Audeau et al. 1985). Percent hemoglobin saturation was unchanged by inhalation of either 5 ppm hydrogen sulfide by volunteers during 30-minutes of submaximal exercise (Bhambhani et al. 1994), or 10 ppm hydrogen sulfide during two 30-minute sessions of submaximal exercise (Bhambhani et al. 1997).

Workers who were sometimes exposed to airborne concentrations of >20 ppm hydrogen sulfide did not have any changes in hematological parameters (Ahlborg 1951). Pulp industry workers (n=17) exposed to 8-hour TWA concentrations of 0.05–5.2 ppm hydrogen sulfide had no signs of clinical anemia (Tenhunen et al. 1983). Jappinen and Tenhunen (1990) examined blood sulfide concentration and changes in heme metabolism at 2 hours, 1 week, and 1 month post-hydrogen sulfide poisoning in six cases of occupational exposure. Decreased delta-aminolevulinic acid synthase activity and erythrocyte protoporphyrin concentration were noted at the 2-hour and 1-week time periods, but not to the level of statistical significance, and there was no change in heme synthase activity.

No treatment-related changes in hematological parameters were noted in F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed by inhalation to TWA concentrations of 10, 30, or 80 ppm of hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). Laug and Draize (1942) reported increased sulfhemoglobin levels in rabbits exposed for at least 20 minutes to unspecified levels of hydrogen sulfide.

Carbonyl Sulfide. One study examined the potential of carbonyl sulfide to induce hematological alterations. In rats exposed to carbonyl sulfide for 11 days, significant increases in methemoglobin levels were observed at ≥151 ppm; however, the magnitude of the methemoglobin levels in treated animals (1.3–2.3% compared to 0.8–1.0% in controls) was low and was not considered toxicologically relevant. Decreases in erythrocyte count, hematocrit, mean corpuscular volume, mean corpuscular hemoglobin, and mean corpuscular hemoglobin concentration were observed in female rats exposed to 151 or 253 ppm, but were not observed at 453 ppm or in males. The lack of concentration-response and the finding in only one sex suggest that these alterations may not be related to carbonyl sulfide exposure.

##### Musculoskeletal Effects.

Hydrogen Sulfide. In a series of reports characterizing the responses of healthy volunteers to low level, short-term exposures to hydrogen sulfide, Bhambhani and his colleagues (Bhambhani and Singh 1991; Bhambhani et al. 1994, 1996a, 1996b, 1997) concluded that exposures to 5 or 10 ppm hydrogen sulfide via oral inhalation resulted in increases in blood lactate concentrations and decreases in muscle citrate synthase activity that was indicative of an inhibition of the aerobic capacity of exercising muscle. Men appeared to be more sensitive to this effect, showing a small response at 5 ppm where women did not show an effect until the 10 ppm level (Bhambhani et al. 1996b, 1997).

No treatment-related histopathological changes were detected in the skeletal muscle, bone marrow, or bone of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c).

Carbonyl Sulfide. No studies were located regarding musculoskeletal effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Hepatic Effects.

Hydrogen Sulfide. A retrospective study of 221 gas and oil workers exposed to hydrogen sulfide measured unspecified liver enzyme activity in about 30% of the subjects exposed by inhalation to hydrogen sulfide (Burnett et al. 1977). The investigators noted that abnormalities were detected in several subjects; no additional information was provided.

No changes in serum protein, lactate dehydrogenase (LDH), serum glutamic-oxaloacetic transaminase (SGOT; also referred to as aspartate aminotransferase [AST]), or alkaline phosphatase activity were noted in Sprague-Dawley rat dams exposed to 20, 50, or 75 ppm of hydrogen sulfide for 7 hours/day from gestation day 1 through postnatal day 21 (Hayden et al. 1990a). Maternal liver cholesterol levels were increased in Sprague-Dawley dams exposed to 75 ppm, but not 50 ppm, for 7 hours/day from gestation day 6 to postpartum day 21 (Hayden et al. 1990b).

No treatment-related histopathological changes were detected in the livers of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm of hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). No gross or histopathological lesions were found in the livers of crossbred pigs exposed to 8.5 ppm of hydrogen sulfide continuously for 17 days (Curtis et al. 1975).

Carbonyl Sulfide. No studies were located regarding hepatic effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Renal Effects.

Hydrogen Sulfide. Blood urea nitrogen and serum electrolyte levels were within the normal range in several individuals overcome by unknown concentrations of hydrogen sulfide gas in a pelt room (Audeau et al. 1985). One of these four patients had protein and blood in the urine initially, which was not detected upon later testing. Albumin and some granular casts were noted in the urine in another patient, but these findings were transient (Audeau et al. 1985).

F-344 and Sprague-Dawley rats as well as B6C3F_1_ mice were exposed to TWA concentrations of 10, 30, or 80 ppm of hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). No treatment-related histopathological changes were detected in the kidneys of these animals and urinalysis findings were negative, suggesting no renal effects due to hydrogen sulfide exposure. No gross or histopathological lesions were found in the kidneys of crossbred pigs exposed to 8.5 ppm of hydrogen sulfide continuously for 17 days (Curtis et al. 1975).

Carbonyl Sulfide. No studies were located regarding renal effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Endocrine Effects.

Hydrogen Sulfide. No studies were located regarding endocrine effects in humans after inhalation exposure to hydrogen sulfide.

No treatment-related histopathological changes were detected in the pituitary, adrenal, thyroid, or parathyroid glands of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c).

Carbonyl Sulfide. No studies were located regarding endocrine effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Dermal Effects.

Hydrogen Sulfide. Six men lost consciousness after acute hydrogen sulfide exposure; one man with probable exposure to 8–16 ppm had peeling facial skin (Tvedt et al. 1991a, 1991b).

No treatment-related histopathological changes were detected in the skin of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). Slate-grey skin discoloration (which may have been related to increased sulfhemoglobin levels) and erythema were noted in rabbits exposed to unspecified concentrations of hydrogen sulfide for 2 hours (Laug and Draize 1942).

Carbonyl Sulfide. No studies were located regarding dermal effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Ocular Effects.

Hydrogen Sulfide. Ocular effects reported after inhalation exposure are believed to have resulted from direct eye contact with hydrogen sulfide gas. Hydrogen sulfide gas is an eye irritant. Keratoconjunctivitis (sometimes with subsequent infection), punctate corneal erosion, blepharospasm, lacrimation, and photophobia have developed in individuals exposed to brief high-level concentrations of hydrogen sulfide gas (Ahlborg 1951; Luck and Kaye 1989). Hemorrhagic keratoconjunctivitis and subconjunctival hemorrhage were reported in cases of near-lethal poisoning to unknown concentrations of hydrogen sulfide (Deng and Chang 1987; Stine et al. 1976). A retrospective study of 250 Canadian workers who submitted workers’ compensation claims for hydrogen sulfide exposure found that 18% had developed conjunctivitis, which persisted for several days in some cases (Arnold et al. 1985). Stinging of the eyes has been reported in acute occupational hydrogen sulfide poisoning (Audeau et al. 1985). None of these reports of ocular exposure suggested that permanent eye effects may occur (Ahlborg 1951; Arnold et al. 1985; Audeau et al. 1985; Deng and Chang 1987; Luck and Kaye 1989; Stine et al. 1976). People exposed to hydrogen sulfide, methyl mercaptan, and methyl sulfides while living in a community around a paper mill reported eye irritation 12 times more often than people without exposure (Jaakkola et al. 1990). These effects were observed at mean annual hydrogen sulfide exposures estimated at 6 μg/m^3^ (4.3 ppb). However, the ocular symptoms that were reported may have been due to exposure to peak concentrations of hydrogen sulfide (daily peaks as high as 100 μg/m^3^; 70 ppb), and not annual mean concentrations. The ocular effects may have also been due to co-exposure to methyl mercaptan and methyl sulfides. Methyl mercaptan is also an eye irritant and it was also present at an annual mean concentration of 2–5 μg/m^3^ with the highest daily average concentration being 50 μg/m^3^ (Jaakkola et al. 1990).

In a retrospective epidemiologic study using hospital discharge data from 1981 to 1990, Bates et al. (1998) evaluated the risk of disease to known target organ systems of hydrogen sulfide toxicity in residents of Rotorua, a New Zealand city that uses geothermal energy for industrial and domestic heating purposes. No information on hydrogen sulfide levels was presented in this report, but the authors indicate concerns that exposures to hydrogen sulfide and/or mercury from geothermal sources could have health impacts. In their previous work, it was indicated that the most reliable monitoring information for hydrogen sulfide in the area came from a monitoring exercise in 1978, which found a median concentration of hydrogen sulfide of 20 μg/m^3^, with 35% of the measurements >70 μg/m^3^ and 10% >400 μg/m^3^ (Bates et al. 1997). On the basis of hospital discharge data, significant increases in incidence were found for diseases of the nervous system and sense organs (SIR=1.11; p<0.001) among Rotorua residents as compared to the rest of New Zealand. When incidence rates were examined for minor disease groupings within this group of nervous system and sense organ diseases, significantly increased risks were seen for other disorders of the eye and adnexa (SIR=1.12; p<0.001). At the level of individual diseases, statistically significant incidence ratios were found for cataract (SIR=1.26; p<0.001), disorders of the conjunctiva (SIR=2.09; p<0.001), and disorders of the orbit (SIR=1.69; p=0.005). In a subsequent study by this group in which the Rotorua residents were divided into three groups based on expected exposure levels, there was an increase in the incidence of disorders of the eye and adnexa (SIR=1.38; 95% CIs of 1.16–1.64) in the high exposure group when compared to the incidence in the low exposure group (Bates et al. 2002). The incidence in the medium exposure group was not significantly higher than the low exposure group. The effect of hydrogen sulfide on the eye is of considerable importance because ocular effects occur at concentrations that provide no other observable systemic effect (NIOSH 1977a). As noted previously, interpretation of the results of the Bates et al. (1997, 2002) studies is limited by the lack of concurrent monitoring data and examination of potential exposure to other compounds.

Ocular irritation has also been noted after animals were exposed to hydrogen sulfide. Epiphora was noted in F-344 rats exposed to 400 ppm of hydrogen sulfide for 4 hours (Lopez et al. 1988b); effects were not observed at 200 ppm. Eye irritation was noted in guinea pigs exposed to 20 ppm of hydrogen sulfide 1 hour/day for 20 days (Haider et al. 1980). No ocular lesions were found upon microscopic examination of the eyes of crossbred pigs exposed to 8.5 ppm of hydrogen sulfide 24 hours/day for 17 days (Curtis et al. 1975).

No treatment-related histopathological changes were detected in the eyes of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm of hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c).

Carbonyl Sulfide. No studies were located regarding ocular effects in humans or animals after inhalation exposure to carbonyl sulfide.

##### Body Weight Effects.

Hydrogen Sulfide. No studies were located regarding body weight effects in humans after inhalation exposure to hydrogen sulfide.

Pregnant Sprague-Dawley rats exposed to 100 or 150 ppm hydrogen sulfide on gestation days 6–20 showed decreased body weight gains that reached significance at the higher dose. Absolute weight gain (i.e., minus the gravid uterine weight) was significantly depressed at both of these doses. Exposure at 50 ppm hydrogen sulfide had no effect on body weight gain or on absolute weight gain (Saillenfait al. 1989). No effects on body weight were noted in Sprague-Dawley rats exposed to 50 ppm of hydrogen sulfide 5 days/week for 25 weeks (Gagnaire et al. 1986). No treatment-related body weight changes were noted in F-344 rats exposed to TWA airborne concentrations of 10, 30, or 80 ppm of hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983b). However, when Sprague-Dawley rats were exposed on the same regimen, females at 80 ppm showed a significant (10%) decrease in body weight at the end of the study compared to controls, which was not evident at 30 ppm (CIIT 1983c). At 80 ppm, the body weight of males was significantly less (8%) than controls during weeks 1–3, but the final body weight differences were not statistically significant (CIIT 1983c). Similarly, B6C3F_1_ mice of both sexes exposed to TWA concentrations of 80 ppm hydrogen sulfide 6 hours/day, 5 days/week for 90 days showed decreases in body weight of 7–14% compared to controls; these changes were not observed at 30 ppm (CIIT 1983a). No body weight changes were found in crossbred pigs exposed to 8.5 ppm hydrogen sulfide continuously for 17 days (Curtis et al. 1975).

Carbonyl Sulfide. No studies were located regarding body weight effects in humans after inhalation exposure to carbonyl sulfide.

No alterations in body weight were observed in rats exposed to 453 ppm carbonyl sulfide for 11 exposure days (Monsanto 1985b) or 182 ppm for 13 weeks (Monsanto 1987).

##### Metabolic Effects.

Hydrogen Sulfide. Severe metabolic acidosis developed in a worker exposed to hydrogen sulfide generated from a sodium sulfide waste solution dumped onto acid waste material (Stine et al. 1976). Blood lactate concentrations were significantly increased (65%) compared to controls during exercise in men exposed to 5 ppm hydrogen sulfide via oral inhalation for >16 minutes (Bhambhani and Singh 1991), but not at 2 ppm. Additional studies by the same group (Bhambhani et al. 1994, 1996b) exposed both men and women to 5 ppm hydrogen sulfide during 30 minutes of exercise and failed to observe significant increases in lactate concentrations, but did see a decrease in muscle citrate synthase in men, suggesting that aerobic metabolism was being compromised at this level of exposure.

In a subsequent study, Bhambhani et al. (1997) observed significant increases in blood lactate concentrations in male and female volunteers exposed to 10 ppm hydrogen sulfide; no significant changes in the activities of muscle lactate dehydrogenase, citrate synthase, or cytochrome oxidase were observed.

In Sprague-Dawley rat dams exposed to 20, 50, or 75 ppm of hydrogen sulfide for 7 hours/day from gestation day 1 through postnatal day 21, blood glucose levels were increased about 50% at all exposure concentrations (Hayden et al. 1990a).

Carbonyl Sulfide. No studies were located regarding metabolic effects in humans after inhalation exposure to carbonyl sulfide.

Significant increases in serum cholesterol levels were observed in rabbits continuously exposed to 54 ppm carbonyl sulfide for 7 weeks (Kamstrup and Hugod 1979). However, the alterations were only observed at weeks 1, 6, and 7 and corresponded to a downward fluctuation in control levels. An increase in free cholesterol levels in the media layer of the aorta (but not in the intima or internal aspect of the media layer) was also observed; the investigators suggested that this increase was probably due to the increase in serum cholesterol levels.

#### 3.2.1.3 Immunological and Lymphoreticular Effects

Hydrogen Sulfide. No studies were located regarding immunological and lymphoreticular effects in humans after inhalation exposure to hydrogen sulfide.

No treatment-related histopathological changes were found in the spleen or lymph nodes of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm of hydrogen sulfide 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). Pulmonary alveolar macrophage function was studied using lavage fluid from F-344 rats exposed for 4 hours to 50, 200, or 400 ppm hydrogen sulfide (Khan et al. 1991). Although the number of pulmonary alveolar macrophage cells was not influenced by hydrogen sulfide exposure, the number of viable cells was significantly decreased at 400 ppm. When the pulmonary alveolar macrophage cells were treated with Zymosan to stimulate respiration rates, it was found that there was no stimulation of respiration in cells from animals exposed to 200 or 400 ppm; these rates were significantly different from controls and were approximately equal to basal cell levels (Khan et al. 1991).

The highest NOAEL values and all reliable LOAEL values for immunological effects in rats and mice exposed to hydrogen sulfide in acute- and intermediate-duration studies are recorded in Table 3-1 and plotted in Figure 3-1.

Carbonyl Sulfide. No studies were located regarding immunological and lymphoreticular effects in humans or animals after inhalation exposure to carbonyl sulfide.

#### 3.2.1.4 Neurological Effects

Hydrogen Sulfide. Acute human exposure to hydrogen sulfide can result in nausea, headaches, delirium, disturbed equilibrium, poor memory, neurobehavioral changes, olfactory paralysis, loss of consciousness, tremors, and convulsions. Fatigue, poor memory, dizziness, and irritability have been observed in workers chronically exposed to hydrogen sulfide (Beauchamp et al. 1984); however, it is not known if these effects are the result of chronic exposure or due to recurring acute exposures.

Available information on the neurotoxic effects of acute exposures to high levels of hydrogen sulfide in humans comes primarily from case reports. In most instances, exposure concentrations were either unknown or estimated. In most cases, the exact exposure duration was not known, but estimated durations ranged from several minutes to an hour. The most commonly reported effect found in individuals exposed to high concentrations is rapid unconsciousness followed by apparent recovery (with prompt removal from exposure), colloquially referred to as knockdown (Deng and Chang 1987; Krekel 1964; McDonald and McIntosh 1951; Milby 1962; Spolyar 1951). Other described neurological effects in the case reports include disturbed equilibrium, nausea, headache, poor memory, insomnia, irritability, delirium, severe vertigo, unusual sweating, neuropsychological symptoms, convulsions, and tremors (Arnold et al. 1985; Krekel 1964). While deaths were often noted, there were cases in which individuals survived and had complete neurological recovery (Deng and Chang 1987; Krekel 1964; Osbern and Crapo 1981; Ravizza et al. 1982). In a study of the possible effects of exposure to low concentrations of hydrogen sulfide, 3/10 asthmatic volunteers complained of headache after being exposed in a sealed chamber to 2 ppm hydrogen sulfide for 30 minutes (Jappinen et al. 1990).

A few case reports have described permanent or persistent neurological effects in humans following acute inhalation exposure to high concentrations of hydrogen sulfide. One patient developed symptoms of frontal headaches, irritability, poor concentration ability and attention span, and deficits of cortical function tests (including verbal abstraction, attention, and short-term retention) 1 month after accidental exposure to unspecified concentrations of hydrogen sulfide (Stine et al. 1976). All effects except headaches resolved by 2 months after the accident. A 5–10-year follow-up re-examination of several individuals who became unconscious after exposure to unspecified concentrations of hydrogen sulfide revealed permanent neurological symptoms (Tvedt et al. 1991a, 1991b) including vision and memory impairment; rigid movements; slight tremor; ataxia; psychosis; abnormal learning, retention, and motor function; and slight cerebral atrophy. The probable exposure concentration in one of the patients may have exceeded 200 ppm (as measured 2.5 hours after exposure). Divergent reports of the risk of permanent neurological damage due to hydrogen sulfide may result from lack of follow-up after hospital discharge (Tvedt et al. 1991b). Permanent neurologic damage including effects on balance, vibration sense, and impaired verbal and visual recall were observed in one man exposed to a very high concentration (14,000 ppm) of hydrogen sulfide (Kilburn 1993). In another case report, a worker who suffered “knockdown” and presented in a coma, remained in a coma through standard treatment (i.e., sodium nitrite), underwent several treatments with hyperbaric oxygen, and became responsive to simple commands by day 5. However, at the time of discharge, an extensive head injury assessment found effects on speech, attention span, insight, and ability to communicate, as well as a marked impact on visual memory and the ability to acquire, retain, and recall new information. These effects had not resolved by 12 and 18 months after exposure (Snyder et al. 1995). In a somewhat similar scenario, Schneider et al. (1998) describe a case in which another worker lost consciousness when he descended into a 27-foot pit that was part of a sewer construction project. He was overcome by hydrogen sulfide fumes (concentration not specified), fell from a ladder from an unspecified height, and was subsequently removed in a coma and transported to a local trauma center. At the emergency room (and potentially at the site), the patient experienced seizure activity. A body computed tomography (CT) scan showed pulmonary edema; no abnormalities were noted in the head CT scan. The patient was transferred to a hyperbaric medicine unit and started on hyperbaric oxygen treatments (starting approximately 10 hours post-episode). Five days later, he recovered consciousness, and by 7 days, his status had improved enough to discontinue hyperbaric oxygen treatments. He was able to feed himself and move with assistance, but had impaired language, memory, attention, and appeared agitated and restless. Over the course of the next 4 years, the patient was evaluated on a variety of occasions. He continued to show a constellation of deficits (even 4 years later) including problems with general cognitive ability, motor function, and impaired performance on tests of cognitive function. Some of these symptoms appeared to be alleviated through a combined treatment with fairly high doses of Ritalin and Cyclert drugs that enhance dopaminergic functioning.

In a case control study of 16 subjects who had been exposed for minutes, hours, or years to hydrogen sulfide, Kilburn (1997) found evidence of permanent neurobehavior impairment in exposed individuals when compared to 353 controls matched for sex, age, and years of education. A large battery of tests was used to evaluate these individuals, including a detailed self-administered questionnaire, complete physical and clinical screening neurologic examinations, as well as a series of neurophysiologic and neuropsychologic tests. Among those who had chronic low-dose exposure, the most sensitive tests were those evaluating balance, simple reaction time, left visual field, and verbal recall. The group exposed to hydrogen sulfide for hours showed additional defects (including impacts on a variety of neuropsychological tests) although remote memory remained intact. The group that experienced momentary “knockdown” exposure had an even larger suite of deficit in cognitive function, leading the study author to conclude that “...brief high doses were devastating, whereas protracted low doses showed effects on the more sensitive tests.”

A 20-month-old child was exposed for nearly 1 year to >0.6 ppm hydrogen sulfide and other emitted chemicals from a coal mine (Gaitonde et al. 1987). Symptoms included ataxia, choreoathetosis, dystonia, and inability to stand. A CT scan of the brain showed bilateral areas of low density in the region of both basal ganglia and surrounding white matter. Neurophysiological investigations of electroencephalography, visual evoked responses, brain stem evoked responses, and peripheral nerve conduction studies were within normal limits. The child’s condition improved spontaneously, shortly after hospital admission. After 10 weeks, ataxia had resolved and the choreoathetoid movements were reduced. A repeat brain scan showed complete resolution of abnormalities. The relationship of these complaints to low-level hydrogen sulfide exposure is unclear.

The acute toxicity of low levels of hydrogen sulfide was examined by Fiedler et al. (2008). In healthy young adults, exposure to 0.5 or 5 ppm hydrogen sulfide for 2 hours did not result in decrements in visual acuity or visual contrast sensitivity, cognitive tests, or postural sway. A decrease in performance on an auditory verbal learning test was observed as the duration increased, particularly in subjects exposed to 0.05 or 0.5 ppm, relative to the 5 ppm group; however, there was no relationship between exposure concentration and performance. The subjects reported an increase in anxiety during exposure to 5 ppm, which was related to odor irritation.

Neurological effects resulting from chronic-duration exposure to hydrogen sulfide in the shale industry have been reported (Ahlborg 1951). Symptoms observed in workers exposed to daily concentrations of hydrogen sulfide that often exceeded 20 ppm included fatigue, loss of appetite, headache, irritability, poor memory, and dizziness. The frequency of fatigue increased with length of employment and the amount of hydrogen sulfide exposure.

A study of sewer workers (Farahat and Kishk 2010) also reported a significant increase in self-reported memory defects and lack of concentration; the mean hydrogen sulfide concentration inside of manhole openings was 9.4 ppm (range of 8.8–10.5 ppm). In function tests, significant alterations were observed in the test of auditory event-related potentials; simple reaction time; and figure, visual, verbal, and logical memory tests. However, no significant associations between performance on neurophysiological or neuropsychological tests and urinary thiosulfate levels (biomarker for hydrogen sulfide exposure) were found. The study did not specify when during the workshift the workers were tested; thus, it is not known whether the study evaluated acute or chronic neurotoxicity.

In the South Karelia air pollution study (discussed in more detail under respiratory effects) all of the reports found increases in the incidence of headaches or migraines in polluted communities when compared to nonpolluted communities (Jaakkola et al. 1990; Marttila et al. 1994b, 1995; Partti-Pellinen et al. 1996); however, only in the most recent study did this finding achieve statistical significance. Using a cross-sectional, self-administered questionnaire, this report (Partti-Pellinen et al. 1996) evaluated the increased risk of headache or migraine in adults in a slightly polluted and a reference community. In the polluted community, the mean annual TRS concentrations were 2–3 μg/m^3^, the 24-hour concentrations varied between 0 and 56 μg/m^3^, and the maximum 1-hour concentration was 155 μg/m^3^; there was no TRS detected in the reference community. In the polluted community, the sulfur dioxide annual mean concentration was 1 μg/m^3^, the 24-hour concentrations varied between 0 and 24 μg/m^3^ and the maximum 1-hour concentration was 152 μg/m^3^. In the reference community, the mean sulfur dioxide level was 1 μg/m^3^ and the maximum 1-hour concentration was 30 μg/m^3^. The residents of the polluted community showed a significantly increased risk of headache both during the previous 4-week period (OR=1.83; 95% CI=1.06–3.15) and the preceding 12 months (OR=1.70; 95% CI=1.01–2.64), when compared to the residents of the reference community (even after adjusting for differences in age, sex, smoking, history of allergic diseases, education, and marital status between the two communities).

In a retrospective epidemiologic study using hospital discharge data from 1981 to 1990, Bates et al. (1998) evaluated the risk of disease to known target organ systems of hydrogen sulfide toxicity in residents of Rotorua, a New Zealand city that uses geothermal energy for industrial and domestic heating purposes. Although no information on hydrogen sulfide levels was presented in this report, the authors’ previous work indicated that a monitoring exercise in Rotorua in 1978 found a 3-month median concentration of hydrogen sulfide of 20 μg/m^3^, with 35% of the measurements >70 μg/m^3^ and 10% >400 μg/m^3^; additionally, elevated concentrations of mercury had previously been found in the hair of residents (Bates et al. 1997). Significant increases in incidence were found for diseases of the nervous system and sense organs (SIR=1.11; p<0.001) among Rotorua residents as compared to the rest of New Zealand residents. When the data were stratified by sex and ethnicity, the increased risks remained significant for all but non-Māori men. As noted previously, the percentage of Rotorua residents of Māori ethnicity is significantly higher than the rest of New Zealand. When incidence rates were examined for minor disease groupings within nervous system diseases, significantly increased risks were seen for other disorders of the central nervous system (SIR=1.22; p<0.001) and disorders of the peripheral nervous system (SIR=1.35; p<0.001). At the level of individual diseases, statistically significant incidence ratios were found for infant cerebral palsy (SIR=1.42; p=0.02), migraine (SIR=1.40; p=0.002), other conditions of the brain (SIR=2.50; p<0.001), mononeuritis of the upper limbs and mononeuritis multiplex (SIR=1.47; p<0.001), and mononeuritis of the lower limbs (SIR=2.06; p<0.001). A follow-up study of this population found a significant exposure-related trend (p<0.001) for increasing incidence of diseases of the nervous system and sense organs (Bates et al. 2002). In this study, the hospital discharge records were used to obtain disease incidence data; additionally, the affected individuals were divided into three exposure groups (low, medium, and high) based on their current residence. Actual exposure levels were not monitored; a surrogate for exposure was used. When the nervous system disease incidence was further divided into subcategories, significant trends (p<0.001) were found for other disorders of the central nervous system, disorders of the eye and adnexa, and disorders of the ear and mastoid process. The SIRs (95% CI) were significantly elevated in all groups for disorders of the eye and adnexa (1.47 [1.33–1.63], 1.57 [1.30–1.89], and 2.27 [1.97–2.61] for the low, medium, and high exposure groups, respectively). In the high exposure group, the SIRs were also elevated for other disorders of the central nervous system (2.59 [1.91–3.44]), disorders of the peripheral nervous system (2.27 [1.97–2.61]), and disorders of the ear and mastoid process (2.00 [1.65–2.40]). The lack of exposure data, the assumption that hydrogen sulfide exposure only occurred at home, the assumption that current exposure also represented historical exposure, the potential exposure to other compounds, and the lack of control for confounding variables such as smoking and socioeconomic status limit the interpretation of these data. A follow-up study of 1,637 adult Rotorua residents found no significant associations between hydrogen sulfide exposure and the results of tests of attention, psychomotor speed, memory, fine motor function, or mood (Reed et al. 2014). The median and mean hydrogen sulfide concentrations (TWA of passive monitoring samples taken during summer and winter 2010 and winter 2011) were 20.3 and 20.8 ppb, respectively, for current residences and 26.4 and 27.0 ppb, respectively, at current workplaces.

ATSDR (Inserra et al. 2004) examined residents of Dakota City, Nebraska for neurobehavioral effects resulting from chronic exposure to ≥90 ppb hydrogen sulfide. Although the 90 ppb level was used as a cut off value, historical monitoring data records showed much higher levels (e.g., the outdoor hydrogen sulfide level exceeded 1,000 ppb 275 times in the 1995–1999 time period). Hydrogen sulfide exposure did not appear to adversely affect performance on most neurobehavioral tests; in fact, the hydrogen sulfide exposed groups scored better than the referent group on 21 of the 28 tests, although the differences were not statistically significant. The hydrogen sulfide group did score lower on a memory test (match to sample score) and a test of grip strength, but the differences were not statistically significant.

A significant association between mood/stress ratings and hydrogen sulfide levels were reported in residents living within 1.5 miles of at least one industrial hog operation in North Carolina (Horton et al. 2009). The average hydrogen sulfide concentrations ranged from <0.01 to 1.5 ppb and the highest measured levels ranged from 2 to 90 ppb. During a 2-week period, the subjects were asked to go outside for 10 minutes twice a day and return inside and complete a five-question survey on mood/stress using a 9-point rating scale. Although most of the time (>80%) the subjects rated annoyance or stress as 0 (not at all), significant associations between reporting stress or annoyance and feeling nervous or anxious with hydrogen sulfide atmospheric levels were found. The ORs for a 1-ppb change in hydrogen sulfide were 1.18 (95% CI=1.08–1.30) for stress or annoyance and 1.12 (95% CI=1.08–1.30) for feeling nervous or anxious. Significant associations between the response to these questions and semivolatile PM_10_ levels were also found. It is unclear whether the observed effects were symptoms of a neurological effect or a response to the hydrogen sulfide odor.

Additional ecological studies have reported neurological effects in communities near industrial sources of hydrogen sulfide, but do not provide reliable monitoring data. Alterations in tests of balance sway with eyes open or closed, color discrimination, visual field performance, cognition, and reaction time were observed in residents living near a hog manure lagoon, as compared to an out-of-state control group (Kilburn 2012). In residents living near an industrial source emitting chronic, low levels of hydrogen sulfide, a significant increase in central nervous system effects (OR=12.7; 95% CI=7.59–22.09) was observed, as compared to referent communities (Legator et al. 2001). A number of central nervous system effects were reported by at least 40% of the residents (including fatigue, depression, short-term memory loss, difficulty sleeping, numbness, lethargy, headaches, and changes in senses); the incidences of these symptoms in the referent population were ≤10%. Neurological symptoms (headache, dizziness, lightheadedness, loss of balance, extreme fatigue, somnolence, insomnia, irritability, lack of concentration, recent and long-term memory loss, and instability of mood) were reported in residents living near sour gas/oil fields in New Mexico (Kilburn et al. 2010). Impaired performance on neurophysiological and neuropsychological function tests (including reaction time, balance sway, grip strength, psychological function, verbal recall, attention/coordination, and long-term memory) were also observed. In addition to the potential for exposure to hydrogen sulfide, the residents were also likely exposed to benzene, toluene, ethylbenzene, and xylenes (BTEX); cyclohexane; n-hexane; and naphthalene.

Rabbits exposed to 72 ppm of hydrogen sulfide for 1.5 hours lost consciousness (Kosmider et al. 1967). Haider et al. (1980) observed behaviors in guinea pigs exposed daily to 20 ppm of hydrogen sulfide for 11 days that were indicative of fatigue, somnolence, and dizziness; no additional information of overt behaviors were provided. Neurochemical analyses revealed decreased cerebral hemisphere and brain stem total lipids and phospholipids. Rats exposed to 800 ppm of hydrogen sulfide for 20 minutes lost consciousness (Beck et al. 1979). Lethargy was observed in rats following exposure to 400 ppm of hydrogen sulfide for 4 hours (Lopez et al. 1988b).

A decreased response rate in a discriminated avoidance task was observed in male Wistar rats exposed to ≥200–300 ppm hydrogen sulfide (Higuchi and Fukamachi 1977). At concentrations of <400–500 ppm, the response rates and percent avoidances recovered rapidly postexposure; at 400–500 ppm, the response rates were almost to within normal limits 1 day postexposure. When the animals were tested for Sidman-type conditioned avoidance response at response-shock intervals of 10 or 30 seconds, an inverse relationship between hydrogen sulfide concentration and response rate was noted (Higuchi and Fukamachi 1977). As with the discriminated avoidance task, the effect dissipated when exposure stopped.

Excitement was observed in female NMRI mice exposed to 100 ppm of hydrogen sulfide for 2 hours at 4-day intervals (Savolainen et al. 1980). Exposure also resulted in decreased cerebral ribonucleic acid (RNA), decreased orotic acid incorporation into the RNA fraction, and inhibition of cytochrome oxidase. An increase in the glial enzyme marker 2’,3’-cyclic nucleotide-3’-phosphohydrolase was seen. Neurochemical effects have been reported in other studies. Decreased leucine uptake and acid proteinase activity in the brain were observed in mice exposed to 100 ppm hydrogen sulfide for 2 hours (Elovaara et al. 1978). Inhibition of brain cytochrome oxidase and a decrease in orotic acid uptake were observed in mice exposed to 100 ppm hydrogen sulfide for up to 4 days (Savolainen et al. 1980).

Significant decreases in motor activity (ambulations and total movements) were observed in rats receiving nose-only exposure to 80, 200, or 400 ppm hydrogen sulfide 3 hours/day for 5 days (Struve et al. 2001). However, a decrease in motor activity was not observed in rats receiving whole-body exposures to 80 ppm 3 hours/day for 5 days (Struve et al. 2001). The study authors did not discuss these conflicting results. In addition, significant impairment of learning and memory (as assessed in a water maze test) was observed in rats receiving nose-only exposure to 400 ppm. However, these results should be interpreted cautiously because the impaired learning and memory may have been secondary to the decrease in motor activity and decreased body temperature also observed in these animals.

A series of intermediate-duration studies conducted by Partlo et al. (2001) used the radial arm maze to assess the effect of hydrogen sulfide on learning and memory in rats exposed to 125 ppm hydrogen sulfide 4 hours/day, 5 days/week for 5–11 weeks. In the first study, the rats were trained on the radial arm maze prior to hydrogen sulfide exposure. The 5-week exposure to hydrogen sulfide did not adversely affect postexposure performance on the maze, suggesting that 5 weeks of exposure to hydrogen sulfide did not adversely affect memory. In the second study, the rats were exposed to hydrogen sulfide and trained on the maze daily for 11 weeks. The results of this study suggest that hydrogen sulfide did not interfere with acquisition of the maze task, but did adversely affect performance rate. In the third study, the rats from the second study were retrained on a modified radial arm maze without additional exposure to hydrogen sulfide. These results suggested that the hydrogen sulfide-exposed rats had difficulty relearning a complex task.

The intermediate-duration effects of hydrogen sulfide on neurological function were examined by the measurement of motor and sensory nerve conduction velocities of the tail nerve or morphology of the sciatic nerve (Gagnaire et al. 1986). Male Sprague-Dawley rats were exposed to 0 or 50 ppm hydrogen sulfide for 5 days/week for 25 weeks. The study authors did not report the duration of exposure to hydrogen sulfide per day. No neurotoxic effects were observed in the rats.

Neurologic function and neuropathology were evaluated in Sprague-Dawley rats exposed to 0, 10, 30, or 80.0 ppm hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983c). Neurological function evaluation included an assessment of posture; gait; tone of facial muscles; pupillary, palpebral, extensor thrust; and crossed-extensor thrust reflexes. Besides routine neuropathologic examinations, special studies included an examination of teased fibers from muscular and sural branches of the tibial nerve together with specimens from the cervical and lumbar spinal cord. Absolute brain weights were decreased (5%) in male rats exposed to 80 ppm hydrogen sulfide in this study; however, there were no treatment-related effects on neurological function or neuropathology. No signs of neurotoxicity were noted in a similar study in which F-344 rats were exposed to 0, 10, 30, or 80 ppm hydrogen sulfide for 90 days (CIIT 1983b). Likewise, no treatment-related neurological effects were observed in male and female B6C3F_1_ mice exposed to 0, 10.1, 30.5, or 80.0 ppm hydrogen sulfide for 90 days (CIIT 1983a).

The highest NOAEL values and all reliable LOAEL values for neurological effects in rats, guinea pigs, mice, and rabbits from acute- or intermediate-duration hydrogen sulfide studies are recorded in Table 3-1 and plotted in Figure 3-1.

The available human data, supported by animal studies, provide strong evidence that hydrogen sulfide exposure adversely affects the nervous system. The most commonly reported effect in humans is unconsciousness which can be followed by death or an apparent full recovery (Deng and Chang 1987; Krekel 1964; McDonald and McIntosh 1951; Milby 1962; Spolyar 1951); most studies did not provide exposure information. In individuals who appeared to recover completely from the exposure, subsequent studies have found permanent neurological effects in some of these subjects, including vision and memory impairment, reduced motor function, and abnormal learning function (Kilburn 1993, 1997; Schneider et al. 1998; Snyder et al. 1995; Tvedt et al. 1991a, 1991b). No reliable data on the exposure level resulting in unconsciousness were located. Subclinical neurological effects (detected as alterations in neurological tests) were reported in individuals chronically exposed to low (concentration not specified) levels of hydrogen sulfide (Farahat and Kishk 2010; Kilburn 1997); the effects included alterations in balance, reaction time, verbal recall, and memory. Additionally, workers and community members living in areas with hydrogen sulfide pollution reported fatigue, irritability, headaches, poor memory, and/or stress (Ahlborg 1951; Horton et al. 2009; Kilburn et al. 2010; Legator et al. 2001; Partti-Pellinen et al. 1996). As with other studies, limited monitoring data are available and the subjects were exposed to other substances including other sulfur compounds, benzene, toluene, and/or particulate matter. Studies in animals confirm the findings from the human studies. Unconsciousness was observed in rabbits exposed to 72 ppm for 1.5 hours (Kosmider et al. 1967) and rats exposed to 800 ppm for 20 minutes (Beck et al. 1979) and lethargy was observed in rats exposed to 400 ppm for 4 hours (Lopez et al. 1988b). Additionally, impaired learning was observed in rats exposed to 125 ppm 4 hours/day, 5 days/week for 11 weeks (Partlo et al. 2001). In other intermediate-duration studies, no effects on posture, gait, or reflexes were observed in rats and mice exposed to 80 ppm 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983c).

Carbonyl Sulfide. No studies were located regarding neurological effects in humans after inhalation exposure to carbonyl sulfide.

Acute- and intermediate-duration exposure studies clearly identify the nervous system as a sensitive target of carbonyl sulfide toxicity. Morgan et al. (2004) noted a number of effects in rats exposed to carbonyl sulfide 6 hours/day, 5 days/week for 12 exposures. Hypotonia and slight gait abnormalities were observed in rats exposed to 400 ppm and ataxia and hypothermia were observed at 500 ppm. Hypothermia was also observed after one or two exposures to 600 ppm. Immediately after a single 6-hour exposure to 600 ppm, lethargy was noted in rats; 1 day postexposure, the animals exhibited clinical signs of hypothermia, lethargy, head tilt, and ataxia (Morgan et al. 2004). Although the clinical signs lessened over a 14-day recovery period, ataxia with head tilt was noted in several animals at the end of the recovery period. Another study also reported ataxia in rats exposed to 453 ppm 6 hours/day, 5 days/week for at least 6 days (Monsanto 1985b). No overt signs of neurotoxicity were observed in rats exposed to 300 ppm 6 hours/day, 5 days/week for 4 or 12 exposures (Morgan et al. 2004) or 253 ppm 6 hours/day, 5 days/week for 11 exposures (Monsanto 1985b). Exposure to 400 ppm (6 hours/day, 5 days/week) for 10 or 12 exposures also resulted in decreases in motor activity (Herr et al. 2007) and forelimb and hindlimb grip strength (Herr et al. 2007; Morgan et al. 2004); no alterations in motor function were observed at 300 ppm (Herr et al. 2007; Morgan et al. 2004). Functional observational battery testing in rats exposed to 400 ppm for 12 weeks showed mild gait changes in about 25% of the rats, which was more prevalent after 6 weeks of exposure than after 12 weeks of exposure (Morgan et al. 2004). Morgan et al. (2004) suggested that there was some compensation for the motor impairment since the effects were more pronounced after 2 weeks of exposure than after 12 weeks of exposure.

Histopathological alterations were observed in rats following a single 6-hour exposure to 600 ppm carbonyl sulfide (Morgan et al. 2004). Two weeks after the exposure, necrosis and microgliosis was observed in the cerebellar nucleus, internal capsule, and thalamus; no histological alterations were observed in the brains of rats similarly exposed to 75–300 ppm. In rats sacrificed in moribund condition after 2 days of exposure to 600 ppm (6 hours/day), bilateral symmetrical necrosis in the parietal cortex area 1 and thalamus and necrosis in the retrosplenial granular cortex, pyriform cortex, red nucleus, cerebellar roof nucleus, posterior collicular nucleus, and anterior olivary nucleus were observed (Morgan et al. 2004; Sills et al. 2004). No morphological lesions were observed in the brains of rats exposed to 500 ppm 6 hours/day for 1 or 2 days (Morrison et al. 2009). After 3 or 4 days of exposure, bilateral symmetrical necrosis was observed in the posterior colliculi. Necrosis was also observed in the frontoparietal cortex, putamen, retrosplenial cortex, thalamus, and anterior olivary nucleus in rats exposed to 500 ppm for 4 days (6 hours/day). After 5 days of exposure, neuronal degeneration was observed in the posterior colliculi; it was also observed in the medial geniculate nucleus, parietal cortex, and caudate/putamen after 10 days of exposure (6 hours/day) (Morrison et al. 2009). Neuronal loss and microgliosis were observed in the posterior thalamic nuclear group, zona inserta of the hypothalamus, and posterior colliculus in rats exposed to 600 ppm 6 hours/day for 2 days (Sills et al. 2004). Exposure to 400 ppm 6 hours/day, 5 days/week for 12 exposures resulted in bilateral symmetrical necrosis in the parietal cortex area 1 and putamen (Morgan et al. 2004). Exposure to 500 ppm also resulted in bilateral symmetrical necrosis in the retrosplenial cortex, thalamus, posterior colliculus, and anterior olivary nucleus and there was cavitation (loss of brain substance) within the parietal cortex and retrosplenial cortex, as compared to rats exposed to 500 ppm for 5 days. No significant increases in the incidence of histological alterations were observed in rats exposed to 300 ppm for 12 exposures (Morgan et al. 2004).

Similar findings were observed in rats exposed to 400 ppm carbonyl sulfide 6 hours/day, 5 days/week for 12 weeks (Morgan et al. 2004; Sills et al. 2004). Significant increases in the incidence of unilateral or bilateral symmetrical cortical necrosis and cavitation in the parietal cortex area 1 and bilateral neuronal loss with microgliosis of the posterior colliculus were observed. No histological alterations were observed in rats exposed to 300 ppm. The results of the acute and intermediate duration studies suggest that the histological damage occurs shortly after exposure initiation and does not worsen with continued exposure.

Neurophysiological alterations that correlated with the histopathological damage were also observed in rats exposed to 400 ppm carbonyl sulfide 6 hours/day, 5 days/week. After 12 weeks of exposure, significant increases in the peak-to-peak amplitudes in somatosensory evoked potentials from the S1 facial region cortex were observed. Significant alterations in peak amplitudes in brainstem auditory-evoked responses were observed after 2 (Herr et al. 2007; Morgan et al. 2004) or 12 weeks of exposure (Herr et al. 2007); no alterations were observed in rats exposed to 300 ppm for 12 weeks (Herr et al. 2007). The investigators noted that the observed alterations of brainstem auditory-evoked responses peak generation indicated alterations in the region of the olivary complex-lateral lemniscus region of the brainstem, but with normal function of the auditory nerve and cochlear nucleus region. Additionally, the decreased peak amplitudes and lack of change in the peak latencies is suggestive of loss of neurons rather than changes in conduction along the brainstem neural pathway. Studies by Morgan et al. (2004) and Sills et al. (2004) have demonstrated neuronal loss and microglial infiltration in the posterior colliculi and anterior olivary nuclei in rats exposed to 400 ppm for 4–12 weeks.

Reflex modification of audiometry or visual evoked potentials after 2 weeks of exposure (6 hours/day, 5 da ys/week, testing conducted 11 days postexposure) and peripheral nerve action potential or nerve conduction velocity after 2 weeks of exposure (tested 27 days postexposure) or 12 weeks of exposure (6 hours/day, 5 days/week; tested 34–40 days postexposure) were not significantly altered in rats exposed to 400 ppm (Herr et al. 2007). Additionally, there were no alterations in nerve conduction velocity after 2 or 12 weeks of exposure (Herr et al. 2007).

The highest NOAEL values and all reliable LOAEL values for neurological effects following exposure to carbonyl sulfide are recorded in Table 3-2 and plotted in Figure 3-2.

#### 3.2.1.5 Reproductive Effects

Hydrogen Sulfide. There are limited data on the reproductive toxicity of hydrogen sulfide in humans. Hemminki and Niemi (1982) examined the spontaneous abortion rate in relationship to maternal and paternal occupation and residential environmental pollution in an industrial community in Finland. Women who were employed in rayon textile and paper products jobs had an increased rate of spontaneous abortions (p<0.10), as did women whose husbands worked in rayon textile or chemical processing jobs. This study also examined the possible relationship between exposure to sulfur dioxide, hydrogen sulfide, and carbon disulfide and the occurrence of spontaneous abortions. A non-statistically significant increase in the incidence of spontaneous abortion was observed in women living in areas with hydrogen sulfide concentrations exceeding 2.85 ppm. Interpretation of these results is limited by the lack of control of other potential confounding variables, particularly occupational exposure to other chemicals. A retrospective study of spontaneous abortions in a large population of women working in the petrochemical industry in China, Xu et al. (1998) reported a significantly increased risk of spontaneous abortion with frequent exposure to petrochemicals (OR of 2.7; 95% CI=1.8–3.9). When the risk associated with exposure to specific chemicals was examined, exposure to hydrogen sulfide was found to have an OR of 2.3 (95% CI=1.2–4.4).

No treatment-related histopathological changes were found in male or female reproductive organs of F-344 or Sprague-Dawley rats or B6C3F_1_ mice exposed to TWA concentrations of 10, 30, or 80 ppm hydrogen sulfide for 6 hours/day, 5 days/week for 90 days (CIIT 1983a, 1983b, 1983c). No significant alterations in gestation length, viability, or litter size were observed in Sprague-Dawley rats exposed to 0, 20, 50, or 75 ppm hydrogen sulfide for 7 hours/day on gestation days 6–21 (Hayden et al. 1990b). An apparent increase in parturition time was observed in the hydrogen sulfide-exposed dams (the mean lengths of parturition were 105.0, 148.8, and 117.5 minutes, compared to 85.2, 124, and 82.5 minutes in the three control groups); these data were not statistically analyzed. The study authors noted that increased parturition time was observed in 6 out of 18 exposed animals and in 1 of 17 controls. Dorman et al. (2000) did not find any significant alterations in gestation length in Sprague-Dawley rats exposed to 10, 30, or 80 ppm hydrogen sulfide for 6 hours/day, 7 days/week for 2 weeks prior to mating with exposed males, during the 2 week mating period, and on gestational days 0–19. This study also found no significant alterations in fertility (as assessed by mating index, fertility index, postimplantation loss, late resorptions, or still births), number of females with live pups, litter size, or number of implants per female. No histological alterations in the reproductive organs and accessory sex organs of rats in the controls and 80 ppm exposure group were found; a slight, nonstatistically significant increase in the incidence of testicular degeneration was observed at 80 ppm. Additionally, no significant alterations in sperm count or morphology were observed.

Table 3-2 Levels of Significant Exposure to Carbonyl Sulfide - Inhalation

Key to^a^ Figure | Species (Strain) | Exposure/Duration/Frequency (Route) | System | NOAEL (ppm) | LOAEL | | | Comments
Key to^a^ Figure | Species (Strain) | Exposure/Duration/Frequency (Route) | System | NOAEL (ppm) | Less Serious (ppm) | Serious (ppm) | Reference Chemical Form | Comments
ACUTE EXPOSURE
Death
1 | Rat; (CD) | 4 hr | | | | 1111 M (LC50) | DuPont 1981
2 | Rat; (Sprague-Dawley) | 4 hr | | | | 1082 (LC50) | Monsanto 1985a
Systemic
3 | Rat; (Sprague-Dawley) | 6 hr/d; 5 d/wk; 11 exposures | Hemato | 453 | | | Monsanto 1985b
| | | Bd Wt | 453
Neurological
4 | Rat; (Fischer- 344) | 6 hr/d; 5 d/wk; 10 exposures | | 300 M | 400 M (decreased motor activity, grip strength, slightly abnormal gait) | | Herr et al. 2007
5 | Rat; (Sprague-Dawley) | 6 hr/d; 5 d/wk; 11 exposures | | 253 | | 453 (ataxia, tremors, convulsions) | Monsanto 1985b
6 | Rat; (Fischer- 344) | 6 hr/d; 4 d | | 300 M | | 600 M (hypothermia, ataxia, and necrosis in parietal cortex, thalamus, posterior colliculi) | Morgan et al. 2004
7 | Rat; (Fischer- 344) | 6 hr/d; 5 d/wk; 12 exposures | | 300 | 400 (decreased grip strength, hypotonia, slight gait abnormalities, necrosis in parietal cortex and putamen) | 500 (hypothermia, lethargy, ataxia, necrosis of in parietal cortex, putamen, thalamus, and loss of brain substance in parietal cortex and retrosplenial cortex) | Morgan et al. 2004
8 | Rat; (Fischer- 344) | 6 hr/d; 5 d | | | | 500 M (neuronal degeneration in posterior colliculi) | Morrison et al. 2009
9 | Rat; (Fischer- 344) | 6 hr/d; 10 d | | | 500 M (neuronal degeneration in posterior colliculi, medial geniculate nucleus, parietal cortex, and caudate/putamen) | | Morrison et al. 2009
10 | Rat; (Fischer- 344) | 6 hr/d; 1–2 d | | 500 M | | | Morrison et al. 2009
11 | Rat; (Fischer- 344) | 6 hr/d; 3 d | | | 500 M (bilateral symmetrical necrosis in posterior colliculi) | | Morrison et al. 2009
12 | Rat; (Fischer- 344) | 6 hr/d; 4 d | | | 500 M (necrosis in posterior colliculi, frontoparietal cortex, putamen, retrosplenial cortex, thalamus, and anterior olivary nucleus) | | Morrison et al. 2009
13 | Rat; (Fischer- 344) | 6 hr/d; 2 d | | | 600 (Neuronal loss and microgliosis in posterior thalamic nuclear group, zona inserta of the hypothalamus, and posterior colliculus) | | Sills et al. 2004
INTERMEDIATE EXPOSURE
Death
14 | Rabbit; (White Danish Country) | continuous; 7 weeks | | | | 54 M (3/8 died within first 5 days) | Hugod and Astrup 1980; Hugod 1981
15 | Rabbit; (White Danish country) | continuous; 7 weeks | | | | 54 F (3/18 died within 5 days) | Kamstrup and Hugod 1979
Systemic
16 | Rabbit; (White Danish Country) | continuous; 7 weeks | Cardio | 54 M | | | Hugod and Astrup 1980; Hugod 1981
17 | Rabbit; (White Danish country) | continuous; 7 weeks | Resp | 54 F | | | Kamstrup and Hugod 1979
| | | Cardio | 54 F
Neurological
18 | Rat; (Fischer- 344) | 6 hr/d; 5 d/wk; 12 wk | | 300 | 400 (altered somatosensory evoked potentials in the facial region cortex of the brain and brainstem auditory evoked response peaks) | | Herr et al. 2007
19 | Rat; (Fischer- 344) | 6 hr/d; 5 d/wk; 12 wk | | 300 | 400 (necrosis or cavitation in parietal cortex and neuronal loss or microgliosis in posterior colliculus) | | Morgan et al. 2004
20 | Rat; (Fischer- 344) | 6 hr/d; 5 d/wk; 12 wk | | 300 | | 400 (microgliosis in the posterior colliculus, gliosis in the anterior olivary nucleus, bilateral symmetrical malacia in parietal cortex) | Sills et al. 2004
Reproductive
21 | Rat; (Sprague-Dawley) | 6 hr/d; 5 d/wk for 10 wk then 7 d/wk for 3 wk | | 60 M | 182 M (decreased pregnancy rate) | | Monsanto 1987

a The number corresponds to entries in Figure 3-2.

Bd Wt = body weight; Cardio = cardiovascular; d = day(s); F = Female; Hemato = hematological; hr = hour(s); LC50 = lethal concentration, 50% kill; LOAEL = lowest-observed-adverse-effect level; M = male; NOAEL = no-observed-adverse-effect level; ppm = parts per million; Resp = respiratory; wk = week(s)

Figure 3-2 Levels of Significant Exposure to Carbonyl Sulfide - Inhalation

Acute (≤14 days)

Intermediate (15-364 days)

The highest NOAEL values for reproductive effects following exposure to hydrogen sulfide in rats and mice from intermediate-duration studies are recorded in Table 3-1 and plotted in Figure 3-1.

Carbonyl Sulfide. No studies were located regarding reproductive effects in humans after inhalation exposure to carbonyl sulfide.

One study examined the reproductive toxicity of carbonyl sulfide in male rats (Monsanto 1987). A decrease in pregnancy rate was observed in unexposed female rats mated with male rats exposed to 182 ppm carbonyl sulfide 6 hours/day, 5 days/week for 10 weeks and 6 hours/day, 7 days/week for a 3-week mating period. When the males were allowed to recover for 10 weeks prior to mating to unexposed females, no alterations in fertility were observed (Monsanto 1987). This study identified a NOAEL of 60 ppm. The NOAEL and the LOAEL values from this study are recorded in Table 3-2 and plotted in Figure 3-2.

#### 3.2.1.6 Developmental Effects

Hydrogen Sulfide. No studies were located regarding developmental effects in humans after inhalation exposure to hydrogen sulfide.

No changes in serum protein, LDH, SGOT, or alkaline phosphatase activity were noted in the offspring of Sprague-Dawley rats exposed to 20, 50, or 75 ppm hydrogen sulfide for 7 hours/day from gestation day 1 through postnatal day 21 (Hayden et al. 1990a). No effects on blood glucose were noted in the offspring, although glucose levels were increased by about 50% in dams at all exposure concentrations on postnatal day 21 (Hayden et al. 1990a). In a second study, these authors (Hayden et al. 1990b) found a dose-related increase in parturition time in animals exposed to 20, 50, or 75 ppm hydrogen sulfide for 7 hours/day from gestation day 6 until postpartum day 21. The study also showed developmental delays in pinnae attachment and hair growth, but these effects were not dose related.

No fetal effects were noted in a dose range-finding developmental study in which pregnant Sprague-Dawley rats were exposed to 150 ppm hydrogen sulfide on gestation days 6–20, despite body weight loss in the dams (Saillenfait et al. 1989).

No significant alterations in the incidence of structural anomalies were found in the offspring of Sprague-Dawley rats exposed to 10, 30, or 80 ppm hydrogen sulfide 6 hours/day, 7 days/week on gestational days 0–19 (Dorman et al. 2000). Continued exposure on postnatal days 5–18 did not result in developmental delays (pinnae detachment, surface righting, incisor eruption, negative geotaxis, and eyelid detachment), performance on developmental neurobehavioral tests (motor activity, passive avoidance, acoustic startle, or functional observation battery), or brain histopathology.

An examination of Purkinje cells from Sprague-Dawley rat pups exposed to 20 or 50 ppm hydrogen sulfide for 7 hours/day from gestation day 5 through postpartum day 21 showed severe alterations in the architecture and growth characteristic of the Purkinje cell dendritic fields compared to controls (Hannah and Roth 1991). The study did not mention whether any maternal effects were observed; however, the authors did indicate that “these findings suggest that developing neurons exposed to low concentrations of hydrogen sulfide are at risk of severe deficits.” Two studies by Hannah et al. (1989, 1990) examined the effects of prenatal exposure to hydrogen sulfide on amino acid levels in the brain. In the first study, pregnant Sprague-Dawley rats were exposed to 75 ppm hydrogen sulfide for 7 hours/day, from postcoitus day 5 to postpartum day 21 (Hannah et al. 1989). Aspartate, glutamate, and GABA in the cerebrum and cerebellum were significantly reduced (about 20%) compared to controls by postpartum day 21. Taurine levels of the offspring were initially 25% higher than controls but had returned to control range by postpartum day 21; taurine levels were not measured in dams. In the 1990 study, pregnant Sprague-Dawley rats were exposed to 50 ppm hydrogen sulfide for 7 hours/day, from postcoital day 6 to postpartum day 21 (Hannah et al. 1990). In this study, maternal taurine levels were determined on parturition and on postpartum day 21. Taurine in maternal plasma was 30% higher than controls; taurine levels were not determined in offspring, so relating these levels to high taurine levels found in offspring in the 1989 study is speculative.

Further investigation into the developmental neurological effects of hydrogen sulfide was undertaken by Skrajny et al. (1992). Pregnant Sprague-Dawley rats were exposed to 20 or 75 ppm hydrogen sulfide 7 hours/day from gestation day 5 to postpartum day 21; separate control groups were used for each exposure level. Significant increases in serotonin levels were observed in the frontal cortex and cerebellum on postpartum days 14 and 21 in the 75 ppm group and in the cerebellum on postpartum day 21 in the 20 ppm group. Significant decreases in norepinephrine levels were observed in frontal cortex and cerebellum on postpartum day 14 in the 20 ppm group and in the frontal cortex on postpartum day 21 in the 20 ppm group. In contrast, significant increases in norepinephrine levels were observed in the cerebellum on postpartum day 7 in the 20 and 75 ppm groups, in the cerebellum on postpartum day 14 in the 75 ppm group, and in the frontal cortex and cerebellum on postpartum day 21 in the 75 ppm group (Skrajny et al. 1992). In a subsequent study, the same exposure regimen (i.e., between day 5 postcoital until day 21 postnatal) was used to follow the monoamine levels in various regions of the brain up to 60 days postnatal (Roth et al. 1995). This study found that the alterations of monoamine levels observed at day 21 postnatal (the last day of exposure) gradually returned to control values by day 45.

The highest NOAEL and all reliable LOAEL values for developmental effects in each species and duration category are recorded in Table 3-1 and plotted in Figure 3-1.

Carbonyl Sulfide. No studies were located regarding developmental effects in humans or animals after inhalation exposure to carbonyl sulfide.

#### 3.2.1.7 Cancer

Hydrogen Sulfide. There was no increase in cancer incidence noted in a residential cohort study of individuals living downwind from natural gas refineries in Alberta, Canada, from 1970 to 1984 (Schechter et al. 1989). In a retrospective epidemiologic study using cancer registry data from 1981 to 1990, Bates et al. (1998) evaluated the risk of cancer to known target organ systems of hydrogen sulfide toxicity in residents of Rotorua, a New Zealand city that uses geothermal energy for industrial and domestic heating purposes. No information on hydrogen sulfide levels was presented in this report, but the authors indicate concerns that exposures to hydrogen sulfide and/or mercury from geothermal sources could have health impacts. In their previous work, it was indicated that the most reliable monitoring information for hydrogen sulfide in the area came from a monitoring exercise in 1978 that found a median concentration of hydrogen sulfide of 20 μg/m^3^, with 35% of the measurements over 70 μg/m^3^ and 10% over 400 μg/m^3^ (Bates et al. 1997). Based on the cancer registry information, a significantly increased risk of nasal cancers (SIR=3.17; p=0.01) was found among Rotorua residents as compared to the rest of the population of New Zealand. However, since this is a rare cancer, this finding is based on only four cancers. Because the population of Rotorua has a higher percentage of Māoris than the rest of New Zealand, the investigators also examined their data stratified by ethnicity and sex and found a significantly increased risk of cancers of the trachea, bronchus, and lung (SIR=1.48; p=0.02) among female Māoris in Rotorua as compared to female Māoris in the rest of New Zealand. Differences in smoking history between these two populations were not sufficient to explain the observed differences in risk. The authors concluded that the lack of adequate exposure information did not permit findings of causal relationships between hydrogen sulfide and cancer incidence. The potential co-exposure to mercury also confounds the interpretation of these results.

No studies were located regarding cancer effects in animals after inhalation exposure to hydrogen sulfide.

Carbonyl Sulfide. No studies were located regarding cancer effects in humans or animals after inhalation exposure to carbonyl sulfide.

### 3.2.2 Oral Exposure

No studies were located regarding health effects in humans or animals after oral exposure to carbonyl sulfide.

#### 3.2.2.1 Death

No studies were located regarding death in humans or animals after oral exposure to hydrogen sulfide.

#### 3.2.2.2 Systemic Effects

No studies were located regarding respiratory, cardiovascular, hematological, musculoskeletal, hepatic, renal, endocrine, dermal, ocular, or metabolic effects after oral exposure to hydrogen sulfide.

Gastrointestinal Effects. No studies were located regarding gastrointestinal effects in humans after oral exposure to hydrogen sulfide.

Diarrheic digestive disorder was observed in adult pigs fed hydrogen sulfide at a dose level of 15 mg/kg/day for a few days (Wetterau et al. 1964). The study authors reported that in a repeat study using younger pigs that weighed less, no diarrheic disorder was noted.

Body Weight Effects. No studies were located regarding body weight effects in humans after oral exposure to hydrogen sulfide.

Decreased body weight gain (48.2 kg total weight gain in treated animals versus 62.5 kg total weight gain in controls) was observed in pigs fed hydrogen sulfide at a dose level of 6.7 mg/kg/day for 105 days (Wetterau et al. 1964).

No studies were located regarding the following health effects in humans or animals after oral exposure to hydrogen sulfide:

3.2.2.3 Immunological and Lymphoreticular Effects
3.2.2.4 Neurological Effects
3.2.2.5 Reproductive Effects
3.2.2.6 Developmental Effects
3.2.2.7 Cancer

### 3.2.3 Dermal Exposure

No studies were located regarding health effects in humans or animals after dermal exposure to carbonyl sulfide.

#### 3.2.3.1 Death

No studies were located regarding death in humans after dermal exposure to hydrogen sulfide.

A study by Laug and Draize (1942) reported death in two out of three rabbits exposed to unknown concentrations of hydrogen sulfide through either clipped, intact, or abraded skin. One rabbit with intact skin exposed to hydrogen sulfide for 2 hours survived, while another died in this interval. The rabbit exposed to hydrogen sulfide through abraded skin also died (Laug and Draize 1942). When two guinea pigs were exposed to unknown concentrations of hydrogen sulfide gas for 60 minutes on a small area of their shaved abdomen, neither died (Walton and Witherspoon 1925). However, both guinea pigs that had their entire shaved torso (about 50% body area) exposed to an unknown concentration of hydrogen sulfide died after about 45 minutes (Walton and Witherspoon 1925). No clinical signs of toxicity were seen in a dog with shaved abdomen exposed full body (except the head) to unknown concentrations of hydrogen sulfide in a chamber for 1 hour (Walton and Witherspoon 1925).

#### 3.2.3.2 Systemic Effects

No studies were located regarding respiratory, cardiovascular, gastrointestinal, hematological, musculoskeletal, hepatic, renal, endocrine, dermal, ocular, or body weight effects in humans or animals after dermal exposure to hydrogen sulfide. However, several sources indicate that care must be taken with liquefied hydrogen sulfide in order to avoid frostbite (ATSDR 2001a; NIOSH 2011).

#### 3.2.3.3 Immunological and Lymphoreticular Effects

No studies were located regarding immunological and lymphoreticular effects in humans or animals after dermal exposure to hydrogen sulfide.

#### 3.2.3.4 Neurological Effects

No studies were located regarding neurological effects in humans after dermal exposure to hydrogen sulfide.

No clinical signs of neurotoxicity were seen in two guinea pigs exposed to an unknown concentration of hydrogen sulfide gas for 60 minutes on a small area of their shaved abdomen (Walton and Witherspoon 1925). A dog exposed to an unknown concentration of hydrogen sulfide for 1 hour showed no clinical signs of neurotoxicity (Walton and Witherspoon 1925).

No studies were located regarding the following health effects in humans or animals after dermal exposure to hydrogen sulfide:

3.2.3.5 Reproductive Effects
3.2.3.6 Developmental Effects
3.2.3.7 Cancer

## 3.3 GENOTOXICITY

Hydrogen Sulfide. No studies were located regarding the genotoxicity of hydrogen sulfide in humans.

No mutagenicity was observed with hydrogen sulfide gas in Ames assays using Salmonella typhimurium TA97, TA98, and TA100 strains, either with or without S9 liver fractions, of male Syrian golden hamsters or Sprague-Dawley rats that had been induced with 500 mg/kg Aroclor 1254 (EPA 1984). However, it should be noted that the concentration of hydrogen sulfide gas was limited by its solubility in ethanol, which was the test solvent (EPA 1984). The highest dose that could be obtained was 1,750 μg/plate.

Carbonyl Sulfide. No studies were located regarding the genotoxicity of carbonyl sulfide.

## 3.4 TOXICOKINETICS

Although hydrogen sulfide is primarily absorbed through the lungs, it can also be absorbed through the gastrointestinal tract and intact skin (Laug and Draize 1942; Wetterau et al. 1964). It is metabolized through three pathways: oxidation, methylation, and reactions with metalloproteins or disulfide-containing proteins (Beauchamp et al. 1984). Although the major metabolic pathway for detoxification of hydrogen sulfide is oxidation in the liver, the methylation pathway also serves as a detoxification route (EPA 1987; Weisiger and Jakoby 1979). The major oxidation product of hydrogen sulfide is thiosulfate, which may further converted to sulfate and subsequently be excreted in urine (Bartholomew et al. 1980). Hydrogen sulfide is widely distributed in the body. Sulfides have been found in the liver, blood, brain, lungs, spleen, and kidneys of humans who died after accidental inhalation exposure. Hydrogen sulfide is excreted primarily as sulfate (free sulfate or thiosulfate) in the urine. It is also excreted unchanged in exhaled air and in feces and flatus.

Limited data on the toxicokinetics of carbonyl sulfide were located. Carbonyl sulfide is absorbed via the respiratory tract based on the finding of histological damage in the brains of rats exposed to carbonyl sulfide gas (Morgan et al. 2004). In vitro studies suggest that carbonyl sulfide is metabolized to hydrogen sulfide and thiosulfate (Chengelis and Neal 1979) and in vivo evidence suggests that it is metabolized by carbonic anhydrase (Chengelis and Neal 1980) and the mixed function oxidase enzyme system to carbon dioxide (Chengelis and Neal 1979). No additional toxicokinetic data were identified.

### 3.4.1 Absorption

#### 3.4.1.1 Inhalation Exposure

Hydrogen Sulfide. Hydrogen sulfide is absorbed rapidly through the lungs (Adelson and Sunshine 1966; Allyn 1931; Breysse 1961; Deng and Chang 1987; Hagley and South 1983; Kimura et al. 1994; NIOSH 1989; Osbern and Crapo 1981; Parra et al. 1991). Inhalation absorption of lethal concentrations of hydrogen sulfide is rapid in humans, and effects can occur within seconds to minutes. Inhalation is the most common route of hydrogen sulfide exposure. Hydrogen sulfide dissociates at physiological pH to the hydrogen sulfide anion, which is probably the absorbed form (WHO 1987). No quantitative data are available regarding the absorption of hydrogen sulfide in humans.

Animal data demonstrate that absorption of hydrogen sulfide via the lungs occurs readily and rapidly, but are not sufficient to quantitatively determine the proportion of an inhaled dose that is absorbed (Beck et al. 1979; Kage et al. 1992; Khan et al. 1990; Lopez et al. 1989; Nagata et al. 1990; Prior et al. 1988, 1990; Smith and Gosselin 1964; Tansy et al. 1981). No physiologically based pharmacokinetic (PBPK) models have been developed to provide estimates of hydrogen sulfide absorption.

Carbonyl Sulfide. No data on the absorption of carbonyl sulfide were identified; however, the findings of brain lesions in rats exposed to carbonyl sulfide gas provide evidence that it is absorbed via the respiratory tract.

#### 3.4.1.2 Oral Exposure

Hydrogen Sulfide. Hydrogen sulfide exists as a gas; therefore, oral exposure to hydrogen sulfide will not typically occur. No studies were located regarding absorption in humans after oral exposure to hydrogen sulfide. Some case reports showing accidental oral ingestion of liquid manure or other substances that might contain hydrogen sulfide exist, but in all of these cases, the ingestion was secondary to being "knocked down" by inhalation of hydrogen sulfide (Freireich 1946; Imamura et al. 1996; Kimura et al. 1994; Osbern and Crapo 1981).

One animal study suggests that hydrogen sulfide can be absorbed through the gastrointestinal tract. A study where pigs were fed diets containing dried greens with levels of hydrogen sulfide of 1.5, 3.1, or 6.7 mg/kg/day for 105 days indicated that hydrogen sulfide is absorbed following ingestion (Wetterau et al. 1964).

Carbonyl Sulfide. As with hydrogen sulfide, carbonyl sulfide is a gas and oral exposure will not typically occur.

#### 3.4.1.3 Dermal Exposure

Hydrogen Sulfide. No studies were located regarding absorption in humans after dermal hydrogen sulfide exposure.

Animal data have shown that dermal hydrogen sulfide absorption can occur, although large surface areas of skin must be exposed. In one study, the trunk fur of rabbits was clipped for exposure to unknown concentrations of hydrogen sulfide gas for 1.5–2 hours. Evidence for the absorption of hydrogen sulfide included both the death of the animals and a positive sulfide reaction of expired air with lead acetate paper (Laug and Draize 1942). No evidence of dermal absorption was found in two guinea pigs exposed to unknown concentrations of hydrogen sulfide gas for 1 hour on a small area of their shaved abdomens (Walton and Witherspoon 1925). Dermal absorption was indicated, however, when the entire torso of guinea pigs was exposed to hydrogen sulfide gas and the animals died after about 45 minutes (Walton and Witherspoon 1925). No clinical signs of toxicity were reported in a dog that received full-body exposure (except the head) to unknown concentrations of hydrogen sulfide (Walton and Witherspoon 1925).

Carbonyl Sulfide. No information was located on the dermal absorption of carbonyl sulfide.

### 3.4.2 Distribution

No information was located on the distribution of carbonyl sulfide by any route of exposure.

#### 3.4.2.1 Inhalation Exposure

Hydrogen Sulfide. Few human data are available regarding tissue distribution after inhalation exposure to hydrogen sulfide. One case study reported sulfide (as bis[pentafluorobenzyl]sulfide) distribution in three of four men who drowned after being “overcome” (presumably, by hydrogen sulfide) and falling unconscious into a lake in Japan (Kimura et al. 1994). Concentrations of hydrogen sulfide gas were estimated to be 550–650 ppm, based upon extrapolation of tissue concentrations from rat studies (Kimura et al. 1994; Nagata et al. 1990). Initial blood sulfide concentrations determined 2–3 hours postmortem in these individuals were 0.1, 0.2, and 0.08 μg/g tissue. At 24 hours after death, the blood sulfide levels were 0.5 μg/g, 0.23 μg/g, and undetected, respectively. At 24 hours after death, sulfide concentrations in the brains of these individuals were 0.2, 0.4, and 1.06 μg/g; and lung concentrations were 0.68, 0.21, and 0.23 μg/g. Based on a study in rats by this same group of researchers (Nagata et al. 1990) that showed little or no increase in sulfide concentrations in rat lung and brain 24 hours after death (as well as a lack of sulfide in these tissues in control rats). Kimura and colleagues postulated that the sulfide levels observed in the brain and lungs in the human study may be indicators of tissue levels at the time of death (Kimura et al. 1994). Sulfide was detected, postmortem, in the liver (1.30–1.56 μg/g), spleen (0.32–0.64 μg/g), and kidney (0.47–1.50 μg/g) (Kimura et al. 1994). In another study of a man who was “overcome” by hydrogen sulfide in a tank, hydrogen sulfide levels of 0.92, 1.06, 0.34, and 0.38 μg/g were measured postmortem in the blood, brain, kidney, and liver, respectively (Winek et al. 1968). Hydrogen sulfide concentrations in the tank after the accident were 1,900–6,100 ppm (Winek et al. 1968).

Data from animal studies suggest that the distribution of inhaled hydrogen sulfide is rapid and widespread, while storage of hydrogen sulfide in the body is limited by rapid metabolism and excretion. Adult male rats exposed to 550 or 650 ppm hydrogen sulfide until death had tissue samples taken at 0, 4, 24, and 48 hours after death (Nagata et al. 1990). Sulfide concentrations were measured 1, 7, and 30 days later. Immediately after death, sulfide concentrations in whole blood were 0.48 μg/g in exposed animals and were nondetectable in control animals. Sulfide concentrations rapidly increased with time after death in both control and treated animals. Significant increases in sulfide concentrations were found in the lung (0.60 μg/g), brain (0.31 g/g), thigh muscle (0.21 μg/g), and abdominal muscles (0.22 μg/g), as compared to sulfide concentrations in tissues of controls (tissues collected immediately after death) (Nagata et al. 1990). Liver and kidney samples had similar sulfide concentrations in both exposed and control groups when taken immediately after death. Certain tissues (blood, liver, and kidneys) exhibited an increase in sulfide concentration with time after death (whether hydrogen sulfide exposure occurred or not) while other tissues (lung, brain, and muscle) had little or no change in sulfide concentration (Nagata et al. 1990).

Distribution of hydrogen sulfide in male Wistar rats was examined by Kohno et al. (1991). Animals exposed to 75 ppm hydrogen sulfide for 20, 40, or 60 minutes showed essentially the same tissue distribution of hydrogen sulfide irrespective of duration: 10 μg/mL in blood, 25 μg/g in brain, 20 μg/g in lung, 37 μg/g in heart, 20 μg/g in liver, 25 μg/g in spleen, and 30 μg/g in kidney. The levels in the brain, lung, heart, liver, spleen, and kidney were significantly (p>0.01) higher than blood levels after 20 minutes of exposure.

Japanese white rabbits exposed to 500–1,000 ppm of hydrogen sulfide (the lethal concentration) for 60 minutes had thiosulfate concentrations of 0.08 μmol/mL in blood, 0.095 μmol/g in lung, and 0.023 μmol/g in brain (Kage et al. 1992). Little or no thiosulfate was found in the liver, kidney, or muscle. When rabbits were exposed to 100–200 ppm of hydrogen sulfide for 60 minutes, blood thiosulfate levels decreased from 0.061 μmol/mL immediately postexposure to a trace level at 2 hours postexposure (Kage et al. 1992).

#### 3.4.2.2 Oral Exposure

No studies were located regarding tissue distribution in humans or animals after oral exposure to hydrogen sulfide.

#### 3.4.2.3 Dermal Exposure

No studies were located regarding tissue distribution in humans or animals after dermal exposure to hydrogen sulfide.

### 3.4.3 Metabolism

Hydrogen Sulfide. Hydrogen sulfide metabolism occurs through three pathways: oxidation, methylation, and reaction with metallo- or disulfide-containing proteins (Beauchamp et al. 1984; EPA 1987). Hydrogen sulfide is primarily detoxified by oxidation reactions to sulfate (Tabacova 1986). Hydrogen sulfide can also be detoxified by methylation (EPA 1987; Weisiger and Jakoby 1979). The proposed detoxification pathways most currently accepted for the metabolism of hydrogen sulfide are shown in Figure 3-3 and include oxidation, methylation, as well as the toxic pathways resulting from interactions with metalloproteins and disulfide-containing proteins.

The major metabolic pathway for hydrogen sulfide in the body is the oxidation of sulfide to sulfate, which is excreted in the urine (Beauchamp et al. 1984). The major oxidation product of sulfide is thiosulfate, which can be further converted to sulfate; the primary location for these reactions is in the liver (Bartholomew et al. 1980).

Urinary thiosulfate levels were measured in volunteers exposed to 8, 18, or 30 ppm of hydrogen sulfide for 30–45 minutes and compared to levels in unexposed individuals at a pelt processing plant (Kangas and Savolainen 1987). Very little urinary thiosulfate was excreted in controls (2.9 μmol/mmol creatinine).

Figure 3-3 Metabolic Pathways of Hydrogen Sulfide

Source: Beauchamp et al. 1984

The highest urinary thiosulfate levels among exposed individuals occurred 15 hours after exposure and decreased to control levels by 17 hours postexposure (Kangas and Savolainen 1987). Most absorbed hydrogen sulfide was already oxidized by 15 hours postexposure (Kangas and Savolainen 1987). This study was limited by the lack of summary data on exposed individuals and inadequate data regarding the numbers of subjects. Using perfused rat liver, Bartholomew et al. (1980) found that there was a rapid oxidation of ^35^S-sulfide to sulfate. Furthermore, there was a decrease in thiosulfate released from the liver when nonlabelled thiosulfate was added to the perfusion system, suggesting that thiosulfate acts as an intermediate in the oxidation to sulfate (Bartholomew et al. 1980).

Elevated levels of thiosulfate were observed in the blood, lung, and brain of Japanese white rabbits exposed to 500–1,000 ppm hydrogen sulfide (lethal concentration) for 14–30 minutes (Kage et al. 1992). Exposure to 100–200 ppm for 60 minutes resulted in thiosulfate levels in the urine that peaked (1.2 μM/mL) 1–2 hours after exposure and could still be detected in urine 24 hours after exposure (Kage et al. 1992). In the blood, the thiosulfate levels peaked (0.061 μM/mL) immediately after exposure and were undetectable after 4 hours. Sulfide was not detected in blood or urine of rabbits exposed to 100–200 ppm hydrogen sulfide.

Evidence for the methylation of hydrogen sulfide comes primarily from in vitro studies of Sprague-Dawley rats’ intestinal mucosa (Weisiger et al. 1980). Thiol S-methyltransferase catalyzed the methylation of hydrogen sulfide to methanethiol (CH_3_SH). Methanethiol can act as a substrate for another methylation also catalyzed by thiol S-methyltransferase, yielding dimethylsulfide (CH_3_SCH_3_). The activity of thiol S-methyltransferase was widely distributed, with the greatest activity in cecal and colonic mucosa, liver, lung, and kidney tissues. Thiol S-methyltransferase activity was also found in other parts of the intestine and stomach, spleen, heart, and skeletal muscle. No enzyme activity was found in the feces. Although it has been postulated that methylation is a method of detoxification of hydrogen sulfide (a constituent of human flatus produced in the intestine) the extent to which the toxicity of exogenous hydrogen sulfide is attenuated by methylation is not known.

The interaction of hydrogen sulfide with metalloproteins was postulated because the mechanism of toxicity for hydrogen sulfide is the inhibition of cytochrome oxidase and thus, inhibition of the electron transport system. It appears that hydrogen sulfide interacts with other metalloproteins and may represent a detoxification pathway in some instances (Beauchamp et al. 1984). Reduction of disulfide bridges by hydrogen sulfide was suggested by Smith and Abbanat (1966), who found that mice were protected from lethal concentrations of hydrogen sulfide by the administration of oxidized glutathione. This protection was not afforded by the administration of reduced glutathione. The study authors believed that the disulfide linkage of the oxidized glutathione interacted with the hydrosulfide, which prevented the reaction of sulfide with other sites (Smith and Abbanat 1966). This is attributed to the polarizability of the disulfide bond. The nucleophilic sulfhydryl group of hydrogen sulfide reacts with the δ^+^ of the disulfide bond, thus converting it to a less toxic product.

No studies were located regarding metabolism in humans or animals after oral, dermal, or other routes of exposure to hydrogen sulfide.

Carbonyl Sulfide. There are limited data on the metabolism of carbonyl sulfide. In vitro studies demonstrated that carbonyl sulfide was primarily metabolized by carbonic anhydrase to form hydrogen sulfide and thiosulfate (Chengelis and Neal 1979). Pre-exposure to acetazolamide (a carbonic anhydrase inhibitor) resulted in a decrease in mortality in rats exposed via intraperitoneal injection to a lethal dose of carbonyl sulfide (Chengelis and Neal 1980). There is also in vitro evidence that carbonyl sulfide is metabolized by the mixed-function oxidase enzyme system to carbon dioxide (Chengelis and Neal 1979; Dalvi et al. 1975). However, the metabolism was not inhibited by the cytochrome P-450 monooxygenase inhibitors (SKF 525-A, 4-methylpyrazole, metyrapone) or substrate (carbon disulfide) (Chengelis and Neal 1979).

### 3.4.4 Elimination and Excretion

No information was located on the elimination and excretion of carbonyl sulfide.

#### 3.4.4.1 Inhalation Exposure

Hydrogen Sulfide. The major metabolic pathway for hydrogen sulfide in the body is oxidation of sulfide to sulfate, with the sulfate being excreted in the urine (Beauchamp et al. 1984). Thiosulfate excretion was measured in volunteers exposed to 8, 18, or 30 ppm of hydrogen sulfide for 30–45 minutes and compared to measurements in unexposed individuals at a pelt processing plant (Kangas and Savolainen 1987). The study did not report the summary results of all exposed individuals; however, data from one individual exposed to 18 ppm hydrogen sulfide for 30 minutes found urinary thiosulfate concentrations of approximately 2, 4, 7, 30, and 5 μM/mM creatinine at 1, 2, 5, 15, and 17 hours postexposure, respectively. The highest urinary thiosulfate levels among exposed individuals occurred 15 hours after exposure and dropped to control levels by 17 hours postexposure.

Kage et al. (1992) evaluated sulfide and thiosulfate levels in the blood and urine of Japanese white rabbits exposed to 100–200 ppm for 60 minutes and concluded that thiosulfate was a better marker for exposure since it could be detected immediately in the blood, but also was detectable in the urine 24 hours after exposure. In the blood, thiosulfate levels decreased from 0.061 μM/mL immediately following exposure to an undetectable amount after 4 hours (Kage et al. 1992). In urine samples from these same animals, thiosulfate levels were highest (1.2 μM/mL) 1–2 hours after exposure, but were still detectable after 24 hours of exposure at a slightly higher level than that of controls (Kage et al. 1992).

#### 3.4.4.2 Oral Exposure

No studies were located regarding excretion in humans or animals after oral exposure to hydrogen sulfide.

#### 3.4.4.3 Dermal Exposure

Hydrogen Sulfide. No studies were located regarding excretion in humans after dermal exposure to hydrogen sulfide.

Excretion of hydrogen sulfide was documented after dermal exposure in rabbits. The trunk fur of rabbits was clipped and left intact or abraded for exposure to hydrogen sulfide gas (unknown concentrations) for 1.5–2 hours (Laug and Draize 1942). Evidence for the excretion of hydrogen sulfide by the rabbits was a sulfide reaction of the expired air with lead acetate paper (Laug and Draize 1942). Sulfides in the expired air were noted in one rabbit with intact skin after 7 minutes of exposure. This study was limited by the lack of measurement of exposure concentrations and the small number of animals used.

### 3.4.5 Physiologically Based Pharmacokinetic (PBPK)/Pharmacodynamic (PD) Models

Physiologically based pharmacokinetic (PBPK) models use mathematical descriptions of the uptake and disposition of chemical substances to quantitatively describe the relationships among critical biological processes (Krishnan et al. 1994). PBPK models are also called biologically based tissue dosimetry models. PBPK models are increasingly used in risk assessments, primarily to predict the concentration of potentially toxic moieties of a chemical that will be delivered to any given target tissue following various combinations of route, dose level, and test species (Clewell and Andersen 1985). Physiologically based pharmacodynamic (PBPD) models use mathematical descriptions of the dose-response function to quantitatively describe the relationship between target tissue dose and toxic end points.

PBPK/PD models refine our understanding of complex quantitative dose behaviors by helping to delineate and characterize the relationships between: (1) the external/exposure concentration and target tissue dose of the toxic moiety, and (2) the target tissue dose and observed responses (Andersen and Krishnan 1994; Andersen et al. 1987). These models are biologically and mechanistically based and can be used to extrapolate the pharmacokinetic behavior of chemical substances from high to low dose, from route to route, between species, and between subpopulations within a species. The biological basis of PBPK models results in more meaningful extrapolations than those generated with the more conventional use of uncertainty factors.

The PBPK model for a chemical substance is developed in four interconnected steps: (1) model representation, (2) model parameterization, (3) model simulation, and (4) model validation (Krishnan and Andersen 1994). In the early 1990s, validated PBPK models were developed for a number of toxicologically important chemical substances, both volatile and nonvolatile (Krishnan and Andersen 1994; Leung 1993). PBPK models for a particular substance require estimates of the chemical substance-specific physicochemical parameters, and species-specific physiological and biological parameters. The numerical estimates of these model parameters are incorporated within a set of differential and algebraic equations that describe the pharmacokinetic processes. Solving these differential and algebraic equations provides the predictions of tissue dose. Computers then provide process simulations based on these solutions.

The structure and mathematical expressions used in PBPK models significantly simplify the true complexities of biological systems. However, if the uptake and disposition of the chemical substance(s) are adequately described, this simplification is desirable because data are often unavailable for many biological processes. A simplified scheme reduces the magnitude of cumulative uncertainty. The adequacy of the model is, therefore, of great importance, and model validation is essential to the use of PBPK models in risk assessment.

PBPK models improve the pharmacokinetic extrapolations used in risk assessments that identify the maximal (i.e., the safe) levels for human exposure to chemical substances (Andersen and Krishnan 1994). PBPK models provide a scientifically sound means to predict the target tissue dose of chemicals in humans who are exposed to environmental levels (for example, levels that might occur at hazardous waste sites) based on the results of studies where doses were higher or were administered in different species. Figure 3-4 shows a conceptualized representation of a PBPK model.

Figure 3-4 Conceptual Representation of a Physiologically Based Pharmacokinetic (PBPK) Model for a Hypothetical Chemical Substance

Note: This is a conceptual representation of a physiologically based pharmacokinetic (PBPK) model for a hypothetical chemical substance. The chemical substance is shown to be absorbed via the skin, by inhalation, or by ingestion, metabolized in the liver, and excreted in the urine or by exhalation.

Source: Krishnan et al. 1994

If PBPK models for hydrogen sulfide and carbonyl sulfide exist, the overall results and individual models are discussed in this section in terms of their use in risk assessment, tissue dosimetry, and dose, route, and species extrapolations.

No PBPK models have been developed for hydrogen sulfide or carbonyl sulfide.

## 3.5 MECHANISMS OF ACTION

### 3.5.1 Pharmacokinetic Mechanisms

Hydrogen Sulfide. Hydrogen sulfide is primarily absorbed through the lungs. It can also be absorbed through the gastrointestinal tract and the skin. Hydrogen sulfide is widely distributed in the body after inhalation exposure. Based on analyses of tissues from humans who died after accidental exposure, sulfides have been detected in the liver, blood, brain, lungs, spleen, and kidneys. Hydrogen sulfide is metabolized by oxidation, methylation, and reaction with metalloproteins or disulfide-containing proteins. The major metabolic pathway for detoxification of hydrogen sulfide is oxidation of the sulfide to sulfate in the liver. Hydrogen sulfide is excreted primarily as sulfate in the urine.

Carbonyl Sulfide. No information was located on the pharmacokinetic mechanisms of carbonyl sulfide.

### 3.5.2 Mechanisms of Toxicity

Hydrogen Sulfide. Exposure to hydrogen sulfide at concentrations of 500 ppm and greater causes an initial increase in the rate of respiration as a result of the stimulation of the carotid bodies (chemosensors associated with ventilatory control) (Ammann 1986). Under normal conditions, these chemosensors stimulate ventilation of the lung during extreme cases in which a significant decrease in the partial pressure of oxygen in the arterial blood traveling to the head occurs (Ammann 1986). This action results in an increase in the number of impulses originating from the chemosensors to the respiratory center in the brain. The rate and depth of ventilation increases to the point of hyperpnea (rapid, deep breathing).

Direct inhibition of cellular enzymes has been postulated as one of many underlying mechanisms of toxicity of hydrogen sulfide (Beauchamp et al. 1984; Deng 1992). In particular, cytochrome oxidase, an enzyme involved in cellular oxidative processes and energy production, has been implicated. Inhibition of cytochrome oxidase is believed to disrupt the electron transport chain and to significantly impair oxidative metabolism leading to anaerobic metabolism, severely decreased ATP production with curtailed cellular energy generation, and the generation of lactic acid. Nervous and cardiac tissues (which have the highest oxygen demand) are especially sensitive to the disruption of oxidative metabolism (Ammann 1986). In the central nervous system, this effect may result in death from respiratory arrest.

Inhibition of cytochrome oxidase by hydrogen sulfide is similar to that of cyanide (Smith and Gosselin 1979). Although the suggestion has been frequently made that the effects of hydrogen sulfide on nervous tissue are (as with cyanide) simply due to inhibition of oxidative metabolism, recent authors suggest that this is not the case. Reiffenstein et al. (1992) examined this issue and concluded that while exposure to hydrogen sulfide and anoxic conditions arrive at the same end point, there are pharmacological dissimilarities. Baldelli et al. (1993) investigated the mechanism of toxicity associated with hydrogen sulfide exposure (achieved by intravenous injection of sodium sulfide) and concluded that it resulted not from a direct toxicity on central nervous system neurons (i.e., a ‘cerebral necrosis’ due to poisoning of mitochondria respiration), but rather, from an indirect effect associated with a profound hypotension most likely due to cardiotoxicity. These authors emphasized the importance of immediate cardiopulmonary resuscitation as a way to prevent the delayed neurotoxicity associated with hydrogen sulfide “knockdown” exposures.

An electrophysiological study of the effects of hydrogen sulfide on membrane and synaptic properties of dorsal raphe serotonergic cells in an in vitro rat brain-stem slice preparation has elucidated a possible mechanism of neurotoxicity of hydrogen sulfide (Kombian et al. 1993). These neurons are considered to play an important role in central nervous system control of respiratory rhythm. Hydrogen sulfide has been shown to produce two reversible, concentration-dependent effects on the resting membrane properties of the dorsal raphe neurons. Some neurons (14%) responded to hydrogen sulfide with an outward current accompanied by an increase in conductance, while 39% of the neurons responded with a rapid-onset depolarization corresponding to a weakly voltage-dependent inward current showing little or no change in conductance. In addition, 30% of the neurons displayed both types of responses. Finally, 18% of the neurons were unresponsive to hydrogen sulfide. The outward current induced by hydrogen sulfide was demonstrated to be caused by an elevated conductance to potassium; whereas the hydrogen sulfide-induced inward current was carried by calcium ions. However, the mechanism of calcium ion entry is not clear.

Hydrogen sulfide was shown to inhibit, in a concentration-dependent fashion, all components of the complex evoked synaptic responses of the dorsal raphe serotonergic neurons (Kombian et al. 1993). This effect was rapid, reversible, and involved both pre- and postsynaptic mechanisms. Similar effects of hydrogen sulfide on brain hippocampal CA1 neurons have been reported. The electrophysiological effects of hydrogen sulfide are comparable to those elicited by anoxia. The neuronal action of hydrogen sulfide may involve an interaction with free thiols and disulfide bonds present in most membrane proteins. Collectively, the electrophysiology data suggest a possible role of the effects of hydrogen sulfide on synaptic and membrane properties of the dorsal raphe serotonergic neurons of the brain stem in the cessation of respiratory drive following acute hydrogen sulfide exposure.

Inhibition of monoamine oxidase has been proposed as a possible mechanism underlying the hydrogen sulfide–mediated disruption of neurotransmission in brain stem nuclei controlling respiration (Warenycia et al. 1989). Administration of sodium hydrosulfide (an alkali salt of hydrogen sulfide) has been shown to increase brain catecholamine and serotonin levels in rats. It has also been suggested that persulfide formation resulting from sulfide interaction with tissue cystine and cystinyl peptides may underlie some aspects of hydrogen sulfide neurotoxicity, including inhibition of monoamine oxidase (Warenycia et al. 1990).

Carbonyl Sulfide. No information was located on the mechanisms of carbonyl sulfide toxicity.

### 3.5.3 Animal-to-Human Extrapolations

Hydrogen Sulfide. The toxicokinetic disposition of hydrogen sulfide in humans is not understood. However, available toxicity and toxicokinetic data indicate that hydrogen sulfide can be readily absorbed through the lung and (to a lesser and clinically insignificant extent) through the gastrointestinal tract and skin. Although the metabolism of hydrogen sulfide has been characterized in animals, there are limited data to suggest that the metabolism of hydrogen sulfide may be in part similar in humans. For instance, human data indicate that hydrogen sulfide is oxidized to sulfate and thiosulfate and excreted in the urine. Neurotoxicity induced by hydrogen sulfide has been observed in experimental animals and humans.

Schroeter and associates have used a toxicokinetic-driven computational fluid dynamics model to quantitatively predict hydrogen sulfide tissue doses in rats and humans (Schroeter et al. 2006a, 2006b). The computational fluid dynamics model is based on anatomically accurate representations of the geometry of the rat and human nasal cavities and rat nasal flux (uptake of hydrogen sulfide by the nasal tissue). Using the model, Schroeter et al. (2006a) predicted hydrogen sulfide dosimetry in the human nasal passage and derived regression equations that predicted the maximum and 99^th^ percentile flux values in the human olfactory region at hydrogen sulfide concentrations ranging from 1 to 50 ppm.

Carbonyl Sulfide. No human data for carbonyl sulfide were identified. There are limited data to compare the toxicity of carbonyl sulfide in different animal species since most of the toxicity studies examined rats. In rabbits, 17% mortality was observed following continuous exposure to 54 ppm for 5 days (Hugod 1981; Hugod and Astrup 1980; Kamstrup and Hugod 1979). The lowest lethal concentration in rats was 600 ppm; at this concentration, rats exposed 6 hours/day for 2 days were sacrificed in moribund condition (Morgan et al. 2004). No deaths were observed in rats exposed to 500 ppm 6 hours/day, 5 days/week for 12 exposures (Morgan et al. 2004). The highest nonlethal concentration and the lethal concentration in rats adjusted for intermittent exposure (6 hours/24 hours) are 125 and 150 ppm, respectively. Although the lethal concentration in rabbits is lower than the highest nonlethal concentration in rats, the two studies are not directly comparable due to the differences in exposure duration. In the absence of information to the contrary, it is assumed that the rat is a suitable model for human toxicity to carbonyl sulfide.

## 3.6 TOXICITIES MEDIATED THROUGH THE NEUROENDOCRINE AXIS

Recently, attention has focused on the potential hazardous effects of certain chemicals on the endocrine system because of the ability of these chemicals to mimic or block endogenous hormones. Chemicals with this type of activity are most commonly referred to as endocrine disruptors. However, appropriate terminology to describe such effects remains controversial. The terminology endocrine disruptors, initially used by Thomas and Colborn (1992), was also used in 1996 when Congress mandated the EPA to develop a screening program for “...certain substances [which] may have an effect produced by a naturally occurring estrogen, or other such endocrine effect[s]...”. To meet this mandate, EPA convened a panel called the Endocrine Disruptors Screening and Testing Advisory Committee (EDSTAC), and in 1998, the EDSTAC completed its deliberations and made recommendations to EPA concerning endocrine disruptors. In 1999, the National Academy of Sciences released a report that referred to these same types of chemicals as hormonally active agents. The terminology endocrine modulators has also been used to convey the fact that effects caused by such chemicals may not necessarily be adverse. Many scientists agree that chemicals with the ability to disrupt or modulate the endocrine system are a potential threat to the health of humans, aquatic animals, and wildlife. However, others think that endocrine-active chemicals do not pose a significant health risk, particularly in view of the fact that hormone mimics exist in the natural environment. Examples of natural hormone mimics are the isoflavinoid phytoestrogens (Adlercreutz 1995; Livingston 1978; Mayr et al. 1992). These chemicals are derived from plants and are similar in structure and action to endogenous estrogen. Although the public health significance and descriptive terminology of substances capable of affecting the endocrine system remains controversial, scientists agree that these chemicals may affect the synthesis, secretion, transport, binding, action, or elimination of natural hormones in the body responsible for maintaining homeostasis, reproduction, development, and/or behavior (EPA 1997). Stated differently, such compounds may cause toxicities that are mediated through the neuroendocrine axis. As a result, these chemicals may play a role in altering, for example, metabolic, sexual, immune, and neurobehavioral function. Such chemicals are also thought to be involved in inducing breast, testicular, and prostate cancers, as well as endometriosis (Berger 1994; Giwercman et al. 1993; Hoel et al. 1992).

No studies were identified on the potential for hydrogen sulfide or carbonyl sulfide to disrupt the function of the neuro-endocrine axis.

## 3.7 CHILDREN’S SUSCEPTIBILITY

This section discusses potential health effects from exposures during the period from conception to maturity at 18 years of age in humans, when all biological systems will have fully developed. Potential effects on offspring resulting from exposures of parental germ cells are considered, as well as any indirect effects on the fetus and neonate resulting from maternal exposure during gestation and lactation. Relevant animal and in vitro models are also discussed.

Children are not small adults. They differ from adults in their exposures and may differ in their susceptibility to hazardous chemicals. Children’s unique physiology and behavior can influence the extent of their exposure. Exposures of children are discussed in Section 6.6, Exposures of Children.

Children sometimes differ from adults in their susceptibility to hazardous chemicals, but whether there is a difference depends on the chemical (Guzelian et al. 1992; NRC 1993). Children may be more or less susceptible than adults to health effects, and the relationship may change with developmental age (Guzelian et al. 1992; NRC 1993). Vulnerability often depends on developmental stage. There are critical periods of structural and functional development during both prenatal and postnatal life, and a particular structure or function will be most sensitive to disruption during its critical period(s). Damage may not be evident until a later stage of development. There are often differences in pharmacokinetics and metabolism between children and adults. For example, absorption may be different in neonates because of the immaturity of their gastrointestinal tract and their larger skin surface area in proportion to body weight (Morselli et al. 1980; NRC 1993); the gastrointestinal absorption of lead is greatest in infants and young children (Ziegler et al. 1978). Distribution of xenobiotics may be different; for example, infants have a larger proportion of their bodies as extracellular water, and their brains and livers are proportionately larger (Altman and Dittmer 1974; Fomon 1966; Fomon et al. 1982; Owen and Brozek 1966; Widdowson and Dickerson 1964). The fetus/infant has an immature (developing) blood-brain barrier that past literature has often described as being leaky and poorly intact (Costa et al. 2004). However, current evidence suggests that the blood-brain barrier is anatomically and physically intact at this stage of development, and the restrictive intracellular junctions that exist at the blood-CNS interface are fully formed, intact, and functionally effective (Saunders et al. 2008, 2012).

However, during development of the blood-brain barrier, there are differences between fetuses/infants and adults which are toxicologically important. These differences mainly involve variations in physiological transport systems that form during development (Ek et al. 2012). These transport mechanisms (influx and efflux) play an important role in the movement of amino acids and other vital substances across the blood-brain barrier in the developing brain; these transport mechanisms are far more active in the developing brain than in the adult. Because many drugs or potential toxins may be transported into the brain using these same transport mechanisms—the developing brain may be rendered more vulnerable than the adult. Thus, concern regarding possible involvement of the blood-brain barrier with enhanced susceptibility of the developing brain to toxins is valid. It is important to note however, that this potential selective vulnerability of the developing brain is associated with essential normal physiological mechanisms; and not because of an absence or deficiency of anatomical/physical barrier mechanisms.

The presence of these unique transport systems in the developing brain of the fetus/infant is intriguing; as it raises a very important toxicological question as to whether these mechanisms provide protection for the developing brain or do they render it more vulnerable to toxic injury. Each case of chemical exposure should be assessed on a case-by-case basis. Research continues into the function and structure of the blood-brain barrier in early life (Kearns et al. 2003; Saunders et al. 2012; Scheuplein et al. 2002).

Many xenobiotic metabolizing enzymes have distinctive developmental patterns. At various stages of growth and development, levels of particular enzymes may be higher or lower than those of adults, and sometimes unique enzymes may exist at particular developmental stages (Komori et al. 1990; Leeder and Kearns 1997; NRC 1993; Vieira et al. 1996). Whether differences in xenobiotic metabolism make the child more or less susceptible also depends on whether the relevant enzymes are involved in activation of the parent compound to its toxic form or in detoxification. There may also be differences in excretion, particularly in newborns who all have a low glomerular filtration rate and have not developed efficient tubular secretion and resorption capacities (Altman and Dittmer 1974; NRC 1993; West et al. 1948). Children and adults may differ in their capacity to repair damage from chemical insults. Children also have a longer remaining lifetime in which to express damage from chemicals; this potential is particularly relevant to cancer.

Certain characteristics of the developing human may increase exposure or susceptibility, whereas others may decrease susceptibility to the same chemical. For example, although infants breathe more air per kilogram of body weight than adults breathe, this difference might be somewhat counterbalanced by their alveoli being less developed, which results in a disproportionately smaller surface area for alveolar absorption (NRC 1993).

Hydrogen Sulfide. Although there is a fair amount of data on the toxicity of hydrogen sulfide in humans, there is very little information to judge the impacts of exposure to hydrogen sulfide in infants and children. In adults, exposure to high concentrations of hydrogen sulfide can result in unconsciousness followed by an apparent complete recovery in some individuals. At lower exposure levels, exposure to hydrogen sulfide can result in less severe neurological (e.g., incoordination, poor memory, olfactory impairment) and respiratory symptoms. Animal data suggest that the respiratory tract, particularly the nasal olfactory epithelium, may be the most sensitive target following hydrogen sulfide exposure. It is likely that similar toxicological effects might be seen in children.

Using computational fluid dynamics modeling, Schroeter et al. (2010) evaluated whether differences in nasal anatomy and ventilation between adults and children would affect hydrogen sulfide dosimetry in the olfactory region of the nasal cavity (see Section 3.5.3 for more information on the computational fluid dynamics model). Using data for five adults and two children, the study found that the interindividual differences in hydrogen sulfide uptake was <1.2. However, since the two children were 7 and 8 years of age, the study did not address potential differences in a wide range of childhood ages.

Available human data suggest that maternal or paternal exposure may increase the risk of spontaneous abortions (Hemminki and Niemi 1982; Xu et al. 1998). However, co-exposure to other chemicals precludes establishing a causal relationship from these data. Animal studies did not find structural anomalies, developmental delays, alterations in performance on developmental neurobehavioral tests, or alterations in brain histology in the offspring of animals exposed to 80 ppm or lower hydrogen sulfide during gestation (Dorman et al. 2000; Hayden et al. 1990a; Saillenfait et al. 1989). In contrast, alterations in Purkinje cells (Hannah et al. 1990), brain amino acid levels (Hannah et al. 1989), and neurotransmitter levels (Skrajny et al. 1992) have been observed in rat offspring exposed to low levels (20–75 ppm) of hydrogen sulfide during gestation. However, the toxicological significance of these alterations in the absence of alterations in neurobehavioral performance is not known.

Carbonyl Sulfide. No information was located to evaluate children’s susceptibility to carbonyl sulfide.

## 3.8 BIOMARKERS OF EXPOSURE AND EFFECT

Biomarkers are broadly defined as indicators signaling events in biologic systems or samples. They have been classified as markers of exposure, markers of effect, and markers of susceptibility (NAS/NRC 1989).

A biomarker of exposure is a xenobiotic substance or its metabolite(s) or the product of an interaction between a xenobiotic agent and some target molecule(s) or cell(s) that is measured within a compartment of an organism (NAS/NRC 1989). The preferred biomarkers of exposure are generally the substance itself, substance-specific metabolites in readily obtainable body fluid(s), or excreta. However, several factors can confound the use and interpretation of biomarkers of exposure. The body burden of a substance may be the result of exposures from more than one source. The substance being measured may be a metabolite of another xenobiotic substance (e.g., high urinary levels of phenol can result from exposure to several different aromatic compounds). Depending on the properties of the substance (e.g., biologic half-life) and environmental conditions (e.g., duration and route of exposure), the substance and all of its metabolites may have left the body by the time samples can be taken. It may be difficult to identify individuals exposed to hazardous substances that are commonly found in body tissues and fluids (e.g., essential mineral nutrients such as copper, zinc, and selenium). Biomarkers of exposure to hydrogen sulfide and carbonyl sulfide are discussed in Section 3.8.1.

Biomarkers of effect are defined as any measurable biochemical, physiologic, or other alteration within an organism that, depending on magnitude, can be recognized as an established or potential health impairment or disease (NAS/NRC 1989). This definition encompasses biochemical or cellular signals of tissue dysfunction (e.g., increased liver enzyme activity or pathologic changes in female genital epithelial cells), as well as physiologic signs of dysfunction such as increased blood pressure or decreased lung capacity. Note that these markers are not often substance specific. They also may not be directly adverse, but can indicate potential health impairment (e.g., deoxyribonucleic acid [DNA] adducts). Biomarkers of effect caused by hydrogen sulfide and carbonyl sulfide are discussed in Section 3.8.2.

A biomarker of susceptibility is an indicator of an inherent or acquired limitation of an organism’s ability to respond to the challenge of exposure to a specific xenobiotic substance. It can be an intrinsic genetic or other characteristic or a preexisting disease that results in an increase in absorbed dose, a decrease in the biologically effective dose, or a target tissue response. If biomarkers of susceptibility exist, they are discussed in Section 3.10, Populations That Are Unusually Susceptible.

### 3.8.1 Biomarkers Used to Identify or Quantify Exposure to Hydrogen Sulfide and Carbonyl Sulfide

Hydrogen Sulfide. The most frequently used biomarker of hydrogen sulfide exposure is urinary thiosulfate levels (Milby and Baselt 1999). Thiosulfate is an oxidation product of hydrogen sulfide metabolism and is not specific to hydrogen sulfide metabolism. Ingestion of food or water with high sulfur content can also increase urinary thiosulfate concentrations (Milby and Baselt 1999). An increase in urinary thiosulfate levels were observed in individuals exposed to 8, 18, or 30 ppm hydrogen sulfide for 30–45 minutes (Kangas and Savolainen 1987). The urinary thiosulfate levels peaked approximately 15 hours after exposure. In a subject exposed to 18 ppm for 30 minutes, the peak urinary thiosulfate concentration at 15 hours was 30 µmol/mmol creatinine; 17 hours after exposure, the urinary thiosulfate levels were similar to non-exposed individuals (mean concentration of 2.9 µmol/mmol creatinine). A quantitative relationship between hydrogen sulfide exposure levels and urinary thiosulfate levels has not been established.

Measurement of blood sulfide levels has also been proposed as a biomarker of exposure (Jappinen and Tenhunen 1990). This has limited clinical value because the blood samples must be collected within 2 hours of exposure (Jappinen and Tenhunen 1990). As with urinary thiosulfate levels, a relationship between airborne hydrogen sulfide levels and blood sulfide levels has not been established; additionally, the biomarker is not specific to hydrogen sulfide.

Jappinen and Tenhunen (1990) also investigated the use of alterations in blood heme metabolism as a possible biomarker of hydrogen sulfide exposure. The activities of the enzymes of heme synthesis (i.e., delta-aminolevulinic acid synthase (ALA-S) and heme synthase) were examined in 21 cases of acute hydrogen sulfide toxicity in Finnish pulp mill and oil refinery workers exposed to 20–200 ppm hydrogen sulfide for periods ranging from approximately 1 minute up to 3.5 hours. Several subjects lost consciousness for up to 3 minutes. The activity of delta-aminolevulinic acid synthase and heme synthase were decreased after exposure to hydrogen sulfide. However, the changes in heme metabolism are not specific for hydrogen sulfide, and other sulfur-containing compounds (such as methyl mercaptan) can produce similar effects.

Carbonyl Sulfide. No information on biomarkers of exposure was identified for carbonyl sulfide.

### 3.8.2 Biomarkers Used to Characterize Effects Caused by Hydrogen Sulfide and Carbonyl Sulfide

Hydrogen Sulfide. Hydrogen sulfide-specific biomarkers of effect have not been identified. Potential biomarkers for neurological effects of hydrogen sulfide include indices of cortical, hippocampal, brain stem, basal ganglia, and diencephalon dysfunction. An oil-field worker who became unconscious following exposure to hydrogen sulfide had a diminished vibration sense, delayed visual reaction times, abnormal balance with eyes closed, slow blink reflex latency, impaired verbal and visual recall, and decreased cognitive performance (Kilburn 1993). Cortical function tests revealed deficits in verbal abstraction, attention, and short-term retention in a hydrogen sulfide-poisoned patient (Stine et al. 1976). A 5-year neuro-psychological re-examination of patients who lost consciousness after hydrogen sulfide exposure revealed neurological impairment (Tvedt et al. 1991b); memory and motor function were most affected. Such neurological effects are not specific for hydrogen sulfide and could indicate exposure to other neurotoxic substances.

Carbonyl Sulfide. No information on biomarkers used to characterize effects caused by carbonyl sulfide was located.

## 3.9 INTERACTIONS WITH OTHER CHEMICALS

Hydrogen Sulfide. In a group of Belgian viscose rayon workers exposed to 0.14 or 6.4 ppm of hydrogen sulfide and at least 26 mg/m^3^ of carbon disulfide, the incidence of eye irritation was significantly higher in all hydrogen sulfide-exposed workers than in unexposed controls (Vanhoorne et al. 1995). Control for confounders such as cigarette smoke was not performed (Vanhoorne et al. 1995). Simultaneous exposure of Sprague-Dawley rats to 500 ppm of carbon disulfide and 50 ppm of hydrogen sulfide 5 days/week for 25 weeks, had no interactive effect on sensory tail nerve conduction velocities (SNCV) or motor tail nerve conduction velocities (MNCV) (Gagnaire et al. 1986). Additionally, the amount of 2-thio-thiazolidine-4-carboxylic acid (a urinary metabolite of carbon disulfide excreted in urine after exposure to carbon disulfide) was unaffected by hydrogen sulfide exposure (Gagnaire et al. 1986). In a series of reproductive and developmental studies in which albino rats were exposed to hydrogen sulfide and carbon disulfide, both pre- and postimplantational lethality as well as developmental anomalies of the genitourinary and skeletal systems were reported (Barilyak et al. 1975). However, in some cases, these effects occurred in conjunction with maternal toxicity. It is not clear whether the reported concentration (10 mg/m^3^) to which the animals were exposed includes both hydrogen sulfide and carbon disulfide or represents individual concentrations of each chemical.

There appears to be some evidence that ethanol can increase the effects of hydrogen sulfide. In six cases, less hydrogen sulfide was needed for toxic effects to be observed when workers had consumed alcohol 16–24 hours earlier (Poda 1966).

Much of the occupational data on hydrogen sulfide comes from studies of pulp and paper mill workers who were exposed to other compounds in addition to hydrogen sulfide. An increase in chronic or recurrent headache was noted in Finnish pulp workers who were exposed simultaneously to hydrogen sulfide, methyl mercaptans, and sulfur dioxide (Kangas et al. 1984). Peak concentrations of the chemicals (up to 20 ppm hydrogen sulfide) were believed to be responsible for the occurrence of the symptoms, rather than the lower mean concentrations. A respiratory survey of almost 2,000 Canadian pulp and paper mill workers did not show any increases in the prevalence of respiratory symptoms or pulmonary function abnormalities among exposed workers (Chan-Yeung et al. 1980). Mean exposure concentrations of toxicants measured in this study were 0.05 ppm hydrogen sulfide, 0.3 ppm sulfur dioxide, 8.3 ppm carbon monoxide, 0.8 ppm total particulates, and <0.05 ppm chlorine.

No changes in body weight or microscopic changes in respiratory tract, eye, or visceral organs were noted in crossbred pigs inhaling 2 ppm of hydrogen sulfide and 50 ppm of ammonia continuously for 19 days when compared to controls (Curtis et al. 1975). The toxicity of hydrogen sulfide after dermal exposure was found to be enhanced by dermal exposure to ammonia (Laug and Draize 1942).

Male Wistar rats were administered 330 or 660 mg/kg of ethanol intraperitoneally 30 minutes before being exposed to 800 ppm of hydrogen sulfide for a maximum of 20 minutes (which was a potentially fatal hydrogen sulfide exposure) (Beck et al. 1979). Mean times to unconsciousness in animals that were exposed to hydrogen sulfide with ethanol pretreatment at either of these dose levels were approximately 35% less than times to unconsciousness without ethanol pretreatment (Beck et al. 1979). The clinical relevance of these findings using potentially fatal doses of both ethanol and hydrogen sulfide is unclear.

Carbonyl Sulfide. No studies examining interactions of carbonyl sulfide with other chemicals were located.

## 3.10 POPULATIONS THAT ARE UNUSUALLY SUSCEPTIBLE

A susceptible population will exhibit a different or enhanced response to hydrogen sulfide and carbonyl sulfide than will most persons exposed to the same level of hydrogen sulfide and carbonyl sulfide in the environment. Factors involved with the increased susceptibility may include genetic makeup, age, health and nutritional status, and exposure to other toxic substances (e.g., cigarette smoke). These parameters result in reduced detoxification or excretion of hydrogen sulfide and carbonyl sulfide, or compromised function of organs affected by hydrogen sulfide and carbonyl sulfide. Populations who are at greater risk due to their unusually high exposure to hydrogen sulfide and carbonyl sulfide are discussed in Section 6.7, Populations with Potentially High Exposures.

Hydrogen Sulfide. Some asthmatics exposed to 2 ppm hydrogen sulfide for 30 minutes had changes in pulmonary function tests suggestive of bronchial obstruction, although the exposed group as a whole did not show a statistically significant change in these parameters (Jappinen et al. 1990). Asthmatics have also been found to have a worsening of their condition upon exposure to odors (Shim and Williams 1986). Although this has not been tested with exposure to hydrogen sulfide, it might be reasonably anticipated due to the malodorous quality of hydrogen sulfide gas. These findings suggest that some asthmatics may be more sensitive to hydrogen sulfide than the general population.

Evidence from a number of studies suggests that hydrogen sulfide endogenously produced by bacteria in the digestive tract may play a role in the etiology of ulcerative colitis (Babidge et al. 1998; Pitcher and Cummings 1996; Roediger et al. 1997). It is unclear whether patients are affected due to the excess production of hydrogen sulfide or the inability to detoxify it as effectively as controls. Irrespective of mechanism, it seems likely that individuals already suffering from hydrogen sulfide-associated toxicity will be at higher risk from further hydrogen sulfide exposures. However, there are no data to support whether individuals with ulcerative colitis are more susceptible to the toxicity of hydrogen sulfide.

Carbonyl Sulfide. No information was located which could be used to identify populations that may be unusually susceptible to the toxicity of carbonyl sulfide.

## 3.11 METHODS FOR REDUCING TOXIC EFFECTS

This section will describe clinical practice and research concerning methods for reducing toxic effects of exposure to hydrogen sulfide and carbonyl sulfide. Because some of the treatments discussed may be experimental and unproven, this section should not be used as a guide for treatment of exposures to hydrogen sulfide and carbonyl sulfide. When specific exposures have occurred, poison control centers and medical specialists with experience and expertise in treating patients exposed or potentially exposed to hydrogen sulfide or carbonyl sulfide (i.e., board certified medical toxicologists, board certified occupational medicine physicians, pediatric environmental health medical specialists, etc.) should be consulted for medical advice. The following texts provide specific information about treatment following exposures to hydrogen sulfide:

Hoffman RS, Howland MA, Lewin NA, et al., eds. 2015. Goldfrank’s toxicologic emergencies, 10th edition. New York, NY: McGraw Hill, 1606–1611.

Caravati EM. 2004. Hydrogen sulfide. In: Dart RC, ed. Medical toxicology, 3rd edition; Philadelphia, PA: Lippincott Williams and Wilkins, 1169–1174.

Guidotti TL. 2007. Hydrogen sulfide. In: Shannon MW, Borron SW, Burns MJ, Eds. Haddad and Winchester’s clinical management of poisoning and drug overdose, 4th edition. Philadelphia, PA: Saunders Elsevier, 1335–1342.

### 3.11.1 Reducing Peak Absorption Following Exposure

There are no specific methods available to reduce the absorption of hydrogen sulfide or carbonyl sulfide following exposure. Supportive treatment includes immediate removal from exposure and administration of high flow oxygen (Hoffman et al. 2015).

### 3.11.2 Reducing Body Burden

There are no known methods for reducing the body burden of hydrogen sulfide or carbonyl sulfide.

### 3.11.3 Interfering with the Mechanism of Action for Toxic Effects

Hydrogen Sulfide. Hydrogen sulfide inhibits mitochondrial cytochrome oxidase, resulting in disruption of the electron transport chain and impairing oxidative metabolism. Nervous and cardiac tissues, which have the highest oxygen demand (e.g., brain and heart), are especially sensitive to disruption of oxidative metabolism (Ammann 1986; Hall 1996).

Nitrites such as amyl and sodium nitrites have been used in the treatment of hydrogen sulfide poisoning, and the mechanism of therapeutic action may involve the prevention or reversal of cytochrome oxidase inhibition (Ellenhorn 1997; Hall 1996; Hoidal et al. 1986; Osbern and Crapo 1981; Reiffenstein et al. 1992). It has been postulated that nitrites induce methemoglobin which inactivates sulfide thereby preventing cytochrome oxidase inhibition and reactivating aerobic respiration (Ellenhorn 1997; Hall 1996). There is anecdotal evidence to suggest that this is an effective treatment in cases of exposure to high concentrations of hydrogen sulfide (Hall 1996; Hall and Rumack 1997; Hoidal et al. 1986; Stine et al. 1976). However, this treatment approach has only been shown to be effective if administered within the first minutes of exposure because the sulfide-methemoglobin complex breaks down rapidly in the presence of oxygen (Beck et al. 1981; Ellenhorn 1997; Hall 1996). Given the increased sensitivity of young children to the development of methemoglobinemia from exposure to nitrates/nitrites, care should be taken in using this approach. Consultation with a medical specialist with both expertise and experience treating pediatric patients exposed to hydrogen sulfide would be prudent.

Oxygen treatment may be used after hydrogen sulfide poisoning, although its use is somewhat controversial (Ellenhorn 1997; Ravizza et al. 1982). Smith et al. (1976) found that oxygen was not useful as an antidote to hydrogen sulfide poisoning in mice. High intracellular oxygen pressure may result in nonenzymatic oxidation of cytochrome oxidase, and oxygen may release sulfide from cytochrome oxidase binding by a concentration effect (Ravizza et al. 1982). Hyperbaric oxygen therapy has been suggested for cases not responding to supportive care and nitrite treatment, but its clinical efficacy has not yet been determined (Ellenhorn 1997; Hall 1996). Several case studies have reported the successful use of hyperbaric oxygen treatment (Asif and Exline 2012; Belley et al. 2005; Lindenmann et al. 2010). A study in rats found that hyperbaric treatment for 100 minutes initiated within 20 minutes of termination of a 60-minute exposure to 300 ppm hydrogen sulfide did not significantly alter partial pressure of oxygen, as compared to animals similarly exposed and not undergoing hyperbaric treatment (Wu et al. 2011). However, it did result in a significant decrease in lung cytochrome c oxidase levels. Use of hyperbaric oxygen therapy for hydrogen sulfide toxicity in pediatric populations needs further investigation.

In one case report (Schneider et al. 1998) where an individual suffered long-term (4 years later) neuropsychological sequelae from a “knock-down” exposure to hydrogen sulfide, treatment with two drugs, Ritalin and Cyclert, partially alleviated some of the observed deficits in cognitive function and general cognition; these drugs enhance dopaminergic functioning. However, more examples of the efficacy of this treatment are required.

Haouzi et al. (2015) showed that immediate intravenous administration of hydroxocobalamin could reduce the risk of hydrogen sulfide induced cardiac arrest in sedated, mechanically ventilated sheep infused with high doses of sodium hydrosulfide. The investigators noted that hydroxocobalamin was effective if administered 1–4 minutes after exposure cessation when free hydrogen sulfide was present in the blood; given this small treatment window, this may not be effective for human exposure scenarios. Sonobe et al. (2015) showed that administration of methylene blue decreased the risk of coma and increased survival in rats administered sodium hydrosulfide hydrate via intraperitoneal injection; the rats were injected twice with methylene blue several minutes after sodium hydrosulfide. Improvements in performance on neurobehavioral tests (open field and Morris water maze) were also observed in the methylene blue treated rats.

Carbonyl Sulfide. No information on interfering with the mechanisms of carbonyl sulfide toxicity was located.

## 3.12 ADEQUACY OF THE DATABASE

Section 104(I)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of hydrogen sulfide and carbonyl sulfide is available. Where adequate information is not available, ATSDR, in conjunction with the National Toxicology Program (NTP), is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of hydrogen sulfide and carbonyl sulfide.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 3.12.1 Existing Information on Health Effects of Hydrogen Sulfide and Carbonyl Sulfide

The existing data on health effects of inhalation, oral, and dermal exposure of humans and animals to hydrogen sulfide and carbonyl sulfide are summarized in Figures 3-5 and 3-6. The purpose of this figure is to illustrate the existing information concerning the health effects of hydrogen sulfide and carbonyl sulfide. Each dot in the figure indicates that one or more studies provide information associated with that particular effect. The dot does not necessarily imply anything about the quality of the study or studies, nor should missing information in this figure be interpreted as a “data need”. A data need, as defined in ATSDR’s Decision Guide for Identifying Substance-Specific Data Needs Related to Toxicological Profiles (ATSDR 1989), is substance-specific information necessary to conduct comprehensive public health assessments. Generally, ATSDR defines a data gap more broadly as any substance-specific information missing from the scientific literature.

### 3.12.2 Identification of Data Needs

#### Acute-Duration Exposure.

Hydrogen Sulfide. There are numerous case reports of human fatalities (Adelson and Sunshine 1966; Ago et al. 2008; Allyn 1931; Bott and Dodd 2013; Breysse 1961; Christia-Lotter et al. 2007; Campanya et al. 1989; Deng and Chang 1987; Freireich 1946; Hagley and South; Knight and Presnell 2005; Maebashi et al. 2011; Morse et al. 1981; Osbern and Crapo 1981; Parra et al. 1991; Policastro and Otten 2007; Reedy et al. 2011; Yalamanachili and Smith 2008) or survivors who developed immediate as well as delayed neurological effects (Deng and Chang 1987; Kilburn 1993, 1997; Krekel 1964; McDonald and McIntosh 1951; Milby 1962; Schneider et al. 1998; Spolyar 1951) following acute-duration hydrogen sulfide inhalation exposure. Estimates of exposure concentrations were not often reported in these studies. Cardiac arrhythmia has also been reported in workers exposed to hydrogen sulfide (Krekel 1964). Experimental exposure studies in which subjects were exposed to hydrogen sulfide for 15–120 minutes did not identify any respiratory or cardiovascular effects in healthy subjects at 5 or 10 ppm (Bhambhani and Singh 1991; Bhambhani et al. 1994, 1996a; Fiedler et al. 2008). Suggestive evidence of bronchial obstruction was observed in 2 of 10 asthmatics exposed to 2 ppm of hydrogen sulfide for 30 minutes, although the group as a whole had no significant change in these parameters (Jappinen et al. 1990). Additionally, studies are needed to assess whether asthmatic subjects are a sensitive subpopulation. Because hydrogen sulfide gas is an eye irritant (Ahlborg 1951; Luck and Kaye 1989), studies should monitor ocular effects. Additional studies of the delayed consequences of acute exposures are also needed.

Figure 3-5 Existing Information on Health Effects of Hydrogen Sulfide

Figure 3-6 Existing Information on Health Effects of Carbonyl Sulfide

Acute-duration inhalation studies of hydrogen sulfide in animals have reported death (Beck et al. 1979; Khan et al. 1990; Lopez et al. 1989; Nagata et al. 1990; Prior et al. 1988, 1990; Smith and Gosselin 1964; Tansy et al. 1981), respiratory (Brenneman et al. 2002; Green et al. 1991; Khan et al. 1990; Kohno et al. 1991; Lopez et al. 1987, 1988a, 1988b; Prior et al. 1990), cardiovascular (Higuchi and Fukamachi 1977; Kohno et al. 1991; Kosmider et al. 1967), immunological/lymphoreticular (Khan et al. 1991), and neurological effects (Beck et al. 1979; Haider et al. 1980; Higuchi and Fukamachi 1977; Kosmider et al. 1967; Lopez et al. 1988b; Struve et al. 2001). Additional acute-duration inhalation animal studies would be useful to further define any direct cardiovascular effects of hydrogen sulfide as opposed to those due to hypoxia. The available data on the acute toxicity of inhaled hydrogen sulfide were sufficient for derivation of an acute-duration inhalation MRL.

Data are not sufficient for the development of an acute-duration oral MRL. The only oral study of hydrogen sulfide is a study in which a diarrheic digestive disorder was observed in pigs fed hydrogen sulfide at 15 mg/kg/day for "a few days" (Wetterau et al. 1964). Acute dermal exposure of animals has resulted in death (Laug and Draize 1942). In addition to a lack of route-specific toxicity data, insufficient pharmacokinetic data are available to support the identification of target organs across routes of exposure. However, although oral and dermal data regarding the effects of hydrogen sulfide are very limited, human exposure would be expected to be principally by inhalation.

Carbonyl Sulfide. Death occurred following a single inhalation exposure in rats (DuPont 1981; Monsanto 1985a) or repeated inhalation exposures in rats (Morgan et al. 2004) and rabbits (Hugod 1981; Hugod and Astrup 1980; Kamstrup and Hugod 1979). Neurotoxicity (including overt signs of toxicity and histological alterations in the brain) was observed in rats exposed via inhalation once or up to 12 times (Herr et al. 2007; Monsanto 1985b; Morgan et al. 2004; Morrison et al. 2009; Sills et al. 2004). Although these studies identified NOAELs and LOAELs and established dose-response relationships, the database was not considered adequate for derivation of an acute-duration inhalation MRL for carbonyl sulfide because there are insufficient data to determine whether neurotoxicity is the most sensitive end point. Additionally, studies that include examination of major tissues and organs are needed to determine if there are other sensitive targets of toxicity.

#### Intermediate-Duration Exposure.

Hydrogen Sulfide. Intermediate-duration studies in humans are fairly limited and virtually all are complicated by exposures to other chemicals as well as rarely being accompanied with adequate exposure assessment. Additional epidemiologic studies (particularly prospective or case-control studies) of populations exposed environmentally to various levels of hydrogen sulfide (where other pollutants are monitored and ideally, do not vary) are needed.

A series of 90-day inhalation studies in rats (CIIT 1983b, 1983c) reported significantly decreased body weights in Sprague-Dawley female rats at 80 ppm, but not in male Sprague-Dawley (CIIT 1983c) nor in either sex of F-344 rats (CIIT 1983b). Although CIIT (1983b, 1983c) did not report increases in the occurrence of histological lesions, a re-examination of the histological slides from this study (Dorman et al. 2004) found increases in the incidence of nasal (olfactory neuron loss) and lung (bronchiolar epithelial hypertrophy and hyperplasia) lesions at 30 ppm and higher. In a companion study with B6C3F_1_ mice, a significant increase in the incidence of inflammation of the nasal mucosa was observed at a dose level of 80 ppm but not at 30.5 ppm. Brenneman et al. (2000) identified a NOAEL and LOAEL for nasal effects (loss of olfactory neurons) in Sprague-Dawley rats exposed to 10 and 30 ppm, respectively, for 10 weeks. Although use of the Brenneman et al. (2000) study as the basis of an intermediate-duration inhalation MRL was considered, the human equivalent concentration (HEC) of the NOAEL (5 ppm) was similar to LOAELs identified for respiratory effects in humans acutely exposed to hydrogen sulfide. Thus, the database was considered inadequate for derivation of an intermediate-duration inhalation MRL for hydrogen sulfide.

No histopathological effects were found in respiratory tract tissues or organs when pigs were exposed to 8.5 ppm hydrogen sulfide continuously for 17 days (Curtis et al. 1975). Additional effects reported in rats following inhalation exposure to hydrogen sulfide include increased glucose in lactating rats (Hayden et al. 1990a), increased liver cholesterol in female rats exposed during gestation and lactation (Hayden et al. 1990b), and weight loss in pregnant rats (Saillenfait et al. 1989).

The only oral study of hydrogen sulfide is a study in pigs in which decreased body weights were observed in pigs fed hydrogen sulfide in the diet at 6.7 mg/kg/day for 105 days (Wetterau et al. 1964). No effects were observed at a dose of 3.1 mg/kg/day. However, because this study lacks details and there are no supporting data, no intermediate-duration MRL was derived. Additional intermediate-duration oral studies of hydrogen sulfide are needed to provide support for this study.

No intermediate-duration dermal studies of hydrogen sulfide were identified. As significant human dermal exposure to hydrogen sulfide is unlikely, dermal exposure studies should not be a high priority. However, no pharmacokinetic data are available that might support the identification of target organs across routes of exposures in the absence of route-specific toxicity data.

Carbonyl Sulfide. Studies examining the toxicity of inhaled carbonyl sulfide following intermediate-duration exposure consist of a study in rabbits examining ultrastructural changes in the vascular system and heart (Hugod and Astrup 1980, Hugod 1981), a study examining morphological changes in the lungs, heart, and aorta of rabbits (Kamstup and Hugod 1979), several studies examining neurological end points (Herr et al. 2007; Morgan et al. 2004; Sills et al. 2004), and a reproductive toxicity study in male rats (Monsanto 1987). The animal studies clearly identify the nervous system and possibly the male reproductive system as targets of carbonyl sulfide toxicity. However, the lack of data from studies examining other major tissues and organs does not allow for the determination of the most sensitive targets of toxicity. Thus, an intermediate-duration inhalation MRL for carbonyl sulfide cannot be determined at this time. No oral or dermal exposure studies were identified.

#### Chronic-Duration Exposure and Cancer.

Hydrogen Sulfide. Studies of workers (Ahlborg 1951; Hessel et al. 1997; Richardson 1995), residents living in areas with high geothermal activity (Bates et al. 1997, 2002), residents living near paper mills (Haahtela et al. 1992; Jaakkola et al. 1990 Martttila et al. 1994a, 1994b, 1995; Partti-Pellinen et al. 1996), residents living near swine operations (Kilburn 2012; Schinasi et al. 2011), and residents living in other areas with high levels of hydrogen sulfide (Campagna et al. 2004; Carlsen et al. 2012; Legator et al. 2001) have reported increases in the occurrence of respiratory effects including irritation and alterations in lung function. Most of these studies have the common limitations of poorly reported exposure levels (or lack of monitoring data) and concomitant exposure to other compounds including mercaptans, sulfur dioxide, ammonia, and particulate matter. There was no increase in cancer incidence noted in a residential cohort study of persons living downwind from natural gas refineries (Schechter et al. 1989), but an increased risk of nasal cancers was found in a population residing in a location of high geothermal activity (Bates et al. 1998). No studies have examined the chronic toxicity or carcinogenicity of hydrogen sulfide in laboratory animals.

Additional chronic-duration studies of hydrogen sulfide (including studies of the carcinogenic potential of hydrogen sulfide in humans and animals by any route of exposure) have not been performed. Follow-up epidemiological studies of populations environmentally exposed to hydrogen sulfide due to proximity of pulp mills, sour gas plants, or geothermal energy sources are needed, but only if they are accompanied by adequate exposure measurements. As limited genotoxicity studies suggest that hydrogen sulfide is unlikely to be a carcinogen, lifetime carcinogenicity studies in animals should not be a high priority. In the absence of route-specific toxicity data and route-specific pharmacokinetic data, it is not possible to identify target organs across routes of exposure.

Carbonyl Sulfide. No human or animal studies have examined the chronic toxicity or carcinogenicity of carbonyl sulfide following inhalation, oral, or dermal exposure. Chronic-duration animal studies are needed to identify targets of toxicity, establish dose-response relationships, and to evaluate the carcinogenic potential of carbonyl sulfide.

#### Genotoxicity.

Hydrogen Sulfide. No mutagenicity was observed in Ames assays using Salmonella typhimurium strains TA97, TA98, and TA100 (with or without S9 liver fractions from male Syrian golden hamsters or Sprague-Dawley rats) (EPA 1984). Specific concentrations of hydrogen sulfide gas were limited because of its solubility in ethanol, which was the test solvent. The highest dose that could be obtained was 1,750 μg/plate. Other studies using hydrogen sulfide in the gaseous state would be useful for testing higher doses.

Carbonyl Sulfide. No genotoxicity studies were located for carbonyl sulfide. In vitro studies are needed to assess whether carbonyl sulfide is genotoxic.

#### Reproductive Toxicity.

Hydrogen Sulfide. The findings in two studies (Hemminki and Niemi 1982; Xu et al. 1998) that exposures to hydrogen sulfide are associated with an increased risk of spontaneous abortion warrant further investigation. A well-designed case-control study is needed in which exposure is well characterized in order to ascertain whether this is indeed an effect of concern or merely an anomaly. Additional epidemiologic studies of other reproductive effects would also be useful. No treatment-related histopathological changes were found in the male or female reproductive organs of rats (CIIT 1983b, 1983c) or mice (CIIT 1983a) exposed to hydrogen sulfide for 6 hours/day, 5 days/week for 90 days or in rats exposed to 80 ppm hydrogen sulfide 6 hours/day, 7 days/week for 60–70 days (Dorman et al. 2000). The Dorman et al. (2000) study also found no exposure-related alterations in fertility, late resorptions or stillbirths, litter size, or length of gestation. A multilitter or multigeneration study in several animal species after exposure to hydrogen sulfide by inhalation is needed to further evaluate the reproductive potential of hydrogen sulfide.

Carbonyl Sulfide. Information on the reproductive toxicity of carbonyl sulfide is limited to a study in which male rats were exposed to inhaled carbonyl sulfide prior to mating with unexposed females (Monsanto 1987). The study reported a decrease in pregnancy rate. Additional studies are needed to determine the cause of the decreased pregnancy rate and to evaluate whether carbonyl sulfide affects female reproduction.

#### Developmental Toxicity.

Hydrogen Sulfide. No studies were located regarding developmental effects in humans following hydrogen sulfide exposure.

Developmental effects were not observed in rats exposed to hydrogen sulfide by inhalation at concentrations that resulted in maternal body weight loss (Saillenfait et al. 1989), increased maternal blood glucose levels (Hayden et al. 1990a), or increased cholesterol content of the maternal liver (Hayden et al. 1990b). Purkinje cell path length in offspring of exposed rats was increased compared to controls (Hannah and Roth 1991). Changes in amino acid levels (Hannah et al. 1989, 1990) and serotonin and epinephrine levels (Skrajny et al. 1992) in the brain were found in the offspring of rats exposed by inhalation to hydrogen sulfide during gestation. No alterations in performance on neurobehavioral tests were observed in the offspring of rats exposed to up to 80 ppm 6 hours/day, 7 days/week during gestation and lactation (the pups were also exposed on postnatal days 5–18) (Dorman et al. 2000). Studies regarding the developmental toxicity of hydrogen sulfide following oral or dermal exposure were not located.

Carbonyl Sulfide. No studies evaluating the potential developmental toxicity of carbonyl sulfide were located. Developmental toxicity studies are needed to assess whether the developing organism is a sensitive target; these studies should include neurodevelopmental toxicity testing since neurotoxicity is a sensitive end point in adults.

#### Immunotoxicity.

Hydrogen Sulfide. Immunological effects infrequently observed after human hydrogen sulfide exposure appear to result from infection due to the aspiration or ingestion of manure or gastric contents (Osbern and Crapo 1981). No treatment-related histopathological changes were found in the spleen or lymph nodes of rats (CIIT 1983b, 1983c) or mice (CIIT 1983a) exposed to hydrogen sulfide for 6 hours/day, 5 days/week for 90 days. Although the number of pulmonary alveolar macrophage cells was not influenced by hydrogen sulfide exposure, the number of viable cells was significantly decreased with exposure to 400 ppm (Khan et al. 1991). When pulmonary alveolar macrophage cells were treated with Zymosan to stimulate respiration rates, there was no stimulation of respiration in cells from animals exposed to 200 or 400 ppm of hydrogen sulfide for 4 hours (Khan et al. 1991). Immunological effects have not been studied in humans or animals following oral or dermal exposure to hydrogen sulfide.

Additional studies of immune function in animals exposed to hydrogen sulfide by inhalation are needed. A bacterial and/or viral challenge study would be especially useful to determine whether exposure to hydrogen sulfide increases susceptibility to infection.

Carbonyl Sulfide. No studies evaluating the potential immunotoxicity of carbonyl sulfide were located. Studies are needed to assess whether the immune system is a target of carbonyl sulfide toxicity.

#### Neurotoxicity.

Hydrogen Sulfide. The nervous system is a target organ for hydrogen sulfide. Effects of acute inhalation exposure in humans include nausea, headaches, delirium, disturbed equilibrium, poor memory, loss of consciousness, tremors, and convulsions (Arnold et al. 1985; Deng and Chang 1987; Krekel 1964; McDonald and McIntosh 1951; Milby 1962; Spolyar 1951). Acute effects observed in animals include fatigue, somnolence (Haider et al. 1980), and loss of consciousness (Kosmider et al. 1967). Limited data from chronically exposed workers indicate that loss of appetite, fatigue, poor memory, dizziness, and irritability may result (Ahlborg 1951; Krekel 1964). Studies in rats have shown decreases in performance of discriminated avoidance tasks after exposure to hydrogen sulfide (Higuchi and Fukamachi 1977). The potential neurotoxicity of hydrogen sulfide following oral or dermal exposures has not been characterized. The transplacental neurological effects of hydrogen sulfide exposure are unknown. There is no reason to suspect that the neurotoxic effects observed after hydrogen sulfide exposure are species-specific, and insufficient data are available to determine whether effects are route-specific. Well-designed studies investigating neurotoxic effects in animals following oral or dermal exposure and chronic neurotoxic effects after inhalation exposure are needed to determine the effects that might be seen in exposed humans. Additionally, there is anecdotal evidence that some individuals experience permanent or persistent neurological symptoms (such as memory loss) after acute exposures to high concentrations of hydrogen sulfide. Studies are needed to confirm these reports and determine if acute exposure to hydrogen sulfide can result in permanent neurological damage.

Carbonyl Sulfide. Several acute- and intermediate-duration studies have evaluated the neurotoxicity of carbonyl sulfide in rats. The effects ranged from severe signs of neurotoxicity (including ataxia and hypothermia) and necrosis and neuronal loss in the parietal cortex, thalamus, and other midbrain structures to impaired performance on neurophysiological tests and motor function tests (Herr et al. 2007; Monsanto 1985b; Morgan et al. 2004; Morrison et al. 2009; Sills et al. 2004). These studies have identified NOAEL and LOAEL values for neurotoxicity and the results demonstrate a steep dose-response curve. Additional studies in different species would be useful in evaluating the relevance of the neurological effects observed in rats to humans.

#### Epidemiological and Human Dosimetry Studies.

Hydrogen Sulfide. Published reviews have addressed the duration of exposure and concentrations of hydrogen sulfide resulting in death and serious effects in humans (Beauchamp et al. 1984; EPA 1978; NIOSH 1977a; WHO 1981). Some chronic-duration epidemiological studies (Ahlborg 1951; Haahtela et al. 1992; Horton et al. 2009; Inserra et al. 2004; Jaakkola et al. 1990; Jappinen et al. 1990; Marttila et al. 1994b; Schechter et al. 1989; Tenhunen et al. 1983) have identified approximate exposure concentrations, but exposure assessment was not sufficient to divide the study population into more than one exposure group. Other studies evaluating respiratory effects (Campagna et al. 2004; Carlsen et al. 2012; Dongo et al. 2012; Kilburn 2012; Kilburn et al. 2010; Legator et al. 2001; Marttila et al. 1994a, 1995; Partti-Pellinen et al. 1996; Schinasi et al. 2011) or neurological effects (Bates et al. 1998; Farahat and Kishk 2010; Kilburn 1997; Legator et al. 2001) have not measured hydrogen sulfide levels. Epidemiology studies examining the potential effects of chronic inhalation exposure to various hydrogen sulfide concentrations are needed. Additionally, studies are needed that control for exposure to other contaminants such as methyl mercaptan, methyl sulfides, sulfur dioxide, and particulate matter. There are known populations that have unusually high exposure to hydrogen sulfide.

Carbonyl Sulfide. No human studies examining the potential toxicity of carbonyl sulfide in humans were identified. Studies are needed in populations exposed to carbonyl sulfide to evaluate potential targets of toxicity. Because the animal studies suggest that the nervous system is a sensitive target, epidemiology studies should include neurobehavioral testing.

#### Biomarkers of Exposure and Effect.

##### Exposure

Hydrogen Sulfide. Both blood sulfide concentrations (Jappinen and Tenhunen 1990) and urinary thiosulfate concentrations (Kage et al. 1992; Kangas and Savolainen 1987) have been proposed as indicators of hydrogen sulfide exposure. Obtaining background levels of blood sulfide in a population should not be problematic, although blood samples to determine sulfide concentrations must be obtained within 2 hours of exposure to hydrogen sulfide. Similarly, urinary thiosulfate levels can be obtained for the background population. Further study is needed to correlate airborne exposure concentrations with blood sulfide and thiosulfate levels. Additional alterations in heme synthesis enzymes (delta-aminolevulinic acid synthase and heme synthase) have been proposed as possible biomarkers of exposure (Jappinen and Tenhunen 1990). These effects are not specific for hydrogen sulfide, and further study is needed to correlate these effects with blood sulfide and urinary thiosulfate levels.

Carbonyl Sulfide. There are no studies examining biomarkers of exposure to carbonyl sulfide, and such studies are needed.

##### Effect

Hydrogen Sulfide. No hydrogen-sulfide-specific biomarkers of effect have been identified. Neurological indices are also used as biomarkers of effect for hydrogen sulfide (Gaitonde et al. 1987; Kilburn 1993; Stine et al. 1976; Tvedt et al. 1991b). It is unlikely that a hydrogen-sulfide-specific biomarker of effect will be identified based on nonspecific effects that have been observed in humans and animals exposed to hydrogen sulfide and the mechanistic similarity between cyanide and hydrogen sulfide. Additional data are needed to identify a collection of symptoms that could reasonably characterize hydrogen sulfide exposure.

Carbonyl Sulfide. No studies examining specific biomarkers of effect were identified for carbonyl sulfide.

#### Absorption, Distribution, Metabolism, and Excretion.

Hydrogen Sulfide. Hydrogen sulfide is absorbed through the lungs and can be absorbed in minor quantities through the gastrointestinal tract and intact skin (Kohno et al. 1991; Laug and Draize 1942; Wetterau et al. 1964). Hydrogen sulfide is also produced endogenously in many tissues (e.g., liver, kidney, and heart) as a break-down product of cysteine metabolism. Thus, hydrogen sulfide is widely distributed in the body. Sulfides have been found in the heart, liver, blood, brain, lungs, spleen, and kidneys of humans who died after accidental inhalation exposure (Kohno et al. 1991). However, there are no studies that have tracked the quantitative absorption or endogenous production of hydrogen sulfide nor quantified the differences in its distribution in the various tissues to follow absorption of an external dose. No data are available on distribution after oral or dermal exposure to hydrogen sulfide.

Hydrogen sulfide is metabolized through three pathways: oxidation, methylation, and reactions with metalloproteins or disulfide-containing proteins (Beauchamp et al. 1984). Although the major metabolic pathway for detoxification is oxidation of the sulfide to sulfate in the liver, methylation also serves to detoxify hydrogen sulfide (EPA 1987; Weisiger and Jakoby 1979). The major oxidation product of hydrogen sulfide is thiosulfate, which may be then converted to sulfate and excreted in the urine (Bartholomew et al. 1980; Kage et al. 1992; Kangas and Savolainen 1987). The primary location for the oxidation reaction is the liver (Bartholomew et al. 1980).

The qualitative data on the absorption, distribution, metabolism, and excretion of hydrogen sulfide in humans and animals are well known; quantitative data are generally lacking. Additional studies in animals that provide quantitative toxicokinetic data are needed.

Carbonyl Sulfide. There are very limited data on the toxicokinetics of carbonyl sulfide consisting of two studies that focused on its metabolism by carbonic anhydrase and the mixed function oxidase enzyme system (Chengelis and Neal 1979, 1980). More studies are needed evaluating the absorption, distribution, metabolism, and excretion of carbonyl sulfide.

#### Comparative Toxicokinetics.

Hydrogen Sulfide. PBPK models have not been developed to compare the toxicokinetics of hydrogen sulfide in humans and animals. Studies providing quantitative data necessary to develop PBPK models would be useful.

Carbonyl Sulfide. There are currently insufficient data to characterize the toxicokinetics of carbonyl sulfide in any species; these data are needed for comparing the toxicokinetics across species.

#### Methods for Reducing Toxic Effects.

Hydrogen Sulfide. Other than removing the subject from exposure, there is no specific method to reduce the absorption of hydrogen sulfide. There are no known methods for reducing the body burden of hydrogen sulfide, although reducing the intake of sulfhydryl-containing a mino acids has been shown to reduce endogenous production. Amyl and sodium nitrites have been used as antidotes for hydrogen sulfide poisoning. Oxygen treatment, which may result in nonenzymatic oxidation of cytochrome oxidase, may also be used in the treatment of hydrogen sulfide poisoning (Hall 1996; Ravizza et al. 1982). Several case reports discussed the beneficial use of hyperbaric oxygen treatment (Asif and Exline 2012; Belley et al. 2005; Lindenmann et al. 2010); however, a rat study found that it decreased cytochrome c oxidase levels but did not affect the partial pressure of oxygen (Wu et al. 2011).

There is a need to develop an antidote for hydrogen sulfide poisoning, especially since it has a high knock-down potency. Additional research into the safe use of oxygen as an antidote for hydrogen sulfide poisoning is needed. Studies examining methods to enhance the oxidation or methylation of hydrogen sulfide to increase elimination might also be useful. Further studies of the efficacy of drugs such as Retalin and Cyclert to treat the long-term neuropsychological effects of a knock-down exposure are needed.

Carbonyl Sulfide. No studies have examined methods for reducing the toxic effects of carbonyl sulfide. The available data are insufficient to characterize the toxicity of carbonyl sulfide. There is a potential for human exposure to carbonyl sulfide and studies designed to evaluate methods for reducing toxic effects should be done after the critical targets of toxicity and modes of action have been identified.

Children’s Susceptibility. Data needs relating to both prenatal and childhood exposures and developmental effects (expressed either prenatally or during childhood) are discussed in detail in the Developmental Toxicity subsection above.

Hydrogen Sulfide. There is only limited information available by which to assess the potential toxicity of hydrogen sulfide to children and infants. Several case reports suggest that adolescents respond much like adults to high dose acute exposures (Allyn 1931; Hagley and South 1983; Morse et al. 1981). However, there is no information with which to determine whether the long-term consequences of such exposures differ for adolescents versus adults, nor is there any information on the effects of hydrogen sulfide exposures in children and very little information on infants. Several developmental toxicity studies indicated that the exposure of pregnant rats and their pups to hydrogen sulfide resulted in structural and biochemical changes in the brain (Hannah and Roth 1991; Hannah et al. 1989, 1991). Subsequent work showed that many of the biochemical changes were transient; however, no studies were found that evaluated the behavioral consequences of these changes. Thus, a variety of studies are needed in order to determine whether children and infants are at risk from neurological deficits following hydrogen sulfide exposures in utero or during childhood and adolescence; information from such studies would also be useful in order to determine whether children are more sensitive to hydrogen sulfide exposure.

Carbonyl Sulfide. No studies were identified that could evaluate children’s susceptibility to carbonyl sulfide. Studies in adult rats identify the nervous system as a sensitive target. Thus, future studies examining children should evaluate neurological end points to evaluate whether they are more sensitive than adults.

Child health data needs relating to exposure are discussed in Section 6.8.1, Identification of Data Needs: Exposures of Children.

### 3.12.3 Ongoing Studies

NIEHS is sponsoring a study conducted by Michael Bates, University of California at Berkeley, to examine the chronic toxicity of hydrogen sulfide. The study will examine 1,800 adults living in Rotorua, New Zealand with high, medium, or low exposures to hydrogen sulfide from geothermal fields. The subjects will undergo tests to evaluate neurobehavioral function, peripheral nerve function, lung function, potential cataract formation, and color vision impairment.

The National Institute of Neurological Disorders and Stroke (NINDS) is sponsoring a study conducted by Gerry Boss, University of California at San Diego, to evaluate whether cobinamide (the penultimate precursor in cobalamin [vitamin B12]), can be used as an antidote for hydrogen sulfide toxicity. In another NINDS-sponsored study, Philippe Haouzi, Pennsylvania State University, will examine the effectiveness of powdered methemoglobin and vitamin B12 (hydroxocobalamin) as an antidote in potentially lethal exposures to hydrogen sulfide.

No ongoing studies on carbonyl sulfide were identified.