# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL), prepare toxicological profiles for each substance included on the priority list of hazardous substances, and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates (which are intended to serve as screening levels) are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be greater than 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Hydrogen Sulfide Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hydrogen Sulfide
CAS Number: | 7783-06-4
Date: | November 2016
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 17
Species: | Human

[underlined: Minimal Risk Level]: 0.07 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Jäppinen P, Vikka V, Marttila O, et al. 1990. Exposure to hydrogen sulphide and respiratory function. Br J Intern Med 47:824–828.

[underlined: Experimental design]: This study evaluated lung function in three male and seven female subjects with bronchial asthma requiring medication for 1–13 years; none of the subjects had severe asthma. The subjects were exposed to 2 ppm hydrogen sulfide for 30 minutes. Respiratory function in response to a histamine challenge was assessed prior to exposure and after exposure.

[underlined: Effect noted in study and corresponding doses]: No statistically significant changes in forced vital capacity (FVC), forced expiratory volume in 1 second (FEV1), and forced expiratory flow were noted. Airway resistance (Raw) and specific airway conductance (SGaw) did not show statistically significant changes when examined as a group. In two subjects, there were changes of over 30% in both Raw and SGaw; these changes were suggestive of bronchial obstruction. Additionally, 3 of 10 subjects complained of headaches after exposure.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [x] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 3 for human variability
- [x] 3 for database deficiencies

The 2 ppm concentration was considered a minimally adverse effect level because the changes in airway resistance and specific airway conductance were only observed in 2 of 10 subjects. Because the study was conducted using asthmatics (who are likely to be a sensitive subpopulation) a partial uncertainty factor of 3 was used to account for human variability. An additional uncertainty factor of 3 was used for database deficiencies due to concern for the short (30-minute) exposure duration in the principal study.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] No.

[underlined: Was a conversion used from intermittent to continuous exposure?] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Bhambhani et al. (1996b) evaluated the acute effects of hydrogen sulfide on the physiological and hematological health of male and female volunteers exposed to 5 ppm during two 30-minute sessions of submaximal exercise (50% of maximum aerobic power). No significant changes in any parameter were noted in the women, whereas the men showed a significant decrease in muscle citrate synthetase as well as nonsignificant changes in lactate, lactate dehydrogenase, and cytochrome oxidase. Together, these changes were considered indicative of compromise of aerobic metabolism.

No respiratory or cardiovascular effects were observed in 16 male volunteers exposed by oral inhalation to hydrogen sulfide at 0.5, 2, or 5 ppm for >16 minutes while exercising (Bhambhani and Singh 1991). The end points examined included heart rate, oxygen uptake, carbon dioxide output, and blood gases. Airway resistance and conductance were not measured in this study. No significant changes in pulmonary function parameters were noted in individuals exposed to 10 ppm hydrogen sulfide for 15 minutes during exercise (Bhambhani et al. 1996a).

Respiratory distress was noted in two workers exposed to >40 ppm hydrogen sulfide for under 25 minutes (Spolyar 1951). In animals, impacts on the respiratory system such as increases in the cellularity and lactate dehydrogenase and alkaline phosphatase activity in bronchial lavage fluids have been seen at exposures as low as 10 ppm for 4 hours (Lopez et al. 1987), although without a dose-related trend.

Moderate to massive pulmonary edema was observed in rats exposed to 375 or 399 ppm for 4 hours (Prior et al. 1990). A significant dose-related decrease in lung microsomal cytochrome c oxidase activity was seen in rats following a 4 hour exposure to 50, 200, or 400 ppm hydrogen sulfide (Khan et al. 1990). Similarly, succinate oxidase activity also decreased in a dose-related fashion; although no affect was observed at the lowest dose. Cytochrome oxidase levels returned to normal by 24 hours postexposure in animals in the 200 ppm group, but not the 400 ppm group. Exposure at the two higher dose levels was also associated with complete abolition of the zymosan-induced stimulation of respiratory rates of pulmonary alveolar macrophages and there were significant decreases in the number of viable macrophages in lung lavage fluids at the highest dose (Khan et al. 1991).

[underlined: Agency Contact (Chemical Manager):] Selene Chou

## Hydrogen Sulfide Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hydrogen Sulfide
CAS Number: | 7783-06-4
Date: | November 2016
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 41
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [ ] mg/kg/day [x] ppm

[underlined: Reference]: Brenneman KA, James RA, Gross EA, et al. 2000. Olfactory neuron loss in adult male CD rats following subchronic inhalation exposure to hydrogen sulfide. Toxicol Pathol 28(2):326–333.

[underlined: Experimental design]: Groups of male Sprague Dawley rats (12/group) were exposed to 0, 10, 30, or 80 ppm hydrogen sulfide 6 hours/day, 7 days/week for 10 weeks. Parameters used to assess toxicity were limited to extensive histopathological examination of the nasal cavity (six transverse sections examined via light microscopy; transverse sections form a series of circumferential slices [labeled levels 1–6], which allow for a thorough evaluation of all major structures and mucosae of the nasal cavity).

[underlined: Effect noted in study and corresponding doses]: Nasal lesions occurred only in the olfactory mucosa in rats exposed to 30 or 80 ppm and consisted of multifocal, bilaterally symmetrical olfactory neuron loss and basal cell hyperplasia affecting the lining of the dorsal medial meatus and the dorsal and medial regions of the ethmoid recess. The severity of the olfactory lesions was scored as 1 mild, 2 moderate, or 3 severe. For the olfactory neuron loss, the mild, moderate, or severe severity scores corresponded to 26–50, 51–75, and 76–100%, respectively, reduction in the normal thickness of the olfactory neuron layer. For the basal cell hyperplasia, mild, moderate, or severe severity scores corresponded to 1–33, 34–67, or 68–100% of the normal thickness of the olfactory neuron cell layer replaced by basal cells. No olfactory lesions were observed in the controls or rats exposed to 10 ppm. At 30 ppm, olfactory neuron loss was observed at nasal levels 4 (11/12, severity 1.4) and 5 (9/12, severity 1.1) and basal cell hyperplasia was observed at nasal levels 4 (10/12, severity 1.8) and 5 (11/12, severity 1.3). At 80 ppm, olfactory neuron loss was observed at levels 3 (8/8, severity 2.4), 4 (12/12, severity 2.4), 5 (11/12, severity 1.5), and 6 (5/12, severity 1.2-incidence not statistically significant) and basal cell hyperplasia was observed at nasal levels 4 (12/12, severity 1.2), 5 (11/12, severity 1.3), and 6 (6/12, severity 1.0).

[underlined: Dose and end point used for MRL derivation]: Two approaches were considered for the derivation of the MRL: the traditional NOAEL/LOAEL approach and the benchmark dose (BMD) modeling approach. For the NOAEL/LOAEL approach, the MRL would be derived using the NOAEL of 10 ppm and LOAEL of 30 ppm for olfactory neuron loss and basal cell hyperplasia in the nasal olfactory epithelium. Two data sets were considered for BMD modeling: olfactory neuron loss and basal cell hyperplasia. Incidence data were reported for nasal section levels 3 (olfactory neuron loss only) through 6. Because the highest incidence of lesions in the 30 ppm group was found in level 4, these data were used for the BMD analyses. The incidence data are reported in Table A-1.

Table A-1 Incidence of Olfactory Neuron Loss ad Basal Cell Hyperplasia Observed in the Nasal Cavity of Male Rats Exposed to Hydrogen Sulfide for 10 Weeks

Concentration (ppm) | Incidence of olfactory neuron loss | Incidence of basal cell hyperplasia
0 | 0/12 | 0/12
10 | 0/12 | 0/12
30 | 11/12 | 10/12
80 | 12/12 | 12/12

Source: Brenneman et al. (2000)

The steepness of the dose-response curve for both lesion types (in particular the lack of intermediate response levels) precludes BMD modeling. Therefore, the NOAEL/LOAEL approach was selected for MRL derivation.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a minimal LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustment
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NOAEL_ADJ_ =10 ppm × 6 hours/24 hours × 7 days/7 days=2.5 ppm

The human equivalent concentration (HEC) was calculated using the following equation (EPA 1994b) for category 1 gases:

NOAEL_HEC_ = NOAEL_ADJ_ × RDGR_ET_

The regional gas dose ratio for the extrathoracic region (RGDR_ET_) of 0.184 was calculated using the following equation:

R G D R_E T_ = (((V_E_)/(S A_E T_))_r a t_)/(((V_E_)/(S A_E T_))_h u m a n_)

Where:

V_e_ is the minute volume and SA_ET_ is the surface area of the extrathoracic (ET) region of the respiratory tract.

- Minute volume (V_e_)
  - Human: 13.8 L/minute (EPA 1994b)
  - Rat: 0.190 L/minute; calculated using the following EPA equation:
    - ln(V_e_) = b_0_ + b_1_ln(BW)
- For rats, b_0_ equals −0.578 and b_1_ equals 0.821.
- Because limited body weight data were reported in the study, a reference body weight of 0.267 kg (EPA 1988) was used.
- EPA (1994b) rat and human respiratory surface area reference values:
  Extrathoracic 15.0 cm^2^ ( rat ) 200 cm^2^ ( human )
  NOAEL_[ HEC ]_ = NOAEL ( ADJ ) × RGDR = 2.5 ppm × 0.184 = 0.46 ppm

The dosimetric model typically used to estimate a concentration for humans that would be equivalent to the exposure concentration in rats takes into account species differences in the surface area of the upper respiratory tract and inhalation rates. However, the model does not take into consideration that a larger portion of the rat nasal cavity is lined with olfactory epithelium compared to humans (50% in rats compared to 10% in humans) and differences in air flow patterns. A computational fluid dynamics model of the rat nasal epithelium developed for hydrogen sulfide (Moulin et al. 2002; Schroeter et al. 2006a, 2006b) found strong correlations between the amount of hydrogen sulfide reaching the olfactory tissue and the severity of the lesions (Moulin et al. 2002) and between hydrogen sulfide flux (uptake by the olfactory tissue) and the lesion incidence (Schroeter et al. 2006a). Using data generated from hydrogen sulfide uptake simulations in the human nasal passage at exposure levels of 1–50 ppm, Schroeter et al. (2006a) derived regression equations for predicting the maximum and 99^th^ percentile flux values in the human olfactory region. However, data for the uptake simulations in the human nasal passage were based on a model reconstructed from MRI images from one male individual and did not take into account the potential individual variability in parameters. Schroeter et al. (2010) noted that there is considerable variation in nasal anatomy that could affect airflow patterns and dosimetry of inhaled gases. No actual measurements of gas delivery or absorption across nasal membranes were made; the simulations of a single computer model were used by Schroeter et al. (2006a) to predict HECs. When Schroeter et al. (2010) used the same male subject and a different computer model to simulate gas uptake, the average airflux was 14% lower than estimated by Schroeter et al. (2006a). Using MRI data for five adults and two children aged 7 and 8 years, Schroeter et al. (2010) concluded that normal variations in nasal anatomy, breathing rate, and air flow distribution were not likely to result in large variations in olfactory wall mass flux of hydrogen sulfide. However, the study did not address potential variations in a wide range of childhood ages (including newborns and infants) and the sensitivity of hydrogen sulfide dosimetry to variations in pharmacokinetic parameters. The investigators recommended additional research on the influence of interindividual variability in absorption and pharmacodynamics effects of hydrogen sulfide in the nasal tissues to olfactory dose. Based on these uncertainties in the computational fluid dynamics model to predict a HEC, ATSDR estimated the NOAEL_HEC_ using the dosimetric model, which adjusts for surface area and breathing rate differences between rats and humans. Additionally, the Schroeter et al. (2010) study does not support a reduction in the uncertainty factor for human variability.

[underlined: Was a conversion used from intermittent to continuous exposure?] The NOAEL was adjusted for intermittent exposure (6 hours/day, 7 days/week).

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Intermediate-duration animal studies support the identification of the respiratory tract and nervous system as sensitive targets. Studies conducted by CIIT (1983b, 1983c) did not find significant alterations in the nasal turbinates of Sprague-Dawley or Fischer-344 (F-344) rats exposed to 80 ppm or less hydrogen sulfide 6 hours/day, 5 days/week for 13 weeks. Inflammation of the squamous portion of the nasal mucosa was observed in mice exposed to 80 ppm hydrogen sulfide, 6 hours/day, 5 days/week for 13 weeks (CIIT 1983a); the NOAEL for this effect is 30 ppm. However, a re-examination of the histological specimens from this study (Dorman et al. 2004) revealed a statistically significant increase in the incidence of olfactory neuron loss in Sprague-Dawley rats, F-344 rats, and B6C3F1 mice exposed to 30 or 80 ppm; no lesions were observed at 10 ppm. In addition, increases in the incidence of bronchiolar epithelial hyperplasia and hypertrophy were observed in female Sprague-Dawley rats exposed to 30 or 80 ppm and male Sprague-Dawley and F-344 rats exposed to 80 ppm. The sensitivity of the olfactory epithelium has also been confirmed by acute-duration studies. Degeneration of the olfactory epithelium was observed in rats exposed to 400 ppm hydrogen sulfide for 4 hours (Lopez et al. 1988b), rats exposed to 200 ppm for 3 hours (Brenneman et al. 2002), and rats exposed to 80 ppm, 3 hours/day for 5 days (Brenneman et al. 2002). Additionally, data collected using a computational fluid dynamics model of the rat nasal epithelium (Moulin et al. 2002) suggest that the olfactory epithelium is more sensitive than the nasal respiratory epithelium despite the higher hydrogen sulfide flux (a surrogate for dose) to the regions lined with respiratory epithelium compared to regions lined with olfactory epithelium. Within the areas of the nose lined with olfactory epithelium, a high correlation between predicted hydrogen sulfide flux and the incidence of olfactory lesion was found.

The neurotoxicity of hydrogen sulfide in mature animals following intermediate-duration exposure has been assessed in studies examining brain weight, neurological function (posture, gait, tone of facial muscles, and pupillary reflexes), and histopathology; neurobehavioral performance has not been adequately assessed in longer duration studies. A 5% decrease in absolute brain weight was observed in Sprague-Dawley rats exposed to 80 ppm hydrogen sulfide 6 hours/day, 5 days/week for 13 weeks; no alterations were observed at 30 ppm (CIIT 1983c). No alterations in histopathology or neurological function were observed in these rats (CIIT 1983c) or in similarly exposed F-344 rats (CIIT 1983b) or B6C3F1 mice (CIIT 1983a). Neurodevelopmental toxicity studies have found some alterations that are suggestive of neurotoxicity. The suggestive findings in the offspring of rats exposed for 7 hours/day on gestational day 5 through postnatal day 21 include alterations in the architecture and growth characteristics of Purkinje cell dendritic fields at 20 ppm (Hannah and Roth 1991), decreases in norepinephrine and increases in serotonin in the frontal cortex at 20 ppm (Skrajny et al. 1992), and decreases in brain amino acid levels at 75 ppm (Hannah et al. 1989, 1990). However, no alterations in neurobehavioral performance (assessed via motor activity, passive avoidance, acoustic startle, and functional observation battery), delays in development (pinnae detachment, surface righting, incisor eruption, negative geotaxis, and eyelid detachment), or neuropathology were observed in the offspring of rats exposed 6 hours/day, 7 days/week for 2 weeks prior to mating, during mating, on gestation days 5–19, and on postnatal days 5–18 (Dorman et al. 2000). These data suggest that exposures of 20–80 ppm may result in subclinical alterations in neurochemistry and neuroanatomy.

[underlined: Agency Contact (Chemical Manager):] Selene Chou