# 8 REFERENCES

* Cited in text

*Abraham R, Barbolt TA, Rodgers JB. 1980. Inhibition by bran of the colonic cocarcinogenicity of bile salts in rats given dimethylhydrazine. Exp Mol Pathol 33:133–143.6252045
*ACGIH. 1994a. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1994 to 1995. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*ACGIH. 1994b. Draft criteria document on hydrazine. American Conference of Governmental Industrial Hygienists, Cincinnati, OH. May 19, 1994.
Akin FJ, Norred WP. 1978. Effects of short-term administration of maleic hydrazide or hydrazine on rat hepatic microsomal enzymes. Toxic01 Appl Pharmacol 43:287–292.
*Albanese R, Mirkova E, Gatehouse D, 1988. Species-specific response to the rodent carcinogens 1,2-dimethylhydrazine and 1,2-dibromo-3-chloropropane in rodent bone-marrow micronucleus assays. Mutagenesis 3:35–38.3282142
*Albano E, Tomasi A, Goria-Gatti L, 1989. Free radical activation of monomethyl and dimethyl hydrazines in isolated hepatocytes and liver microsomes. Free Radic Biol Med 6:3–8.2536341
Altmann GG, Lala PK. 1991. Control of 1,2-dimethylhydrazine-induced crypt hyperplasia by naturalkiller cells and its relevance to carcinogenics. In: Chemically induced cell proliferation: Implications for risk assessment. New York, NY: Wiley-Liss, Inc. 417–428.
*Alvarez de Laviada T, Romero FJ, Anton V, 1987. A simple microassay for the determination of hydrazine in biological samples. Effect of hydrazine and isoniazid on liver and brain glutathione. J Anal Toxicol 11:260–262.3431095
*Amlathe S, Gupta VK. 1988. Spectrophotometric determination of trace amounts of hydrazine in polluted water. Analyst 113:1481–1483.3239827
*Amoore JE, Hautala. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
Andrianopoulos G, Nelson R, Bombeck CT, 1987. The influence of physical activity in 1,2dimethylhydrazine induced colon carcinogenesis in the rat. Anticancer Res 7:849–852.3674772
*Andrianopoulos GD, Nelson RL, Barth BH, 1990. The effect of mild stress on DMH-induced colorectal cancer. Cancer Detect Prev 14:577–581.2224923
Anisimov VN, Azarova MA, Dmitrievskaya AY, 1976. Distribution of carcinogenic ^3^H-dialkylhydrazines in the neuroendocrine system and their antigonadotropic effect in rats. Byull Eksp Biol Med 82:1473–1475.
Anon. 1971. Further chapters in the hydrazine story. Food Cosmet Toxicol 9:724–728.4945586
*Anon. 1987. Gas microsensors under development. Govt Report 17. NTIS/NTN87.
Anon. 1973. Hydrazine. Food Cosmet Toxicol 11:897–901.4588674
Anon. 1968. Metabolic sites of hydrazine toxicity. Nutr Rev 256–58.5666198
Anselme K, Petite H, Herbage D. 1992. Inhibition of calcification in vivo by acyl azide cross-linking of a collagen-glycosaminoglycan sponge. Matrix 12:264–273.1435510
*Asano T, Pollard M. 1978. Strain susceptibility and resistance to 1,2-dimethylhydrazine-induced enteric tumors in germfree rats (40146). Society for Experimental Biology and Medicine 158:89–91.
*Ashby J, Mirkova E. 1987. Re-evaluation of 1,2-dimethylhydrazine in the mouse bone marrow micronucleus assay: Observation of a positive response. Environ Mutagen 9:177–181.3816715
ASTM. 1991a. Standard practice for measuring the concentration of toxic gases or vapors using detector tubes. In: 1991 Annual book of ASTM standards. Water and Environmental Technology. Philadelphia, PA: American Society for Testing and Materials. 11.03:318–322.
*ASTM. 1991b. Standard test method for hydrazine in water. In: 1991 Annual book of ASTM standards. Water and Environmental Technology. Philadelphia, PA: American Society for Testing and Materials. 11.01:450–452.
Atkinson R. 1981. A structure-activity relationship for the estimation of rate constants for the gasphase reactions of OH radicals with organic compounds. Int J Chem Kinetics 19:799–828.
*Atkinson R, Carter WP. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
Atkinson R, Carter WP, Aschmann SM, 1985. Atmospheric fates of organic chemicals: Prediction of ozone and hydroxyl radical reaction rates and mechanisms. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/3-85/063.
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Part V. Federal Register 54:37619–37633.
*ATSDR. 1990. Toxicological profile for 1,2-phenylhydrazine. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Centers for Disease Control.
*Augusto 0, Du Plessis LR, Weingrill CL. 1985. Spin-trapping of methyl radical in the oxidative metabolism of 1,2-dimethylhydrazine. Biochem Biophys Res Commun 2:853–858.
*Autrup H, Harris CC, Schwartz RD. 1980a. Metabolism of 1,2dimethylhydrazine by cultured human colon. Carcinogenesis 1:375–380.7273277
Autrup H, Schwartz RD, Essigmann JM, 1980b. Metabolism of aflatoxin B1, benzo[a]pyrene, and 1,2-dimethylhydrazine by cultured rat and human colon. Teratogenesis Carcinogen Mutagen 1:3–13.
*Back KC, Thomas AA. 1962. Pharmacology and toxicology of l,l-dimethylhydrazine (UDMH). AMRL-TDR-62-118.
Back KC, Carter VL, Thomas AA. 1978. Occupational hazards of missile operations with special regard to the hydrazine propellants. Aviat Space Environ Med 591–598.346014
*Back KC, Pinkerton MK, Cooper AB, 1963. Absorption, distribution, and excretion of 1,1-dimethylhydrazine (UDMH). Toxicol Appl Pharmacol 5:401–413.13965951
*Balansky R, Blagoeva P, Mircheva Z, 1992. Effect of metabolic inhibitors, methylxanthines, antioxidants, alkali metals, and corn oil on 1,Zdimethylhydrazine carcinogenicity in rats. Anticancer Res 12:933–940.1622151
Balo J. 1979. Role of hydrazine in carcinogenesis. Adv Cancer Res 30:151–164.388991
*Banerjee S, Pack EJ, Sikka H, 1984. Kinetics of oxidation of methylhydrazines in water, factors controlling the formation of l,l-dimethylnitrosamine. Chemosphere 4:549–559.
*Bansal BR, Rhoads JE, Bansal SC. 1978. Effects of diet on colon carcinogenesis and the immune system in rats treated with 1,2-dimethylhydrazine. Cancer Res 38:3293–3303.688219
*Barbolt TA, Abraham R. 1980. Dose-response, sex difference, and the effect of bran in dimethylhydrazine-induced intestinal tumorigenesis in rats. Toxico1 Appl Pharmacol 55:417–422.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barnes DS, Clapp NK, Scott DA, 1983. Effects of wheat, rice, corn, and soybean bran on 1,2-dimethylhydrazine-induced large bowel tumorigenesis in F344 rats. Nutr Cancer 5: 1–8.6314283
Barrow BJ, O’Riordan MA, Stellato TA, 1990. Enzyme-altered foci in colons of carcinogentreated rats. Cancer Res 50:1911–1916.2137723
Barrow LR, Shank RC, Magee PN. 1983. S-Adenosylmethionine metabolism and DNA methylation in hydrazine-treated rats. Carcinogenesis 8:953–957.
*Barsoum GH, Thompson J, Neoptolemos JP, 1992. Dietary calcium does not reduce experimental colorectal carcinogenesis after small bowel resection despite reducing cellular proliferation. Gut 33:1515–1520.1452077
*Bauer RM, Tarr MJ, Olsen RG. 1990. Effect of 1,1-dimethylhydrazine on lymphoproliferation and interleukin 2 immunoregulatory function. Arch Environ Contam Toxicol 19:148–153.2331149
*Becker RA, Barrows LR, Shank RC. 1981. Methylation of liver DNA guanine in hydrazine hepatotoxicity: dose-response and kinetic characteristics of 7-methylguanine and O^6^-methylguanine formation and persistence in rats. Carcinogenesis 11: 1181– 1188.
*Bedell MA, Lewis JG, Billings KC, 1982. Cell specificity in hepatocarcinogenesis: Preferential accumulation of 06-methylguanine in target cell DNA during continuous exposure of rats to 1,2 dimethylhydrazine. Cancer Res 42:3079–3083.7093953
*Belleli A, Shany S, Levy J, 1992. A protective role of 1,25dihydroxyvitamin D, in chemically induced rat colon carcinogenesis. Carcinogenesis 12:2293–2298.
Beniashvili DS. 1989. Induction of renal tumors in cynomolgus monkeys (Mucaca fascicularis) by prenatal exposure to 1,2-dimethylhydrazine. J Natl Cancer Inst 17:1325–1327.
Beniashvili DS, Turusov VS, Krutovskikh, 1992. Tumor induction in monkeys after administration of dimethylhydrazine. Jpn J Cancer Res 83:584–587.1644662
*Beranek DT, Weis CC, Evans FE, 1983. Identification of N^5^-methyl-N^5^-formy1-2,5,6-triamino-4-hydroxypyrimidine as a major adduct in rat liver DNA and after treatment with the carcinogens, n,n-dimethylnitrosamine or 1,2-dimethylhydrazine. Biochem Biophys Res Commun 2:625–631.
Besada A. Analytical use of copper(neocuproine in the spectrophotometric determination of hydrazines. Analytical Letters 21: 1917–1925.
*Bhide SV, D’Souza RA, Sawai MM, 1976. Lung tumor incidence in mice treated with hydrazine sulphate. Int J Cancer 18:530–535.977192
*Biancifiori C. 1970. Hepatomas in CBA/Cb/Se mice and liver lesions in golden hamsters induced by hydrazine sulfate. J Natl Cancer Inst 44:943–953.11515062
*Biancifiori C, Ribacchi R. 1962. Pulmonary tumours in mice induced by oral isoniazid and its metabolites. Nature 194:488–489.13868911
*Biancifiori C, Bucciarelli E, Clayson DB, 1964. Induction of hepatomas in CBA/Cb/Se mice in hydrazine sulphate and the lack of effect of croton oil on tumour induction in BALB/c/Cb/Se mice. Br J Cancer 543–550.14219548
*Biancifiori C, Giomelli-Santilli FE, Milia U, 1966. Pulmonary tumours in rats induced by oral hydrazine sulphate. Nature 212:414–415.
Bilbin M, Tudek B, Czeczot H. 1992. Induction of aberrant crypts in the colons of rats-by alkylating agents. Acta Biochimica Polonica 39: 113–117.1441823
Bird RP, Pretlow TP. 1992. Letter to the editor - Correspondence re: Cademi et al., effect of dietary carbohydrates on the growth of dysplastic crypt foci in the colon of rats treated with 1,2-dimethylhydrazine. Cancer Res 52:4291–4292.1638542
*Blair IA, Tinoco RM, Brodie MJ, 1985. Plasma hydrazine concentrations in man after isoniazid and hydralazine administration. Human Toxicol 4:195–202.
*Bodansky M. 1923. The action of hydrazine and some of its derivatives in producing liver injury as measured by the effect of levulose tolerance. J Biol Chem 3:799–811.
*Boffa LC, Bolognesi C. 1986. In vitro DNA and nuclear proteins alkylation by 1,2-dimethylhydrazine. Mutat Res 173:157–162.3951469
*Bolognesi C, Mariani MR, Boffa LC. 1988. Target tissue DNA damage in inbred mouse strains with different susceptibility to the colon carcinogen 1,2-dimethylhydrazine. Carcinogenesis 8: 1347–1350.
*Bosan WS, Lambert CE, Shank RC. 1986. The role of formaldehyde in hydrazine-induced methylation of liver DNA guanine. Carcinogenesis 3:413–418.
*Bosan WS, Shank RC, MacEwen JD, 1987. Methylation of DNA guanine during the course of induction of liver cancer in hamsters by hydrazine or dimethylnitrosamine. Carcinogenesis 3:439–444.
Brasitus TA, Dudeja PK, Dahlya R. 1986. Premalignant alterations in the lipid composition and fluidity of colonic brush border membranes of rats administered 1,2-dimethylhydrazine. J Clin Invest 77:837–840.
*Braun BA, Zirrolli JA. 1983. Environmental fate of hydrazine fuels in aqueous and soil environments. Air Force Engineering and Services Center, Engineering and Services Laboratory, Tyndall Air Force Base, FL. ESL-TR-82-45.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company. 5:93–94, 10:103-104.
Brown DM, McNaught AD, Schell P. 1966. The chemical basis of hydrazine mutagenesis. Biochem Biophys Res Commun 6:967–971.
*Brubaker KL. 1988. The chemistry of the hypochlorite neutralization of hydrazine fuels. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 192–201.
*Brusick D, Matheson D. 1976. Mutagenic evaluation of l,l-dimethylhydrazine, methylhydrazine, and N-phenyl-X-naphthylamine. AMRL-TR-76-125. 108-139.
*Budavari S, O’Neil MJ, Smith A, , eds. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck and Co., Inc., 512, 754.
Cabral JR. 1985. Hydrazine: laboratory evidence. In: International Agency for Research on Cancer. Lyon, France: IARC Scientific Publications No. 65.
*Cademi G, Bianchini F, Marcina A, 1991. Effects of dietary carbohydrates on the growth of dysplastic crypt foci in the colon of rats treated with 1,2 dimethylhydrazine. Cancer Res 51:3721–3725.2065328
*Calvert RJ, Klurfeld DM, Subramaniam S, 1987. Reduction of colonic carcinogenesis by wheat bran independent of fecal bile acid concentration. J Natl Cancer Inst 4:875–880.
Carr LA, Basham JK, York BE, 1992. Inhibition of uptake of 1-methyl-4-phenylpyridinium ion and dopamine in striatal synaptosomes by tobacco smoke components. Eur J Pharmacol 215:285–287.1396992
CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDUATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
Chen X, Wan M, Chen Y. 1991. Treatment of onychomycosis with hydrazine hydrate. Mycoses 34:107–109.1840157
Chester JR, Gaissert HA, Ross JS, 1989. Colonic cancer induced by 1,2-dimethylhydrazine: Promotion by experimental colitis. Br J Cancer 59:704–705.2736203
Chevrier JP. 1975. A study of the toxicity of 1,1-dimethylhydrazine in animals: IV. A contribution to treatment. Eur J Toxicol Environ Hyg 8:32–37.
*Chlebowski RT, Herber D, Richardson B, 1984. Influence of hydrazine sulfate on abnormal carbohydrate metabolism in cancer patients with weight loss. Cancer Res 44:857–861.6692384
*Colacchio TA, Memoli VA, Hildebrandt L. 1989. Antioxidants vs carotenoids. Arch Surg 124:217–221.2492799
Columbano A, Rajalakshmi S, Sarma DS. 1980. Requirement of cell proliferation for the induction of presumptive preneoplastic lesions in rat liver by a single dose of 1,2-dimethylhydrazine. Chem Biol Interact 32:347–351.6107180
Colvin LB. 1969. Metabolic fate of hydrazines and hydrazides. J Pharm Sci 12:1433–1443.
*Comstock CC, Lawson LH, Greene EA, 1954. Inhalation toxicity of hydrazine vapor. Arch Ind Hyg 10:476–790.
*Cook MG, McNamara P. 1980. Effect of dietary vitamin E on dimethylhydrazine-induced colonic tumors in mice. Cancer Res 40: 1329–1331.7357560
*Cook LR, Glenn RE, Podolak GE. 1979. Monitoring and analysis of personnel exposures to hydrazines at a rocket propellant plant. Am Ind Hyg Assoc J 40:69–73.484453
*Coomes MW, Prough RA. 1983. The mitochondrial metabolism of 1,2-disubstituted hydrazines, procarbazine and 1,2-dimethylhyrazine. Drug Metab Dispos 6:550–555.
*Comish HH. 1969. The role of vitamin B_6_ in the toxicity of hydrazines. Ann N Y Acad Sci 136–145.5262010
*Comish HH, Hartung R. 1969. The subacute toxicity of l,l-dimethylhydrazine. Toxicol Appl Pharmacol 15:62–68.5798733
*Couch DB, Gingerich JD, Stuart E, 1986. Induction of sister chromatid exchanges in murine colonic tissue. Environ Mutagen 8:579–587.3732197
*Craven PA, DeRubertis FR. 1992. Effects of aspirin on 1,2-dimethylhydrazine-induced colonic carcinogenesis. Carcinogenesis 4:541–546.
*Craven PA, Neidig M, DeRubertis FR. 1985. Fatty acid stimulated N-demethylation of 1,2-dimethylhydrazine and tetramethylhydrazine by rat colonic mucosa. Biochem Pharmacol 17:3101–3106.
*CRISP. 1993. Computer Retrieval of Information on Scientific Projects. National Institutes of Health, Division of Research Grants, Bethesda, MD. March 11, 1993.
*Cruse JP, Lewin MR, Clark CG. 1982. Dietary cholesterol deprivation improves survival and reduces incidence of metastatic colon cancer in dimethylhydrazine-pretreated rats. Gut 23:594–599.7084805
*D’Souza RA, Bhide SV. 1975. Metabolic studies on the effect of hydrazine sulphate & isoniazid on newborn & adult Swiss mice. Indian J Exp Biol 13:542–544.1218922
*Decaens C, Gautier R, Daher N, 1989. Induction of rat intestinal carcinogenesis with single doses, low and high repeated doses of 1,2-dimethylhydrazine. Carcinogenesis 1:69–72.
*De Flora S, Mugnoli A. 1981. Relationships between mutagenic potency, reversion mechanism and metabolic behaviour within a class of chemicals (hydrazine derivatives). Cancer Lett 12:279–285.7306933
*Dhennin C, Vesin L, Feauveaux J. 1988. Burns and the toxic effects of a derivative of hydrazine. Burns 2:130–134.
*Dixon MF, Cowen DM, Cooper H. 1975. Chronic hepatotoxicity and intestinal bleeding in 1,2-dimethylhydrazine carcinogenesis in rats and mice. Biomedicine 23:247–252.1085170
*Dominguez AM, Amenta JS, Hill CS, 1962. Morphologic and biochemical alteration in the kidney of the hydrazine-treated rat. Aerosp Med 1094– 1097.13887111
*Dost FN, Reed DJ, Wang CH. 1966. The metabolic fate of monomethylhydrazine and unsymmetrical dimethylhydrazine. Biochem Pharmacol 15: 1325–1332.
*Druckrey H. 1970. Production of colonic carcinomas by 1,2-dialkylhydrazines and azoxyalkanes. In: Burdette WJ, ed. Carcinoma of the colon and antecedent epithelium. Springfield, IL: Charles C. Thomas, 267–279.
Dudeja PK, Brasitus TA. 1990. 1,2-Dimethylhydrazine-induced alterations in lipid peroxidation in preneoplastic and neoplastic colonic tissues. Biochimica Biophysics Acta 1046:267–270.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 35, 82, 1391.
*EPA. 1980. U.S. Environmental Protection Agency. Federal Register 45:33132–33133.
*EPA. 1984a. Health and environmental effects profile for 1,1-dimethylhydrazine. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/X-84-134.
*EPA. 1984b. Health and environmental effects profile for hydrazine and hydrazine sulfate. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/X-84/332.
*EPA. 1987. U.S. Environmental Protection Agency. Part II. Federal Register 52:13378–13379, 13399-13400.
EPA. 1988a. Evaluation of the potential carcinogenicity of hydrazine. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment Group. OHEA-C-073-116.
*EPA. 1988b. U.S. Environmental Protection Agency. Part II. Federal Register 53:4500–4505.
*EPA. 1989. U.S. Environmental Protection Agency. Part V. Federal Register 54:33459, 33418–33419.
*EPA. 1990a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPN600/8-90/066A.
*EPA. 1990b. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22537, 22593, 22712.
EPA. 1990c. Method 8270B. Semivolatile organic compounds by gas chromatography/mass spectrometry (GCYMS): capillary column technique. Draft. Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 1–43.
*EPA. 1990d. Method 8250A. Semivolatile organic compounds by gas chromatography/mass spectrometry (GS/MS): packed column technique. Draft. Test methods for evaluating solid waste. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, 1–32.
*EPA. 1990e. U.S. Environmental Protection Agency. Part IV. Federal Register 55:18496–18513.
*EPA. 1991a. U.S. Environmental Protection Agency. Part II. Federal Register 55:3864–3870, 3890, 3910.
*EPA. 1991b. U.S. Environmental Protection Agency. Part III. Federal Register 56:7134–7135, 7234.
*EPA. 1991c. U.S. Environmental Protection Agency. Part IV. Federal Register 56:27339–27342, 27354, 27364-27365.
*EPA. 1991d. U.S. Environmental Protection Agency. Part IX. Federal Register 56:41212–41217, 41251-41253.
*EPA. 1992a. U.S. Environmental Protection Agency. Part II. Federal Register 57:62608–62619, 62690-62693.
*EPA. 1992b. U.S. Environmental Protection Agency. Part II. Federal Register 57:37194–37197, 37249, 37259.
*EPA. 1992c. U.S. Environmental Protection Agency. Part III. Federal Register 57:46436–46445.
*EPA. 1992d. U.S. Environmental Protection Agency. Part VIII. Federal Register 57:41020–41046.
*EPA. 1993. U.S. Environmental Protection Agency. Part III. Federal Register 58:5102–5125.
*Erikson JM, Prough RA. 1986. Oxidative metabolism of some hydrazine derivatives by rat liver and lung tissue fractions. J Biochem Toxicol 1:41–52.3271870
*Ernst H, Rittinghausen S, Wahnschaffe U, 1987. Induction of malignant peripheral nerve sheath tumors in European hamsters with 1,1-dimethylhydrazine (UDMH). Cancer Lett 35:303–311.3594425
Estrada-Flores E, Mendoza CY. 1990. Histology of rat placentas treated with methylhydrazine Ro 4-6467. Bol Estud Med Biol 38:3–4.2291778
Evans DM. 1959. Two cases of hydrazine hydrate dermatitis without systemic intoxication. Br J Ind Med 16:126–127.13651555
Evans JT, Hauschka TS, Mittleman A. 1974. Differential susceptibility of four mouse strains to induction of multiple large-bowel neoplasms by 1,2-dimethylhydrazine. J Natl Cancer Inst 3:999–1000.
Fairchild MD, Sterman MB. 1965a. Behavioral and neurophysiological studies of UMDH in the cat. AMRL-TDR-64-72.
Fairchild MD, Sterman MB. 1965b. l,l-Dimethylhydrazine effects on central excitatory and inhibitory mechanisms in cats. AMRL-TR-64-142.
*Fajen JM, McCammon CS. 1988. Exposure characterization study of workers exposed to hydrazines. Cincinnati, OH: National Institute for Occupational Safety and Health. 261–295.
Fedorov SN, Balansky RM, Novikov LB, 1991. Properties of mitochondrial DNA from liver tissue of rats treated with 1,2-dimethylhydrazine. Vapor Med Khim 37:82–84.
*Feinberg A, Zedeck MS. 1980. Production of a highly reactive alkylating agent from the organospecific carcinogen methylazoxymethanol by alcohol dehydrogenase. Cancer Res 40:4446–4450.7002292
*Fiala ES. 1977. Investigations into the metabolism and mode of action of the colon carcinogens 1,2-dimethylhydrazine and azoxymethane. Cancer 40:2436–2445.200341
*Fiala ES, Kulakis C. 1981. Separation of hydrazine, monomethylhydrazine, 1,1-dimethylhydrazine and 1,2-dimethylhydrazine by high performance liquid chromatography with electrochemical detection. J Chromatogr 214:229–233.
*Fiala ES, Kulakis C, Bobotas G, 1976. Detection and estimation of azomethane in expired air of 1,2-dimethylhydrazine-treated rats. J Natl Cancer Inst 6: 1271– 1273.
*Fiala ES, Bobotas G, Lukakis C, 1977. Effects of disulfiram and related compounds on the metabolism in vivo of the colon carcinogen, 1,2-dimethylhydrazine. Biochem Pharmacol 26:1763–1768.907715
*Floyd WN. 1980. The importance of ammonia in the metabolic effects of hydrazine. Aviat Space Environ Med 899–901.7417161
*Fortney SR. 1967. Effect of hydrazine on carbohydrate metabolism in vivo and in vitro. Aerospace Med 727–73 1.6050398
*Frazier DE, Tarr MJ, Olsen RG. 1991. The in vitro and in vivo effects of 1,1-dimethylhydrazine (UDMH) on murine lymphocyte subsets and IA antigen expression. Immunopharmacol Immunotoxicol 13:25–46.1837557
*Frazier DE, Tarr MJ, Olsen RG. 1992. Evaluation of murine lymphocyte membrane potential, intracellular free calcium, and interleukin-2 receptor expression upon exposure to 1,1 -dimethylhydrazine. Toxicol Lett 61:27–37.1609436
*Frierson WB. 1965. Use of pyridoxine HCL in acute hydrazine and UDMH intoxication. Ind Med Surgery 650–65 1.
*Frost J, Hjorth N. 1959. Contact dermatitis from hydrazine hydrochloride in soldering flux, cross sensitization to apresoline and isoniazid. Acta Dermato-Venerologica 39:82–86.
*Fujii K, Komano H. 1989. Tumor induction in mice administered neonatally with 1,2dimethylhydrazine. Sci Rep Res Inst Tohoku Univ [Med] 36:46–50.
*Furst A, Gustavson WR. 1967. A comparison of alkylhydrazines and their B_6_-hydrazones as convulsant agents (31693). P S E B M 124:172–175.
*Furst A, Gustavson WR, deRopp RS. 1969. Biochemical pharmacology of hydrazines toxicity. AMRL-TR-68– 132.
*Geake CL, Barth ML, Cornish HH. 1966. Vitamin B, and the toxicity of l,l-dimethylhydrazine. Biochem Pharmacol 15:1614–1618.5971815
Gent WL, Seifart HI, Parkin DP, 1992. Factors in hydrazine formation from isoniazid by paediatric and adult tuberculosis patients Eur J Clin Pharmacol 43: 131–136.1425868
*Gershanovich ML, Danova LA, Ivin BA, 1981. Results of clinical study on antitumor action of hydrazine sulfate. Nutr Cancer 3:7–12.7050922
*Gershanovich ML, Danova LA, Kondratyev VB, 1976. Clinical data on the antitumor activity of hydrazine sulfate. Cancer Treat Rep 7:933–935.
Gershbein LL, Rao KC. 1992. Action of hydrazine drugs in tumor-free and 1,2-dimethylhydrazinetreated male rats. Oncology Res 4:121–127.
*Glassroth JL, White MC, Snider DE Jr. 1977. An assessment of the possible association of isoniazid with human cancer deaths. Am Rev Resp Dis 116:1065–1074.337865
*Glauert HP, Bennink MR. 1983. Metabolism of 1,2dimethylhydrazine by cultured rat colon epithelial cells. Nutr Cancer 5:78–86.6647041
*Glauert HP, Weeks JA. 1989. Dose- and time-response of colon carcinogenesis in Fischer-344 rats after a single dose of 1,2-dimethylhydrazine. Toxicol Lett 48283–287.
*Godoy HM, Gomez MI, Castro JA. 1983. Metabolism and activation of l,l-dimethylhydrazine and methylhydrazine, two products of nitrosodimethylamine reductive biotransformation, in rats. J Natl Cancer Inst 5:1047–1051.
*Gaff WR, Allison T, Matsumiya Y. 1967. Effects of 1,l-dimethylhydrazine (UDMH) on evoked cerebral neuroelectric responses. AMRL-TR-67-67.
*Gaff WR, Allison T, Matsumiya Y. 1970. Effects of convulsive doses of l,l-dimethylhydrazine on somatic evoked responses in the cat. Exp Neurol 27:213–216.5424585
Goldfrank LR, Flomenbaum NE, Lewin NA, 1990. Goldfrank’s toxicologic emergencies. Norwalk, Connecticut: Appleton & Lange 4th Ed. 206.
Goria-Gatti I, Iannone A, Tomasi A, 1992. In vitro and in vivo evidence for the formation of methyl radical from procarbazine: A spin-trapping study. Carcinogenesis 5:799–805.
*Guengerich FP, Kim DH, Iwasaki M. 1991. Role of human cytochrome P-450 BE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4:168–179.1664256
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1286–1287.
*Hagihara PF, Yoneda K, Sachatello CR, 1980. Colonic tumorigenesis in rats with 1,2-dimethylhydrazine. Dis Colon Rectum 3:137–140.
Hamilton SR, Gordon GB, Floyd J, 1991. Evaluation of dietary dehydroepiandroesterone for chemoprotection against tumorigenesis in premalignant colonic epithelium of male F344 rats. Cancer Res 5 1:476–480.
Hanson D. 1993. OSHA won’t appeal toxics exposure survey. C&EN March 29, 1993. 5.
*Harati Y, Niakan E. 1986. Hydrazine toxicity, pyridoxine therapy, and peripheral neuropathy. Ann Intern Med 5:728–729.
*Harbach PR, Swenberg JA. 1981. Effects of selenium on 1,2-dimethylhydrazine metabolism and DNA alkylation. Carcinogenesis 7:575–580.
*Harris CC, Autrup H, Stoner GD, 1977. Metabolism of dimethylnitrosamine and 1,2-dimethylhydrazine in cultured human bronchi. Cancer Res 37:2309–23 11.861952
*Harris GW, Atkinson R, Pitts JN. 1979. Kinetics of the reactions of the OH radical with hydrazine and methylhydrazine. J Phys Chem 83:2557–2559.
*Haun CC. 1977. Canine hepatotoxic response to the inhalation of 1,1-dimethylhydrazine (UDMH) and 1,1-dimethylhydrazine with dimethylnitrosamine (DMNA). AMRL-TR-76-125.
*Haun CC, Kinkead ER. 1973. Chronic inhalation toxicity of hydrazine. Springfield, VA: U.S. Department of Commerce. AMRL-TR-73-125.
*Haun CC, Kinkead ER, Vemot EH, 1984. Chronic inhalation toxicity of unsymmetrical dimethylhydrazine: Oncogenic effects. AFAMRL-TR-85-020.
*Hawks A, Magee PN. 1974. The alkylation of nucleic acids of rat and mouse in vivo by the carcinogen 1,2-dimethylhydrazine. Br J Cancer 30:440–447.4469196
Hawks A, Hicks RM, Holsman JW, 1974. Morphological and biochemical effects of 1,2-dimethylhydrazine and 1-methylhydrazine in rats and mice. Br J Cancer 30:429–439.4469195
*HazDat. 1995. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. June, 1993.
*HEAST. 1992. Health effects assessment summary tables. Annual FY 1992. Washington, DC: U.S. Environmental Protection Agency, NTIS No. PB92-921199.
*Heitman DW, Hardman WE, Cameron IL. 1992. Dietary supplementation with pectin and guar gum on 1,2-dimethylhydrazine-induced colon carcinogenesis in rats. Carcinogenesis 5:815–818.
Hemminki K, Vainio H. 1984. Human exposure to potentially carcinogenic compounds. In: Monitoring human exposure to carcinogenic and mutagenic agents. Proceedings of a joint symposium held in Espoo, Finland, December 12-15, 1983. International Agency for Research on Cancer, Lyon, France. IARC Scientific Publications No. 59.
Hietanen E, Kobliakov V, Bartsch H. 1986. Role of different cytochrome P-450 isozymes in the demethylation of various substrates. Gen Pharmacol 5:565–568.
Hines RN, Prough RA. 1980. The characterization of an inhibitory complex formed with cytochrome P-450 and a metabolite of 1,1-disubstituted hydrazines. J Pharmacol Exp Ther 21480–86.
Holt A, Sharman DF, Callingham BA. 1992. Effects in vitro of procarbazine metabolites on some amine oxidase activities in the rat. J Pharm Pharmacol 44:494–499.1359074
*Holtzclaw JR, Rose SL, Wyatt JR. 1984. Simultaneous determination of hydrazine, methylhydrazine, and l,l-dimethylhydrazine in air by derivatization/gas chromatography. Anal Chem 56:2952–2956.6524668
*Hovding G. 1967. Occupational dermatitis from hydrazine hydrate used in boiler protection. Acta Derm Venereol 47:293–297.4168785
Howard PH, Boethling RS, Jarvis WF, eds. 1991. Handbook of environmental degradation rates. New York, NY: Lewis Publishers.
*HSDB. 1995. Hazardous substances data bank 1. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*IARC. 1974. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 4. Some aromatic amines, hydrazine and related substances, N-nitroso compounds and miscellaneous alkylating agents. Lyon, France: International Agency for Research on Cancer, 127–15 1.
*IARC. 1994. IARC monographs on the evaluation of carcinogenic risk to humans. List of IARC evaluations. World Health Organization, International Agency for Research on Cancer, Lyon, France, 12 – 13 .
Ijiri K. 1989. Apoptosis (cell death) induced in mouse bowel by 1,2-dimethylhydrazine methylazoxymethanol acetate, and y-rays. Cancer Res 49:6342–6346.2804979
Imaida K, Hirose M, Yamaguchi S, 1990. Effects of naturally occurring antioxidants on combined 1,2-dimethylhydrazine- and 1-methyl-1-nitrosourea-initiated carcinogenesis in F344 male rats. Cancer Lett 5553–59.
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. February, 1995.
*Ito K, Yamamoto K, Kawanishi S. 1992. Manganese-mediated oxidative damage of cellular and isolated DNA by isoniazid and related hydrazines: Non-Fenton-type hydroxyl radical formation. Biochemistry 31:11606–11613.1332766
*Izumi K, Otsuka H, Furuya K, 1979. Carcinogenicity of 1,2-dimethylhydrazine dihydrochloride in BALBlc mice. Virchows Arch [Pathol Anat] 384:263–267.
Jacobs MM. 1990. Potassium inhibition of DMH-induced small intestinal tumors in rats. Nutr Cancer 14:95–101.2216902
*Jacobson KH, Clem JH, Wheelwright HJ, 1955. The acute toxicity of the vapors of some methylated hydrazine derivatives. AMA Arch Ind Health 12:609–616.13268078
*Jacoby RF, Lior X, Teng BB, 1991. Mutations in the K-ras oncogene induced by 1,2-dimethylhydrazine in preneoplastic and neoplastic rat colonic mucosa. J Clin Invest 87:624–630.1991846
James JT, Autrup H. 1983. Methylated DNA adducts in the large intestine of ICR/Ha and C57BL/Ha mice given 1,2-dimethylhydrazine. J Natl Cancer Inst 70:541–546.6572742
*James JT, Shamsuddin AM, Trump BF. 1983. Comparative study of the morphologic, histochemical, and proliferative changes induced in the large intestine of ICR/Ha and C57BL/Ha mice by 1,2-dimethylhydrazine. J Natl Cancer Inst 71:955–964.6580497
Jaskiewicz K, Rossouw JE, Kritchevsky D, 1986. The influence of diet and dimethylhydrazine on the small and large intestine of vet-vet monkeys. Br J Exp Pathol 67:361–369.2872910
*Jody BJ, Kosenka P, Lewis S., 1988. Ozonation of hydrazines and their associated impurities. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 202–215.
Juchau MR, Horita A. 1972. Metabolism of hydrazine derivatives of pharmacologic interest. Drug Metab 1:71–100.
Juhasz J, Balo J, Szende B. 1966. Tumour-inducing effect of hydrazine in mice. Nature 5043:1377.
Kakehi K, Suzuki S, Honda S, 1991. Precolumn labeling of reducing carbohydrates with 1-(p-methoxy)phenyl-3-methyl-5-pyrazolone: Analysis of neutral and sialic acid-containing oligosaccharides found in glycoproteins. Anal Biochem 199:256–268.1725951
Kalyanaraman B, Sinha BK. 1985. Free radical-mediated activation of hydrazine derivatives. Environ Health Perspect 64:179–184.3007088
*Kane DA, Williamson KJ. 1983. Bacterial toxicity and metabolism of hydrazine fuels. Arch Environ Contam Toxicol 12:447–453.
*Kaneo Y, Iguchi S, Kubo H, 1984. Tissue distribution of hydrazine and its metabolites in rats, J Pharmacobiodyn 7:556–562.6512678
*Kang JO. 1994. Methylated purine bases in hepatic and colonic RNA of rats treated with 1,2-dimethylhydrazine. Biochem Med Metab Biol 53:52–57.7531989
*Kang JO, Slater G, Aufses AH, 1988. Production of ethane by rats treated with the colon carcinogen, 1,2-dimethylhydrazine. Biochem Pharmacol 15:2967–2971.
*Karkare MR, Clark TD, Glauert HP. 1991. Effect of dietary calcium on colon carcinogenesis induced by a single injection of 1,2-dimethylhydrazine in rats. Am Instit Nutr 568577.
*Kawanishi S, Yamamoto K. 1991. Mechanism of site-specific DNA damage induced by methylhydrazines in the presence of copper(II) or manganese(III). Biochemistry 30:3069–3075.1848785
Keller WC. 1988. Toxicity assessment of hydrazine fuels. Aerosp Med A100-A106.
*Keller WC, Olson CT, Back KC, 1984. Teratogenic assessment of three methylated hydrazine derivatives in the rat. J Toxic01 Environ Health 13:125–131.
Kelly MG, O’Gara RW, Yancey ST, 1968. Comparative carcinogenicity of N-isopropyl-a-(2-methylhydrazino)-p-toluamide * HCI (procarbazine hydrochloride), its degradation products, other hydrazines, and isonicotinic acid hydrazide. J Nat Cancer Inst 42:337–342.
*Kerklaan P, Bouter S, Mohn G. 1983. Activation of nitrosamines and other carcinogens by mouseliver S9, mouse hepatocytes and in the host-mediated assay produces different mutagenic-responses in Salmonella TA1535. Mutat Res 110:9–22.6865998
Kimball RF. 1977. The mutagenicity of hydrazine and some of its derivatives. Mutat Res 39:111–126.405576
*Kirklin JK, Watson M, Bondoc CC, 1976. Treatment of hydrazine-induced coma with pyridoxine, New England J Med 938–939.815813
*Koval TM. 1984. Selective inhibition of replicative and repair DNA synthesis in mouse colon following administration of 1,2-dimethylhydrazine. J Toxicol Environ Health 12: 117–124.
Kumagai H, Kawaura A, Furuya K, 1982. Perianal lesions of BALB/c mice induced by 1,2-dimethylhydrazine dihydrochloride and methylazoxymethanol-acetate: Their classification and histogenesis. Gann 73:358–364.7129000
*Kumari HL, Kamat PL, D’Ambrosio SM, 1985. A comparative study of dimethylhydrazine regioisomers and the methylazoxymethanol metabolite of 1,1- and 1,2-dimethylhydrazine in relation to transformation in human fibroblasts. Cancer Lett 29:265–275.4075295
*Lambert CE, Shank RC. 1988. Role of formaldehyde hydrazone and catalase in hydrazine-induced methylation of DNA guanine. Carcinogenesis 1:65–70.
*Latendresse JR, Marit GB, Vemot EH, 1995. Oncogenic potential of inhaled hydrazine in the nose of rats and hamsters after 1 or 10 1-hr exposures. Fund Appl Toxicol 27:33–48.
*Leakakos T, Shank RC. 1994. Hydrazine genotoxicity in the neonatal rat. Toxicol Appl Pharmacol 126:295–300.8209382
*Leasure CS, Miller EL. 1988. Measurement of hydrazine contamination in soils. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 276-285.
*Lee SH, Aleyassine H. 1970. Hydrazine toxicity in pregnant rats. Arch Environ Health 21:615–619.5475425
*Levi BZ, Kuhn JC, Ulitzur S. 1986. Determination of the activity of 16 hydrazine derivatives in the bioluminescence test for genotoxic agents. Mutat Res 173:233–237.3513001
*Liu YY, Schmeltz I, Hoffman D. 1974. Chemical studies on tobacco smoke. Quantitative analysis of hydrazine in tobacco and cigarette smoke. Anal Chem 46:885–889.4840592
*Llewellyn BM, Keller WC, Olson CT. 1986. Urinary metabolites of hydrazine in male Fischer 344 rats following inhalation or intravenous exposure. AAMRL-TR-86-025.
*Llor X, Jacoby RF, Teng BB, 1991. K-ras mutations in 1,2-dimethylhydrazine-induced colonic tumors: Effects of supplemental dietary calcium and vitamin D deficiency. Cancer Res 51:4305–4309.1868452
*Locniskar M, Nauss KM, Newbeme PM. 1986. Effect of colon tumor development and dietary fat on the immune system of rats treated with DMH. Nutr Cancer 8:73–84.3703686
Lumsden AJ, Codde JP, Gray BN, 1992. Prevention of myelosuppression does not.improve the therapeutic efficacy of chemo-immunotherapy. Anticancer Res 12:1725–1730.1444239
Lunn 6, Sansone EB, Andrews AW. 1991. Aerial oxidation of hydrazines to nitrosamines. Environ Mel Mutagen 17:59–62.
Lunn G, Sansone EB, Keefer LK. 1983. Reductive destruction of hydrazines as an approach to hazard control. Environ Sci Technol 17:240–243.22304642
MacEwen JD, Vemot EH, Haun CC, 1981. Chronic inhalation toxicity of hydrazine: Oncogenic effects. AFAMRL-TR-81-56.
Mackay D, Shiu WY, Bobra A, 1982. Volatilization of organic pollutants from water. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development, EPA 600/3-82-019.
*MacNaughton MG, Stauffer TB, Stone DA. 1981. Environmental chemistry and management of hydrazine. Aviation Space Environ Med 149–153.
*MacRae WD, Stich HF. 1979. Induction of sister-chromatid exchanges in Chinese hamster ovary cells by thiol and hydrazine compounds. Mutat Res 68:351–365.522883
Madamas P, Dube M, Rola-Pleszczynski M, 1992. An animal model of Kaposi’s sarcoma. II. Pathogenesis of dimethyl hydrazine induced angiosarcoma and colorectal cancer in three mouse strains. Anticancer Res 12:113–118.1567155
*Malaveille C, Brun G, Bartsch H. 1983. Studies on the efficiency of the Salmonella/rat hepatocyte assay for the detection of carcinogens as mutagens: Activation of 1,2-dimethyl-hydrazine and procarbazine into bacterial mutagens. Carcinogenesis 4:449–455.6340851
*Mansell RS, Bloom SA, Downs WC. 1988. Numerical simulation of hydrazine transport in a sandy soil. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 177–189.
Mantel C, London S. 1980. Adaptation of a soil bacterium to hydrazine propellants. Bull Environ Contam Toxicol 25:762–770.7470652
*Marshall CE, Watis DI, Sugden MC. 1983. Effects of hydrazine on liver and brown adipose tissue lipogenesis in 24-h starved rats. J Pharm Pharmacol 35:460–461.6136590
*Maru GB, Bhide SV. 1982. Effect of antioxidants and antioxicants of isoniazid on the formation of lung tumours in mice by isoniazid and hydrazine sulphate. Cancer Lett 17:75–80.7151054
Matheson D, Brusick D, Jagannath D. 1978. Genetic activity of1,11-dimethylhydrazine and methylhydrazine in a battery of in vitro and in vivo assays. Mutat Res 53:93–94.
Matsuki Y, Akazawa M, Tsuchiya K, 1991. Effects of ascorbic acid on the free radical formations of isoniazid and its metabolites. [Japanese] 10:600–605.
*Matsuyama K, Sendo T, Yamashita C, 1983. Brain distribution of hydrazine and its GABA elevating effect in rats. J Pharm Dyn 6:136–138.
Mazur JF, Podolak GE, Heitke BT. 1980. Use of a GC concentrator to improve analysis of low levels of airborne hydrazine and unsymmetrical dimethylhydrazine. Am Ind Hyg Assoc 41:66–69.
McIntosh GH. 1992. The influence of dietary vitamin E and calcium status on intestinal tumors in rats. Nutr Cancer 17:47–55.1574444
McKennis H, Yard AS, Adair EJ, 1961. L-y-Glutamylhydrazine and the metabolism of hydrazine. J Pharmacol Exp Ther 131:152–157.
McKinley S, Anderson CD, Jones ME. 1967. Studies on the action of hydrazine, hydroxylamine, and other amines in the carbamyl phosphate synthetase reaction. J Biol Chem 14:3381–3390.
McLellan EA, Medline A, Bird RP. 1991. Dose response and proliferative characteristics of aberrant crypt foci: Putative preneoplastic lesions in rat colon. Carcinogenesis 11:2093–2098.
Melvin WW, Johnson WS. 1976. A survey of information relevant to occupational health standards for hydrazines. Kelly AFB, TX: USAF Environmental Health Laboratory.
Milia U, Biancifiori C, Santilli FE. 1965. Late finding in pulmonary carcinogenesis by hydrazine sulphate in newborn BALB/c/Cb/Se substrain mice. Lav Anat Istol Patol Perugia XXV:165–171.
*Minard FN, Mushahwar IK. 1966. The effect of periodic convulsions induced by l,l-dimethylhydrazine on the synthesis of rat brain metabolites from [2^-14^C]glucose. J Neurochem 13:1–11 5931176
*Mitz MA, Aldrich FL, Vasta BM. 1962. Study of intermediary metabolic pathways of 1,1-dimethylhydrazine (UDMH). AMRL-TDR-62-110.
*Mizuno A, Mizobuchi T, Ishibashi Y, 1989. C-Fos mRNA induction under vitamin B_6_ antagonist-induced seizure. Neurosci Lett 98:272–275.2725947
*Moliner AM, Street JJ. 1989a. Decomposition of hydrazine in aqueous solutions. J Environ Qual 18:483–487.
*Moliner AM, Street JJ. 1989b. Interactions of hydrazine with clays and soils. J Environ Qual 18:487–491.
Moloney SJ, Snider BJ, Prough RA. 1984. The interactions of hydrazine derivatives with rat-hepatic cytochrome P-450. Xenobiotica 14:803–814.6506753
*Mori H, Sugie S, Yoshimi N, 1988. Genotoxicity of a variety of hydrazine derivatives in the hepatocyte primary culture/DNA repair test using rat and mouse hepatocytes. Jpn J Cancer Res 79:204–211.3130355
*Morris J, Densem JW, Walk NJ, 1995. Occupational exposure to hydrazine and subsequent risk of cancer. J Occup Environ Med (in press).
*Nagasawa HT, Shirota FN. 1972. Decomposition of methylazoxymethanol, the aglycone of cycasin, in D_2_O. Nature 236:234–235.
Narisawa T, Fukaura Y, Kotanagi H, 1992. Inhibitory effect of cryptoporic acid E, a product from fungus Cryptoporus volvutus, on colon carcinogenesis induced with N-methyl-N-nitrosourea in rats and with 1,2-dimethylhydrazine in mice. Jpn J Cancer Res 83:830–834.1399820
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
*NATICH. 1995. National Air Toxics Information Clearinghouse. Database report on state, local and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Washington, DC. March 14, 1995.
*NATICH. 1991. National Air Toxics Information Clearinghouse: NATICH database report on state, local and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA 450/3-91-018, 4-96, 4-133.
*Neft RE, Conner MK. 1989. Induction of sister chromatid exchange in multiple murine tissues in vivo by various methylating agents. Teratogenesis Carcinogen Mutagen 9:219–237.
Nelson RL. 1992. Chlorophyllin, an antimutagen, acts as a tumor promoter in the ratdimethylhydrazine colon carcinogenesis model. Anticancer Res 12:737–740.1622132
*Nelson RL, Briley S, Vaz OP, 1992. The effect of vagotomy and pyloroplasty on colorectal tumor induction in the rat. J Surg Oncol 51:281–286.1434662
*Netto LE, Leite LC, August0 0. 1987. Enzymatic activation of the carcinogens 2-phenylethylhydrazine and 1,Zdimethylhydrazine to carbon-centered radicals. Braz J Med Biol Res 20:865–868.3455269
*Netto LE, Ramakrishna NV, Kolar C, 1992. Identification of C^8^-methylguanine in the hydrolysates of DNA from rats administered 1,2-dimethylhydrazine. J Biol Chem 267:21524–21527.1400464
*Newaz SN, Fang WF, Strobe1 HW. 1983. Metabolism of the carcinogen 1,2-dimethylhydrazine by isolated human colon microsomes and human colon tumor cells in culture. Cancer 52:794–798.6871822
*NIOSH. 1977a. 1,1-Dimethylhydrazine - method S143. In: NIOSH manual of analytical methods, 2nd ed. Vol. 3. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control.
*NIOSH. 1977b. Hydrazine compounds in air - method 248. In: NIOSH manual of analytical methods. 2nd ed. Vol. 1. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control.
*NIOSH. 1984. Hydrazine - method 3503. In: NIOSH manual of analytical methods. 3rd ed. Vol. 2. Cincinnati, OH: National Institute for Occupational Safety and Health, (NIOSH),.Centers for Disease Control.
*NIOSH. 1992. Compendium of policy documents and statements. In: NIOSH recommendations for occupational safety and health. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control.
*NIOSH. 1994. NIOSH pocket guide to chemical hazards. Washington, DC: Department of Health and Human Services, 114, 166, 361.
*Noda A, Ishizawa M, Ohno K, 1986. Relationship between oxidative metabolites of hydrazine and hydrazine-induced mutagenicity. Toxicol Lett 31: 131–137.3520960
*Noda A, Noda H, Misaka A, 1988. Hydrazine radical formation catalyzed by rat microsomal NADPH-cytochrome P-450 reductase. Biochem Biophys Res Commun 153:256–260.2837203
*Noda A, Sendo T, Ohno K, 1987. Metabolism and cytotoxicity of hydrazine in isolated rat hepatocytes. Chem Pharmacol Bull 35:2538–2544.
NOES. 1993. National Occupational Exposure Survey. National Institute of Occupational Safety and Health, Cincinnati, OH. March 10, 1993.
*NRC. 1989. Recommended dietary allowances. 10th ed. Washington, DC: National Research Council, Commission on Life Sciences. 142–149.
*NTP. 1994. National Toxicology Program. Seventh annual report on carcinogens. Research Triangle Park, NC: National Institute of Environmental Health Sciences. 182-183, 231–233.
*O’Brien RD, Kirkpatrick M, Miller PS. 1964. Poisoning of the rat by hydrazine and alkylhydrazines. Toxicol Appl Pharmacol 6:371–377.14223485
*O’Leary JF, Oikemus A. 1956. Correspondence: Treatment of hydrazine toxicity. Arch Ind Health 569–570.
*Ochoa M, Wittes RE, Krakoff II I. 1975. Trial of hydrazine sulfate (NSC-150014) in patients with cancer. Cancer Chemother Rep 59:1151–1154.769954
*Oravec CR, Jones CA, Huberman E. 1986. Activation of the colon carcinogen 1,2-dimethylhydrazine in a rat colon cell-mediated mutagenesis assay. Cancer Res 46:5068–5071.3756864
*OSHA. 1989. Occupational Safety and Health Administration: Part III. Federal Register 54:2332, 2935.
OSHA. 1992. Occupational Safety and Health Administration: Part II. Federal Register 57:26002, 26545–52696.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436. April 1990.
*Ou LT. 1987. Microbial degradation of hydrazine. Bull Environ Contam Toxicol 39:78–85.3607323
*Ou LT, Street JJ. 1987a. Hydrazine degradation and its effect on microbial activity in soil. Bull Environ Contam Toxicol 38:179–183.3101771
*Ou ET, Street JJ. 1987b. Microbial enhancement of hydrazine degradation in soil and water. Bull Environ Contam Toxicol 39:541–548.3664009
*Parodi S, DeFlora S, Cavanna M, 1981. DNA-damaging activity in vivo and bacterial mutagenicity of sixteen hydrazine derivatives as related quantitatively to their carcinogenicity. Cancer Res 41:1469–1482.7214329
*Patrick RL, Back KC. 1965. Pathology and toxicology of repeated doses of hydrazine and 1,1-dimethylhydrazine in monkeys and rats. Ind Med Surg 430–435.14288270
*Pence BC. 1985. Fecal mutagens and Bucteauidesfwgilis levels in the feces of dimethylhydrazine-treated rats: Influence of diet. Mutat Res 15853–60.
Pence BC, Tsai SY, Richard BC. 1991. Effects of dietary fat on hepatic microsomal metabolism of 1,2-dimethylhydrazine. Cancer Lett 59:225–229.1913618
*Pereyo N. 1986. Hydrazine derivatives and induction of systemic lupus erythematosus. J Am Acad Dermatol 14:514–515.3958266
*Petersen P, Bredahl E, Lauritsen O, 1970. Examination of the liver in personnel working with liquid rocket propellant. Br J Ind Med 27:141–146.5428632
Pinkerton MK, Lauer JM, Diamond P, 1962. A calorimetric determination for 1, 1-dimethylhydrazine (UDMH) in air, blood and water. Industrial Hygiene Journal 239–244.
*Pitts JN, Tuazon EC, Carter WP, 1980. Atmospheric chemistry of hydrazines: Gas phase kinetics and mechanistic studies. ESL-TR-80-39.
*Poitrast BJ, Keller WC, Elves RG. 1988. Estimation of chemical hazards in breast milk. Aviat Space Environ Med A87-A92.
Potten CS, Li YQ, O’Connor PJ, 1992. A possible explanation for the differential cancer incidence in the intestine, based on distribution of the cytotoxic effects of carcinogens in the murine large bowel. Carcinogenesis 13:2305–2312.1473238
*Pozharisski KM, Kapustin YM, Likhachev AJ, 1975. The mechanism of carcinogenic action of 1,2dimethylhydrazine (SDMH) in rats. Int J Cancer 15:673–683.1140867
*Pozharisski KM, Shaposhnikov JD, Petrov AS, 1976. Distribution and carcinogenic action of 1,2dimethylhydrazine (SDMH) in rats. Z Krebforsch 87:67–80.
Preece NE, Timbrell JA. 1989. Investigation of lipid peroxidation induced by hydrazine compounds in vivo in the rat. Pharmacol Toxicol 64:282–285.2726691
*Preece NE, Nicholson JK, Timbrell JA. 1991. Identification of novel hydrazine metabolites by 15N-NMR. Biochem Pharmacol 9:1319–1324.
*Preece NE, Forrow S, Ghatineh S, 1992a. Determination of hydrazine in biofluids by capillary gas chromatography with nitrogen-sensitive or mass spectrometric detection. J Chromatogr Biomed Appl 573:227–234.
*Preece NE, Ghatineh S, Trimbrell JA. 1992b. Studies on the disposition and metabolism of hydrazine in rats in vivo. Human Exp Toxicol 11: 121–127.
*Prough RA. 1973. The N-oxidation of alkylhydrazines catalyzed by the microsomal mixed-function amine oxidase. Arch Biochem Biophys 158:442–444.4729304
*Prough RA, Freeman PC, Hines RN. 1981. The oxidation of hydrazine derivatives catalyzed by the purified liver microsomal FAD-containing monooxygenase. J Biol Chem 256:4178–4184.7217078
*Public Law 101-549. 1990. Clean Air Act Amendments of 1990. Federal Laws 71:2022–2023.
*Quintero-Ruiz A, Paz-Net-i LL, Villa-Trevino S. 1981. Indirect alkylation of CBA mouse liver DNA and RNA by hydrazine in vivo: A possible mechanism of action as a carcinogen. J Natl Cancer Inst 3:613–618.
*Radding SB, Liu DH, Johnson HL, 1977. Review of the environmental fate of selected chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/5-77-003.
Ravichandran K, Baldwin RP. 1983. Liquid chromatographic determination of hydrazines with electrochemically pretreated glassy carbon electrodes. Anal Chem 55:1782–1786.
*Reed DJ, Dost FN, McCutcheon RS, 1963. Biochemical and pharmacological studies of 1,1-dimethylhydrazine. AMRL-TDR-63– 127.
*Reid FJ. 1965. Hydrazine poisoning. British Medical Journal 1246.
*Reidenberg MM, Durant PJ, Harris RA, 1983. Lupus erythematosis-like disease due to hydrazine. Am J Med 75:365–370.6683928
Reinhardt CF, Dinman BD. 1965a. Acute hepatotoxicity and enzymatic response to hydrazine and 1,1-dimethylhydrazine in rats. AMRL-TR-65-19.
*Reinhardt CF, Dinman BD. 1965b. Toxicity of hydrazine and l,l-dimethylhydrazine (UDMH): Hepatostructural and enzymatic change. Arch Environ Health 10:859–869.14308824
*Reynolds BA, Thomas AA. 1965. A calorimetric method for the determination of hydrazine and monomethylhydrazine in blood. Am Ind Hyg Assoc J 527–531.5865322
*Reynolds HH, Rohles FH, Fineg J, 1963. The effect of UDMH on learned behavior in the Java monkey. Aerosp Med 920–922.14050678
*Reynolds HH, Rohles FH, Prine JR, 1964. The effect of 1,1-dimethylhydrazine (UDMH) on complex avoidance behavior in the Java monkey. Aerosp Med 377–382.14140624
*Richter ED, Gal A, Bitchatchi E, 1992. Residual neurobehavioral impairment in a water technician exposed to hydrazine-containing mixtures. Isr J Med Sci 28:598–602.1428814
*Rinehart WE, Donait E, Green EA. 1960. The sub-acute and chronic toxicity of 1,1-dimethylhydrazine vapor. Indust Hyg J 207–210.
*Roberts E, Simonsen DG. 1966. Further toxicologic studies of acute hydrazine toxicity in mice. SAM-TR-66-89.
Roe FJ. 1978. Letter to the Editor: Hydrazine. Ann Occup Hyg 21:323–326.751560
*Roe FJ, Grant GA, Millican DM. 1967. Carcinogenicity of hydrazine and l,l-dimethylhydrazine for mouse lung. Nature 216:375–376.6053815
*Rogers AM, Back KC. 1981. Comparative mutagenicity of hydrazine and 3 methylated derivatives in L5178Y mouse lymphoma cells. Mutat Res 89:321–328.7290098
*Rogers KJ, Pegg AE. 1977. Formation of 06-methylaguanine by alkylation of rat liver, colon, and kidney DNA following administration of 1,2-dimethylhydrazine. Cancer Res 37:4082–4087.908041
*Rothberg S, Cope OG. 1956. Toxicity studies on hydrazine, methylhydrazine, symmetrical dimethylhydrazine, unsymmetrical dimethylhydrazine and dimethylnitrosamine (U). Chemical Warfare Laboratories Report No. 2027.
*Runge-Morris MA, Iacob S, Novak RF. 1988. Characterization of hydrazine-stimulated proteolysis in human erythrocytes. Toxic01 Appl Pharmacol 94:414–426.
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:A142–A151.3706135
*Rutschmann MA, Buser HR. 1991. Determination of daminozide and dimethylhydrazine residues in Swiss apple juice concentrates using gas chromatography-mass spectrometry. J Agric Food Chem 39:176–181.
Santerre CR, Cash JN, Zabik MJ. 1991. The decomposition of daminozide (ALAR) to form unsymmetrical dimethylhydrazine (UDMH) in heated, pH adjusted, canned solutions. J Food Protection 54:225–229.
Santodonato J. 1985. Monograph on human exposure to chemicals in the workplace: Hydrazine. Bethesda, MD: National Cancer Institute. PB86-155108.
Savchenko MF. 1974. The effect of hydrazine on the intrauterine development of the embryo. Gig Sanit 23–25.
Savchenko MR, Benemansky VV, Bazhanov OV. 1975. The toxicity of hydrazine for animals of different ages. Gig Sanit 29–33.
*Saxton WL, Steinbrecher K, Gunderson E. 1989. Results of a survey for the presence of daminozide and unsymmetrical dimethylhydrazine in food. J Agric Food Chem 37:570–573.
*Schiller CM, Curley WH, McConnell EE. 1980. Induction of colon tumors by a single oral dose of 1,2-dimethylhydrazine. Cancer Lett 11:75–79.7226140
*Schiller CM, Walden R, Kee TE. 1979. Effects of hydrazine and its derivatives on the development of intestinal brush border enzymes. Toxicol Appl Pharmacol 49:305–311.115112
*Schmeltz I, Abidi S, Hoffmann D. 1977. Tumorigenic agents in unburned processed tobacco: N-nitrosodiethanolamine and 1, l-dimethylhydrazine. Cancer Lett 2: 125–132.837359
*Schmidt EW. 1988. One hundred years of hydrazine chemistry. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 4-16.
Schuette SA, Rose RC. 1986. The effect of diets high in fat and/or fiber on colonic absorption of DMH in the rat. Nutr Cancer 8257–265.
*Sedgwick B. 1992. Oxidation of methylhydrazines to mutagenic methylating derivatives and inducers of the adaptive response of Escherichia coli to alkylation damage. Cancer Res 52:3693–3697.1617641
*Segerbo BE. 1979. Alterations in seizure mechanisms caused by oxygen high pressure, l,ldimethylhydrazine, and pyridoxine. Undersea Biomed Res 6:167–174.531996
Shaffer CB, Wands RC. 1973. Guides for short-term exposure limits to hydrazines. AMRL-TR-73-125.
*Sheth-Desai N, Lamba-Kanwal V, Eichholz A. 1987. Organ-specific effects of 1,2-dimethylhydrazine in hamster. Jpn J Cancer Res 78 117–125.3104254
*Shirai T, Ikawa E, Hirose M, 1985. Modification by five antioxidants of 1,2-dimethylhydrazineinitiated colon carcinogenesis in F344 rats. Carcinogenesis 4:637–639.
*Shirai T, Nakanowatari J, Kurata Y, 1983. Different dose-response relationships in the induction of different types of colonic tumors in wistar rats by 1,2-dimethylhydrazine. Gann 74:21–27.6301917
*Shook BS, Cowart OH. 1957. Health hazards associated with unsymmetrical dimethylhydrazine. Ind Med Surgery 333–336.
*Siegers CP, Bumann D, Trepkau HD, 1992. Influence of dietary iron overload on cell proliferation and intestinal tumorigenesis in mice. Cancer Lett 65:245–249.1516040
*Sinha BK. 1987. Activation of hydrazine derivatives to free radicals in the perfused rat liver: A spintrapping study. Biochimica Biophysics Acta 924:261–269.
*Sittig M. 1991. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NY: Noyes Publications.
*Slonin AR, Gisclard JB. 1976. Hydrazine degradation in aquatic systems. Bull Environ Contam Toxicol 16:301–309.10026
*Smith EB, Castaneda FA. 1970. Effect of UDMH on blood coagulation, the blood-aqueous barrier and the cornea. Aerosp Med 1240–1243.5490160
*Smith EB, Clark DA. 1971. Absorption of unsymmetrical dimethylhydrazine (UDMH) through canine skin. Toxicol Appl Pharmacol 18:649–659.5569836
*Smith EB, Clark DA. 1972. Absorption of hydrazine through canine skin. Toxicol Appl Pharmacol 21:186–193.5023832
*Sohn OS, Ishizaki H, Yang CS, 1991. Metabolism of azoxymethane, methylazoxymethanol and N-nitrosodimethylamine by cytochrome P450IIEl. Carcinogenesis 12:127–131.1988172
*Sotaniemi E, Hirvonen J, Isomaki H, 1971. Hydrazine toxicity in the human. Ann Clin Res 3:30–33.5546553
*Sotomayor RE, Chauhan PS, Ehling UH. 1982. Induction of unscheduled DNA synthesis in the germ cells of male mice after treatment with hydrazine or procarbazine. Toxicology 25:201–211.7157400
Southern JT, Schiller CM. 1981. Utilization of blood analyses to evaluate metabolic changes in control and 1,2-dimethylhydrazine-treated adult male fischer rats. Cancer Lett 14:47–54.7296540
*Spremulli E, Wampler GL, Regelson W. 1979. Clinical study of hydrazine sulfate in advanced cancer patients. Cancer Chemother Pharmacol 3:121–124.389477
*Springer DL, Krivak BM, Broderick DJ, 1981. Metabolic fate of hydrazine. J Toxicol Environ Health 8:21–29.7328705
*SRI. 1987. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 589, 697, 799, 808.
*SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 578, 684, 784, 793.
*SRI. 1992. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International, 580, 695, 792, 801.
*Steinhoff S, Mohr U, Schmidt WM. 1990. On the question of the carcinogenic action of hydrazine evaluation on the basis of new experimental results. Exp Pathol 39:1–9.2394235
*Sternran MB, Fairchild MD. 1967. Subconvulsive effects of 1,1-dimethylhydrazine on locomotor performance in the cat: Relationship of dose to time of onset. AMRL-TR-67-66.
Stetter JR, Tellefsen KA. 1979. Electrochemical determination of hydrazine and methyl- and 1,1-dimethylhydrazine in air. Talanta 26:799–804.18962518
*Stone DA. 1989. Atmospheric chemistry of propellant vapors. Toxicol Lett 49:349–360.2603168
Stone DA, Wiseman FL. 1988. The third conference on the environmental chemistry of hydrazine fuels. Rockville, MD: Hazardous Materials. AD/A197 632.
*Street JJ, Moliner AM. 1988. Hydrazine fate and transmissions in natural waters and soils. In: The Third Conference on the Environmental Chemistry of Hydrazine Fuels. ESL-TR-87-74, 108-l 17.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. Second edition, Beltsville, MD: Bradford Communications Corporation.
*Sunter JP, Senior PV. 1983. Induction of renal tumors in rats by the administration of 1,2-dimethylhydrazine. Pathology 140:69–76.
*Suzuki Y, Ohkido M. 1979. Contact dermatitis from hydrazine derivatives. Contact Dermatitis 5:113–114.157249
*Swenberg JA, Cooper HK, Bucheler J, 1979. 1,2-Dimethylhydrazine-induced methylation of DNA bases in various rat organs and the effect of pretreatment with disulfiram. Cancer Res 39:465–467.761218
Takahashi M, Imaida K. 1991. Modification of tumor development in the gastrointestinal tract. Prog Exp Tumor Res 58–74.2028026
Tayek JA, Herber D, Chlebowski RT. 1987. Effect of hydrazine sulphate on whole-body protein breakdown measured by ^14^C-1ysine metabolism in lung cancer patients. The Lancet 241–244.
*Teague CA, Gavin JB, Herdson PB. 1981. The response of three inbred strains of rat to the carcinogen 1,2-dimethylhydrazine. Pathology 13:473–485.6272178
Thorup I, Meyer O, Kristiansen E. 1992. Effect of a dietary fiber (beet fiber) on dimethylhydrazineinduced colon cancer in Wistar rats. Nutr Cancer 17:251–261.1331991
*Timbrell JA, Harland SJ. 1979. Identification and quantitation of hydrazine in the urine of patients treated with hydralazine. Clin Pharmacol Ther 81–88.445966
*Timbrell JA, Scales MD, Streeter AJ. 1982. Studies on hydrazine hepatotoxicity. 2. Biochemical findings. J Toxicol Environ Health 10:955–968.7161842
*Tomasi A, Albano E, Botti B, 1987. Detection of free radical intermediates in the oxidative metabolism of carcinogenic hydrazine derivatives. Toxicol Pathol 15:178–183.3039646
*Toth B. 1969. Lung tumor induction and inhibition of breast adenocarcinomas by hydrazine sulfate in mice. J Natl Cancer Inst 42:469–475.5777492
*Toth B. 1972a. Hydrazine, methylhydrazine and methylhydrazine sulfate carcinogenesis in Swiss mice. Failure of ammonium hydroxide to interfere in the development of tumors. Int J Cancer 9:109–118.5015659
*Toth B. 1972b. Morphological studies of angiosarcomas induced by 1,2-dimethylhydrazine dihydrochloride in Syrian golden hamsters. Cancer Res 32:2818–2827.4345408
*Toth B. 1973a. l,l-Dimethylhydrazine (unsymmetrical) carcinogenesis in mice. Light microscopic and ultrastructural studies on neoplastic blood vessels. J Natl Cancer Inst 50: 181–194.4735011
Toth B. 1973b. Tumor induction studies with substituted hydrazines. AMRL-TR-73-125 365-371.
Toth B. 1991. Carcinogenic fungal hydrazines. In Vivo 5:95–100.1768794
*Toth B, Patil K. 1982. A carcinogenicity dose response study by continuous administration of 1,2-dimethylhydrazine dihydrochloride in mice. Anticancer Res 2:365–368.7168554
*Toth B, Malick L, Shimizu H, 1976. Production of intestinal and other tumors by 1,2-dimethylhydrazine dihydrochloride in mice. Am J Pathol 69–86.945699
*TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Tuazon EC, Carter WP, Winer AM, 1981. Reactions of hydrazines with ozone under simulated atmospheric conditions. Environ Sci Technol 15:823–828.
Turusov VS. 1980. Morphology and histogenesis of anal region and clitoral gland tumors induced in mice by 1,2-dimethylhydrazine. J Natl Cancer Inst 5:1161–1167.
Turusov VS, Lanko NS, Parfenov YD, 1988. Carcinogenicity of deuterium-labeled 1,2-dimethylhydrazine in mice. Cancer Res 48:2162–2167.3349486
Tweedie DJ, Erikson JM, Prough RA. 1987. Metabolism of hydrazine anti-cancer agents. Pharmacol Ther 34:111–127.3310042
*Van Ketel WG. 1964. Contact dermatitis from a hydrazine-derivate in a stain remover, cross sensitization to apresoline and isoniazid. Acta Derm Venereol 44:49–53.
*Van Stee EW. 1965. Acute effects of exposure to hydrazine and hydrazine derivatives on renal function in the dog. Aerosp Med 764–767.14334710
*Vernot EH, MacEwen JD, Bruner RH, 1985. Long-term inhalation toxicity of hydrazine. Fund Appl Toxicol 5:1050–1064.
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. Second Edition. New York, NY: Van Nostrand Reinhold Company, 554-555, 740–741.
*Vinas-Salas J, Fortuny JC, Panades J, 1992. Appearance of ear tumors in Sprague-Dawley rats treated with 1,2-dimethylhydrazine when used as a model for colonic carcinogenesis. Carcinogenesis 3:493–495.
*Visek WJ, Clinton SK, Imrey PB, 1991. Dietary protein and chronic toxicity of 1,2-dimethylhydrazine fed to mice. J Toxicol Environ Health 32:383–413.2016752
Von Burg R, Stout T. 1991. Toxicology update. J Appl Toxicol 11:447–450.1761803
Wagner I, Habs M, Schmahl D. 1979. Occult blood testing using the guaiac method (haemoccult-test) for detection of tumorous lesions induced with 1,2-dimethylhydrazine and acetoxymethyl-methylnitrosamine in rats. Acta Hepato-Gastroenterol 26:504–507.
*Wakabayashi T, Horiuchi M, Sakaguchi M, 1983. Induction of megamitochondria in the mouse and rat livers by hydrazine. Exp Mol Pathol 39:139–153.6617823
*Wald N, Boreham J, Doll R, 1984. Occupational exposure to hydrazine and subsequent risk of cancer. Br J Ind Med 41:31–34.6691933
*Wargovich MJ, Medline A, Bruce WR. 1983. Early histopathologic events to evolution of colon cancer in C57B/6 and CFl mice treated with 1,2-dimethylhydrazine. J Natl Cancer Inst 71:125–131.6575199
*Warren D, Cornelius C, Ford B. 1984. Liver function studies on Rhesus monkeys (Macuca muluttu) following the administration of hydrazine sulfate. Vet Hum Toxicol 26:295–299.6147041
*Watanabe M, Koga T, Sugano M. 1985. Influence of dietary cis- and trans-fat on 1,2-dimethylhydrazine-induced colon tumors and fecal steroid excretion in Fischer 344 rats. Am J Clin Nutr 42:475–484.4041127
*Wattenberg LW. 1975. Inhibition of dimethylhydazine-induced neoplasia of the large intestine by disulfiram. J Nat Cancer Inst 54:1005–1006.1127713
Wheeler CE, Penn SR, Cawley EP. 1965. Dermatitis from hydrazine hydrobromide solder flux. Arch Dermat 91:235–239.
*WHO. 1987. Environmental health criteria 68: Hydrazine. World Health Organization, Geneva, Switzerland, 1–89.
*Williams GM, Weisburger JH. 1991. Chemical carcinogenesis. In: Casarett and Doull’s Toxicology, the basic science of poisons. Amdur MO, Doull J, Klaasen CD, eds. Elmsford, NY: Pergamon Press, Inc. 180–181.
*Wilpart M, Mainguet P, Maskens A, 1983. Mutagenicity of 1,2-dimethylhydrazine towards Salmonella typhimuriurn, co-mutagenic effect of secondary biliary acids. Carcinogenesis 1:45–48.
*Wilson RB. 1976. Species variation in response to dimethylhydrazine. Toxicol Appl Pharmacol 38:647–650.1014019
*Winton DJ, Gooderham NJ, Boobis AR, 1990. Mutagenesis of mouse intestine in vivo using the Dlb-1 specific locus test: studies with 1,2-dimethylhydrazine, dimethylnitrosamine, and the dietary mutagen 2-amino-3,8-dimethylimidazo[4,5-f]quinoxaline. Cancer Res 50:7992–7996.2253241
*Walter S, Schmahl D, Frank N. 1984. Influence of diet on 1,2-dimethylhydrazine metabolism in rat liver. Nutr Cancer 6:181–186.6443635
*Wrangsjo K, Martensson A. 1986. Hydrazine contact dermatitis from gold plating. Contact Dermatitis 244–245.2948762
*Wright D. 1987. Pesticide and industrial chemical residues. New method for the determination of 1,1-dimethylhydrazine residues in apples and peaches. J Assoc Off Anal Chem 70:718–720.3624183
*Wryobek AJ, London SA. 1973. Effect of hydrazines on mouse sperm cells. AMRL-TR-73-125.
Yamada K, Yoshitake K, Sato M, 1992. Proliferating cell nuclear antigen expression in normal, preneoplastic, and neoplastic colonic epithelium of the rat. Gastroenterology 103:160–167.1351857
*Yamamoto K, Kawanishi S. 1991. Site-specific DNA damage induced by hydrazine in the presence of manganese and copper ions. J Biol Chem 256:1509–1515.
*Yamamoto RS, Weisburger JH. 1970. Failure to arginine glutamate to inhibit lung tumor formation by isoniazid and hydrazine in mice. Life Sci 9:285–289.5445842
*Zeilmaker MJ, Horsfall MJ, van Helten JB, 1991. Mutational specificities of environmental carcinogens in the Zucl gene of Escherichiu coli H.V: DNA sequence analysis of mutations in bacteria recovered from the liver of Swiss mice exposed to 1,2-dimethylhydrazine, azoxymethane, and methylazoxymethanolacetate. Mol Carcinogen 4: 180–188.
*Zijlstra JA, Vogel EW. 1988. Influence of inhibition of the metabolic activation on the mutagenicity of some nitrosamines, triazenes, hydrazines and seniciphylline in Drosophila melunoguster. Mutat Res 202:251–267.3141806
Zusman I, Madar Z, Nyska A. 1992a. Individual variability of pathological parameters in chemically induced rat colon tumors. Acta Anat 145:106–111.1441880
Zusman I, Zimber A, Madar Z, 1992b. Morphological, histochemical and immunohistochemical differences between tumorous and adjacent tissues in chemically induced colon cancer in rats. Acta Anat 145:29–34.1414210