# 7 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, numerous regulations and advisories have been established for hydrazines by various international, national and state agencies. Major regulations and advisories pertaining to hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine are summarized in Tables 7-1, 7-2, and 7-3, respectively.

ATSDR has derived an intermediate-duration inhalation MRL of 4×10^−3^ ppm for hydrazine, as described in Appendix A. The MRL is based on a LOAEL of 0.2 ppm for fatty liver changes in female mice (Haun and Kinkead 1973). The LOAEL was adjusted for intermittent exposure (6 hours/day, 5 days/week), converted to a Human Equivalent Concentration (HEC), and divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR has derived an intermediate-duration inhalation MRL of 2×10^−4^ ppm for 1,1-dimethylhydrazine, as described in Appendix A. The MRL is based on a LOAEL of 0.05 ppm for hepatic effects (hyaline degeneration of the gall bladder in female mice) (Haun et al. 1984). The LOAEL was adjusted for intermittent exposure (6 hours/day, 5 days/week), converted to an HEC, and divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR has derived an intermediate-duration oral MRL of 8X10^−4^ mg/kg/day for 1,2-dimethylhydrazine, as described in Appendix A. The MRL is based on a LOAEL of 0.75 mg/kg/day for mild hepatitis in male mice (Visek et al. 1991). The LOAEL was divided by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

TABLE 7-1 Regulations and Guidelines Applicable to Hydrazine

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | Group 2B^a^ | IARC 1994
[underlined: NATIONAL]
Regulations:
a. Air:
EPA OAQPS | Hazardous Air Pollutant | Yes | Public Law 101-549 Section 112
| High-risk Pollutant (proposed) | Yes | EPA 1991c
| List of Regulated Substances and Threshold for Accidental Release Prevention - Proposed | 5,000 pounds | EPA 1993
OSHA | PEL TWA | 0.1 ppm (0.1 mg/m^3^), skin^b^ | NIOSH 1994
b. Food:
FDA | Boiler water additive-limits for steam that will contact food | 0 | 21 CFR 173.310
c. Other:
EPA OERR | Reportable quantity | 1 pound | EPA 1989 (40 CFR 302.4)
| Extremely Hazardous Substance TPQ | 1,000 pounds | EPA 1987 (40 CFR 355)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1980 (40 CFR 261)
| Land Disposal Restrictions | Yes | EPA 1990b, 1991a (40 CFR 268)
| Burning of Hazardous Waste in Boilers and Industrial Furnaces-Residue Concentration Limit | l×10^−4^ mg/kg | EPA 1991b
EPA OTS | Toxic Chemical Release Reporting Rule | Yes | EPA 1988b (40 CFR 372)
| Priority Testing List (Section 4E) | Yes | EPA 1991d
Guidelines:
a. Air:
ACGIH | TLV TWA | Suspected human carcinogen, 0.1 ppm (0.13 mg/m^3^), skin | ACGIH 1994a
| Proposed TLV TWA | Animal carcinogen, 0.01 ppm (0.013 mg/m^3^), skin
NIOSH | REL Ceiling (120 minutes) | Potential occupational carcinogen 0.03 ppm (0.04 mg/m^3^) | NIOSH 1994
b. Other:
EPA | Carcinogenic Classification | Group B2^c^ | IRIS 1995
| Cancer slope factor (q_1_*)
| q_1_* (oral) | 3.0 (mg/kg-day)^−1^
| q_1_* (inhalation) | 1.7×10^1^ (mg/kg-day)^−1^
DHHS | Carcinogenic Classification | May reasonably be anticipated to be a carcinogen | NTP 1994
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Acceptable ambient air concentrations | | NATICH 1995
Connecticut | | 1.0 μg/m^3^ (8 hour)
Florida | | 1.0 × 10^−3^ mg/m^3^ (8 hour)
| | 3.1 × 10^−2^ μg/m^3^ (24 hour)
| | 1.3 × 10^−1^ μg/m^3^ (8 hour)
| | 3.4 × 10^−4^ μg/m^3^ (1 year)
Kansas | | 2.0 × 10^−4^ μg/m^3^ (1 year)
Louisiana | | 2.0 × 10^−2^ μg/m^3^ (1 year)
Maine | | 2.0 × 10^−4^ μg/m^3^ (1 year)
Massachusetts | | 7.0 × 10^−3^ μg/m^3^ (24 hour)
| | 2.0 × 10^−3^ μg/m^3^ (anuual)
Michigan | | 2.0 × 10^−4^ μg/m^3^ (1 year)
Nevada | | 2.0 × 10^−3^ mg/m^3^ (8 hour)
New York | | 3.3 × 10^−1^ μg/m^3^ (1 year)
North Carolina | | 6.0 × 10^−4^ mg/m^3^ (24 hour)
North Dakota | | 0 (best available control technology)
Oklahoma | | 3.93 × 10^−1^ μg/m^3^ (24 hour)
Pennsylvania | | 2.4 × 10^−1^ μg/m^3^ (1 year)
| | 2.4 × 10^−1^ ppb (1 year)
Rhode Island | | 3.0 × 10^−4^ μg/m^3^ (annual)
South Carolina | | 5.0 × 10^−1^ μg/m^3^ (24 hour)
Texas | | 1.3 × 10^−1^ μg/m^3^ (30 minute)
| | 1.3 × 10^−3^ μg/m^3^ (annual)
Virginia | | 1.3 μg/m^3^ (24 hour)

a Group 2B: Possible human carcinogen

b Due to a Federal court decision, not enforceable as of March 22, 1993 (Hanson 1993).

c Group B2: Probable human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; DHHS = Department of Health and Human Services; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OAQPS = Office of Air Quality Planning and Standards; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; OTS = Office of Toxic Substances; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average

TABLE 7-2 Regulations and Guidelines Applicable to 1,1-Dimethylhydrazine

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | Group 2B^a^ | IARC 1994
[underlined: NATIONAL]
Regulations:
a. Air:
EPA OAQPS | Hazardous Air Pollutant | Yes | Public Law 101-549
| List of Regulated Substances and Threshold for Accidental Release Prevention - Proposed | 5,000 pounds | EPA 1993
| NESHAP for Source Categories: Organic HAPs from Synthetic Organic Chemical Manufacturing Industry - Proposed | Yes | EPA 1992a
OSHA | Skin PEL TWA | .5 ppm (1 mg/m^3^) | NIOSH 1994
b. Other:
EPA OERR | Reportable quantity | 10 pounds | EPA 1989 (40 CFR 302.4)
| Extremely Hazardous Substance TPQ | 1,000 pounds | EPA 1987 (40 CFR 355)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1980 (40 CFR 261)
| Land Disposal Restrictions | Yes | EPA 1990b
| | | EPA 1991a
| | | EPA 1992b (40 CFR 268)
EPA OTS | Toxic Chemical Release Reporting Rule | Yes | EPA 1988b (40 CFR 372)
| Priority Testing List (Section 4E) | Yes | EPA 1991d
Guidelines:
a. Air:
ACGIH | TLV TWA | Suspected human carcinogen, 0.5 ppm (1.2 mg/m^3^), skin | ACGIH 1994a
| Proposed TLV TWA | Animal carcinogen, 0.01 ppm (0.25 mg/m^3^) skin
NIOSH | REL Ceiling (120 minutes) | Potential occupational carcinogen 0.06 ppm (0.15 mg/m^3^) | NIOSH 1994
b. Other:
EPA | Carcinogenic Classification | Group B2^c^ | HEAST 1992
| Cancer slope factor (q_1_*)
| q_1_* (oral) | 2.6 (mg/kg-day)^−1^
| q_1_* (inhalation) | 3.5 (mg/kg-day)^−1^
DHHS | Carcinogenic Classification | May reasonably be anticipated to be a carcinogen | NTP 1994
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Acceptable ambient air concentrations | | NATICH 1995
Connecticut | | 11 μg/m^3^ (8 hour)
Florida | | 1.0 × 10^−2^ mg/m^3^ (8 hour)
| | 6.0 × 10^−2^ μg/m^3^ (24 hour)
| | 2.5 × 10^−1^ μg/m^3^ (8 hour)
Nevada | | 2.4 × 10^−2^ mg/m^3^ (8 hour)
New York | | 3.3 μg/m^3^ (1 year)
North Dakota | | 0 (best available control technology)
Oklahoma | | 1.5 μg/m^3^ (24 hour)
Pennsylvania | | 2.4 μg/m^3^ (1 year)
| | 1.2 ppb (1 year)
South Carolina | | 5.0 μg/m^3^ (24 hour)
Texas | | 2.5 × 10^−1^ μg/m^3^ (30 minute)
| | 2.5 × 10^−2^ μg/m^3^ (annual)
Virginia | | 12 μg/m^3^ (24 hour)
Washington | | 3.3 μg/m^3^ (24 hour)

a Group 2B: Possible human carcinogen

b Due to a Federal court decision, not enforceable as of March 22, 1993 (Hanson 1993).

c Group B2: Probable human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; DHHS = Department of Health and Human Services; HAP = Hazardous Air Pollutants; IARC = International Agency for Research on Cancer; NESHAP = National Emission Standards for Hazardous Air Pollutants; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OAQPS = Office of Air Quality Planning and Standards; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; OTS = Office of Toxic Substances; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; TLV = Threshold Limit Value; TPQ = Threshold Planning Quantity; TWA = Time-Weighted Average.

TABLE 7-3 Regulations and Guidelines Applicable to 1,2-Dimethylhydrazine

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | Group 2B^a^ | IARC 1994
[underlined: NATIONAL]
Regulations:
a. Other:
EPA OERR | Reportable quantity | 1 pound | EPA 1989 (40 CFR 302.4)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1980 (40 CFR 261)
| Land Disposal Restrictions | Yes | EPA 1990b
| | | EPA 1991a (40 CFR 268)
EPA OTS | Toxic Chemical Release Reporting Rule - Proposed | Yes | EPA 1992d (40 CFR 372)
Guidelines:
a. Other:
EPA | Carcinogenic Classification | Group B2^b^ | HEAST 1992
| Cancer slope factor (q_1_*)
| q_1_* (oral) | 3.7 × 10^1^ (mg/kg-day)^−1^
| q_1_* (inhalation) | 3.7 × 10^1^ (mg/kg-day)^−1^
[underlined: STATE]
Regulations and Guidelines:
a. Air: | Acceptable ambient air concentrations | | NATICH 1991
South Carolina | | 5.0 μg/m^3^ (24 hour)

a Group 2B: Possible human carcinogen

b Group B2: Probable human carcinogen

EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; OERR = Office of Emergency and Remedial Response; OSW = Office of Solid Waste; OTS = Office of Toxic Substances