# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of hydrazines is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical properties of hydrazines is located in Table 3-2.

TABLE 3-1 Chemical Identity of Hydrazines

Characteristic | Hydrazine | 1,1-Dimethylhydrazine | 1,2-Dimethylhydrazine | References
Synonym(s) | Diamine; diamide; anhydrous hydrazine; hydrazine base | Hydrazine, 1,1-dimethyl; DMH; unsymmetrical dimethylhydrazine; UDMH; dimazine; and others | Hydrazine, 1,2-dimethyl; DMH; symmetrical dimethylhydrazine; SDMH; hydrazomethane; and others | HSDB 1993
Registered trade name(s) | Levoxin^®^; SCAV-OX; Zerox; Oxytreat 35 | No data | No data | HSDB 1993; WHO 1987
Chemical formula | H_4_N_2_ | C_2_H_8_N_2_ | C_2_H_8_N_2_ | HSDB 1993
Chemical structure | H_2_N-NH_2_ | [image] | CH_3_ - NH - NH - CH_3_ | IARC 1974
Identification numbers:
CAS registry | 302-01-2 | 57-14-7 | 540-73-8 | HSDB 1993
NIOSH RTECS | MU7175000 | MV2450000 | MV2625000 | HSDB 1993
EPA hazardous waste | U133 | U098 | U099 | HSDB 1993
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | UN2029, UN2030 | UN1163 | UN2382 | HSDB 1993
| IMCO 3.1 | IMCO 3.2 | IMCO 3.1
| IMCO 8.2
| NA 9188
HSDB | 544 | 528 | 4039 | HSDB 1993
NCI | No data | No data | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/lnternational Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Hydrazines

Property | Hydrazine | 1,1-Dimethylhydrazine | 1,2-Dimethylhydrazine | Reference
Molecular weight | 32.05 | 60.10 | 60.10 | HSDB 1993
Color | Colorless | Colorless | Colorless | HSDB 1993
Physical state | Liquid | Liquid | Liquid | HSDB 1993
Melting point | 2°C | −58°C | −9°C | HSDB 1993
Boiling point | 113.5°C | 63.9°C | 81°C | WHO 1987
Density | 1.0036 g/mL at 25°C | 0.7914 g/mL at 25°C | 0.8274 g/mL at 20°C | HSDB 1993; WHO 1987
Odor | Ammoniacal, pungent, fishy | Ammoniacal, fishy | Ammoniacal | HSDB 1993; WHO 1987
Odor threshold:
Water | 160 mg/L | No data | No data | Amoore and Hautala 1983
Air | 3-4 mg/m^3^ | 12-20 mg/m^3^ | No data | Ruth 1986
Solubility:
Water | Miscible | Miscible | Miscible | Budavari et al. 1989; HSDB 1993
Organic solvent(s) | Miscible with alcohol, insoluble in chloroform and ether | Miscible with alcohol, ether, dimethyl formamide and hydrocarbons | Miscible with alcohol, ether, dimethyl formamide and hydrocarbons | ACGIH 1991a, 1991b; Budavari et al. 1989
Partition coefficients:
Log K_ow_ | −3.08 | No data | No data | Radding et al. 1977; Poitrast et al. 1988
| −1.07 | | | Radding et al. 1977; Poitrast et al. 1988
Log K_oc_ | No data | No data | No data
Vapor pressure | 10.4-16 mmHg at 20°C | 157 mmHg at 25°C | 68 mmHg at 24°C | HSDB 1993; Verschueren 1983; WHO 1987
Henry’s law constant | No data | No data | No data | HSDB 1993; Verschueren 1983; WHO 1987
Autoignition temperature | No data | 249°C | No data
Flashpoint | 38°C (open cup) | −15°C (closed cup) | <23°C (closed cup) | HSDB 1993; WHO 1987
Flammability limits | 1.8-100% | No data | No data | WHO 1987
Conversion factors | 1 ppm = 1.31 mg/m^3^ | 1 ppm = 2.5 mg/m^3^ | 1 ppm = 2.5 ing/m^3^ | HSDB 1993; Verschueren 1983; WHO 1987
| 1 mg/m^3^ = 0.76 ppm | 1 mg/m^3^ = 0.407 ppm | 1 mg/m^3^ = 0.407 ppm | HSDB 1993; Verschueren 1983; WHO 1987
Explosive limits | 4.7-100% | 2-95% | No data | ACGIH 1991a, 1991b