# 2 HEALTH EFFECTS

## 2.1 INTRODUCTION

The primary purpose of this chapter is to provide public health officials, physicians, toxicologists, and other interested individuals and groups with an overall perspective on the toxicology of hydrazines. It contains descriptions and evaluations of toxicological studies and epidemiological investigations and provides conclusions, where possible, on the relevance of toxicity and toxicokinetic data to public health.

A glossary and list of acronyms, abbreviations, and symbols can be found at the end of this profile.

The term “hydrazines” is a generic name used in this document to describe a group of three structurally related chemicals: hydrazine, l,l-dimethylhydrazine, and 1,2-dimethylhydrazine. These three hydrazines were selected for inclusion in this document because they have been detected at hazardous waste sites and are of concern to the Department of Defense. Numerous other hydrazine derivatives exist as well. For example, the reader is referred to the Toxicological Profile for 1,2-Diphenylhydrazine (ATSDR 1990) for information on this chemical.

## 2.2 DISCUSSION OF HEALTH EFFECTS BY ROUTE OF EXPOSURE

To help public health professionals and others address the needs of persons living or working near hazardous waste sites, the information in this section is organized first by route of exposure - inhalation, oral, and dermal; and then by health effect - death, systemic, immunological, neurological, reproductive, developmental, genotoxic, and carcinogenic effects. These data are discussed in terms of three exposure periods - acute (14 days or less), intermediate (15-364 days), and chronic (365 days -. or more).

Levels of significant exposure for each route and duration are presented in tables and illustrated in figures. The points in the figures showing no-observed-adverse-effect levels (NOAELs) or lowest observed-adverse-effect levels (LOAELs) reflect the actual doses (levels of exposure) used in the studies. LOAELs have been classified into “less serious” or “serious” effects. “Serious” effects are those that evoke failure in a biological system and can lead to morbidity or mortality (e.g., acute respiratory distress or death). “Less serious” effects are those that are not expected to cause significant dysfunction or death, or those whose significance to the organism is not entirely clear. ATSDR acknowledges that a considerable amount of judgment may be required in establishing whether an end point should be classified as a NOAEL, “less serious” LOAEL, or “serious” LOAEL, and that in some cases, there will be insufficient data to decide whether the effect is indicative of significant dysfunction. However, the Agency has established guidelines and policies that are used to classify these end points. ATSDR believes that there is sufficient merit in this approach to warrant an attempt at distinguishing between “less serious” and “serious” effects. The distinction between “less serious” effects and “serious” effects is considered to be important because it helps the users of the profiles to identify levels of exposure at which major health effects start to appear. LOAELs or NOAELs should also help in determining whether or not the effects vary with dose and/or duration, and place into perspective the possible significance of these effects to human health.

The significance of the exposure levels shown in the Levels of Significant Exposure (LSE) tables and figures may differ depending on the user’s perspective. Public health officials and others concerned with appropriate actions to take at hazardous waste sites may want information on levels of exposure associated with more subtle effects in humans or animals or exposure levels below which no adverse effects have been observed. Estimates of levels posing minimal risk to humans (Minimal Risk Levels or MRLs) may be of interest to health professionals and citizens alike.

Levels of exposure associated with carcinogenic effects (Cancer Effect Levels, CELs) of hydrazines are indicated in Tables 2-1 and 2-2 and Figures 2-1 and 2-2. Because cancer effects could occur at lower exposure levels, Figures 2-1 and 2-2 also show a range for the upper bound of estimated excess risks, ranging from a risk of 1 in 10,000 to 1 in 10,000,000 (10m^−4^ to 10m^−7^), as developed by EPA.

Estimates of exposure levels posing minimal risk to humans (Minimal Risk Levels or MRLs) have been made for hydrazines. An MRL is defined as an estimate of daily human exposure-to a substance that is likely to be without an appreciable risk of adverse effects (noncarcinogenic) over a specified duration of exposure. MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration within a given route of exposure. MRLs are based on noncancerous health effects only and do not consider carcinogenic effects. MRLs can be derived for acute, intermediate, and chronic duration exposures for inhalation and oral routes. Appropriate methodology does not exist to develop MRLs for dermal exposure.

Although methods have been established to derive these levels (Barnes and Dourson 1988; EPA 1990), uncertainties are associated with these techniques. Furthermore, ATSDR acknowledges additional uncertainties inherent in the application of the procedures to derive less than lifetime MRLs. As an example, acute inhalation MRLs may not be protective for health effects that are delayed in development or are acquired following repeated acute insults, such as hypersensitivity reactions, asthma, or chronic bronchitis. As these kinds of health effects data become available and methods to assess levels of significant human exposure improve, these MRLs will be revised.

A User’s Guide has been provided at the end of this profile (see Appendix A). This guide should aid in the interpretation of the tables and figures for Levels of Significant Exposure and the MRLs.

### 2.2.1 Inhalation Exposure

In their pure form, hydrazines are fairly volatile liquids (see Section 3.2), and therefore inhalation exposures are of concern. Data regarding toxic effects in humans or animals after inhalation exposure to 1,2dimethylhydrazine are lacking. In one preliminary study, however, the toxicity of 1,2dimethylhydrazine vapors to rats was judged to be less than that of l, l-dimethylhydrazine but greater than that of hydrazine (Jacobson et al. 1955). More complete data are available from human and animal studies regarding the toxic effects of inhaled hydrazine and 1,1-dimethylhydrazine. These studies are discussed below.

#### 2.2.1.1 Death

No studies were located regarding death in humans after inhalation exposure to l, l-dimethylhydrazine.

A single case study was located which described the death of a male worker exposed to an undetermined concentration of hydrazine once a week for 6 months (Sotaniemi et al. 1971). Death was attributed to hydrazine exposure, resulting in severe lesions of the kidneys and lungs with complicating pneumonia.

A number of animal studies have reported deaths after inhalation exposure to hydrazines. For example, one out of three dogs died within 3 days of intermittent exposure to 25 ppm 1,1-dimethyl hydrazine (Rinehart et al. 1960). In another study involving a single 4-hour exposure of groups of 3 dogs to vapors of l,l-dimethylhydrazine at levels of 24, 52, or 111 ppm, all animals exposed to the two highest concentrations either died or were moribund within 24 hours, whereas the dogs receiving the lowest concentration showed no signs of adverse effects (Jacobson et al. 1955). During exposure at the two higher levels, the dogs experienced vomiting, convulsions, panting (respiratory distress), and diarrhea. One of the dogs exposed to 24 ppm suffered vomiting and convulsions during exposure but appeared to recover completely in the postexposure observation period. Two out of eight dogs exposed continuously to 1 ppm hydrazine progressively deteriorated and died after 16 weeks (Haun and Kinkead 1973).

A 1-hour exposure to 80 ppm hydrazine did not cause any immediate deaths in rats, although one out of six died during the subsequent 14-day observation period (Cornstock et al. 1954). Twenty-two out of 40 mice died after continuous exposure to 1 ppm hydrazine for 6 months (Haun and Kinkead 1973). Death in these mice was attributed to the hepatotoxic effects of hydrazine. In contrast, mortality was not increased in rats or monkeys exposed to 1 ppm hydrazine, suggesting that mice may be more sensitive to the lethal effects of hydrazine than other species. Mortality was 32-33% in hamsters exposed intermittently to 0.25 ppm hydrazine for 1 year compared to 19% in controls (Vernot et al. 1985). Exposure to 5 ppm l,l-dimethylhydrazine for 6 months did not significantly affect the mortality rates in rats, mice, dogs, and hamsters (Haun et al. 1984).

The above studies indicate that exposure to relatively high concentrations of hydrazines in air can be lethal and suggest that hydrazine may be more toxic than l,l-dimethylhydrazine. In contrast, Jacobson et al. (1955) exposed mice, rats, and hamsters to substantially higher concentrations of hydrazine or 1,1-dimethylhydrazine vapors for 4 hours and found 1,1-dimethylhydrazine to be more toxic than hydrazine under these conditions. The LC_50_s calculated by these authors for the 4-hour inhalation exposures were 570 and 252 ppm for hydrazine in rats and mice, respectively, and 252, 172, and 392 ppm for l,l-dimethylhydrazine in rats, mice, and hamsters, respectively. In these studies, rats were also exposed to vapors of 1,2-dimethylhydrazine for 4 hours, and based on a limited number of dose levels, an LC_50_ of 280-400 ppm was calculated. All LOAEL values from each reliable study for lethality are recorded in Table 2-1 and plotted in Figure 2-1.

#### 2.2.1.2 Systemic Effects

The systemic effects observed after inhalation exposure are described below. No studies were located regarding dermal effects in humans or animals after inhalation exposure to hydrazines. The highest NOAEL values and all LOAEL values from each reliable study for systemic effects after inhalation exposure to hydrazine and l,l-dimethylhydrazine are recorded in Table 2-1 and plotted in Figure 2-1.

Respiratory Effects. Acute accidental exposure to a mixture of hydrazine and l,l-dimethylhydrazine resulted in dyspnea and pulmonary edema in two men (Frierson 1965). A single case study reported pneumonia, tracheitis, and bronchitis in a man occupationally exposed to an undetermined concentration of hydrazine in air once a week for 6 months (Sotaniemi et al. 1971). These lesions were severe and were a contributing factor in this worker’s death.

Respiratory effects have been observed in a number of animal studies. In dogs, alveolar hemorrhage, emphysema, and atelectasis were observed following intermittent exposure to 25 ppm l,l-dimethylhydrazine for 13 weeks (Rinehart et al. 1960). These effects were not observed in dogs exposed to 5 ppm for 26 weeks. Hyperplasia of the alveoli and lymphoid tissue of the lung was observed in rats and mice exposed to 0.05 ppm l,l-dimethylhydrazine for 6 months (Haun et al. 1984). A higher concentration (0.5 ppm) produced congestion and perivascular cuffing in the lungs of these mice. Intermittent exposure to 5 ppm hydrazine or l,l-dimethylhydrazine for 1 year produced inflammation, hyperplasia, and metaplasia of the upper respiratory tract epithelium in rats and mice (Haun et al. 1984; Vemot et al. 1985). No adverse effects were noted in the lungs of mice exposed intermittently to 1 ppm hydrazine. These data indicate that hydrazine and l,l-dimethylhydrazine can produce lung damage.

Cardiovascular Effects. No studies were located regarding cardiovascular effects in humans after inhalation exposure to l,l-dimethylhydrazine. Data regarding the adverse effects of hydrazine on the cardiovascular system in humans are limited to a single case study. Atria1 fibrillation, enlargement of the heart, and degeneration of heart muscle fibers were noted in a worker exposed to an undetermined concentration of hydrazine once a week for 6 months (Sotaniemi et al. 1971). It is uncertain whether these effects are directly attributable to hydrazine exposure.

TABLE 2-1 Levels of Significant Exposure to Hydrazines - Inhalation

Key^a^ to figure | Species/(strain) | Exposure/duration/frequency | System | NOAEL (ppm) | | LOAEL | | | | | | Reference Chemical Form
Key^a^ to figure | Species/(strain) | Exposure/duration/frequency | System | NOAEL (ppm) | | Less serious (ppm) | | | Serious (ppm) | | | Reference Chemical Form
| ACUTE EXPOSURE
| Death
1 | Rat; (NS) | 4 hr | | | | | | | 570 | M | (LC50) | Jacobson et al. 1955; H
2 | Rat; (NS) | 4 hr | | | | | | | 252 | M | (LC50) | Jacobson et al. 1955; 11DMH
3 | Mouse; (NS) | 4 hr | | | | | | | 252 | F | (LC50) | Jacobson et al. 1955; H
4 | Mouse; (NS) | 4 hr | | | | | | | 172 | F | (LC50) | Jacobson et al. 1955; 11DMH
5 | Dog; (Beagle) | 4 hr | | | | | | | 52 | M | (3/3 deaths) | Jacobson et al. 1955; 11DMH
| Neurological
6 | Dog; (Beagle) | 4 hr | | | | | | | 24 | M | (convulsions) | Jacobson et al. 1955; 11DMH
| INTERMEDIATE EXPOSURE
| Death
7 | Mouse; (CF-1) | 2 wk; (cont) | | | | | | | 140 | F | (29/30 deaths) | Rinehart et al. 1960; 11DMH
8 | Mouse; (CF-1) | 5 wk; (cont) | | | | | | | 75 | F | (8/30 deaths) | Rinehart et al. 1960; 11DMH
9 | Mouse; (ICR) | 6 mo; (cont) | | | | | | | 1 | F | (22/40 deaths) | Haun and Kinkead 1973; H
10 | Dog; (Beagle) | 3d; 6 hr/d | | | | | | | 25 | M | (1/3 deaths) | Rinehart et al. 1960; 11DMH
11 | Dog; (Beagle) | 6 mo; (cont) | | | | | | | 1 | M | (2/8 deaths) | Haun and Kinkead 1973; H
| Systemic
12 | Monkey; (Rhesus) | 6 mo; 5 d/wk; 6 hr/d | Hemato | 5 | F | | | | | | | Haun and Kinkead 1973; H
| | | Hepatic | | | 1 | F | (slight to moderate fatty liver changes)
| | | Derm | 1 | F | 5 | F | (minimal eye irritation)
| | | Bd Wt | 5 | F
13 | Monkey; (Rhesus) | 6 mo; (cont) | Hemato | 1 | F | | | | | | | Haun and Kinkead 1973; H
| | | Hepatic | | | 0.2 | F | (slight to moderate fatty liver changes)
| | | Derm | 0.2 | F | 1 | F | (minimal eye irritation)
| | | Bd Wt | 1 | F
14 | Rat; (F-344/CrIBR) | 6 mo; 5 d/wk; 6 hr/d | Resp | | | 0.05 | M | (alveolar hyperplasia) | | | | Haun et al. 1984; 11DMH
| | | Hemato | 5 | M
| | | Hepatic | | | 0.05 | M | (fatty changes in the liver)
15 | Rat; (Sprague-Dawley) | 6 mo; 5d/wk; 6hr/d | Hemato | 5 | M | | | | | | | Haun and Kinkead 1973; H
| | | Bd Wt | | | 1 | M | (unspecified decrease in body weight gain)
16 | Rat; (Sprague-Dawley) | 6 mo; (cont) | Hemato | 1 | M | | | | | | | Haun and Kinkead 1973; H
| | | Bd Wt | 0.2 | M | 1 | M | (unspecified decrease in body weight gain)
17 | Mouse; (C57BL/6) | 6 mo; 5 d/wk; 6 hr/d | Resp | | | 0.05 | F | (lymphoid hyperplasia of the lung) | | | | Haun et al. 1984; 11DMH
| | 6 mo; 5 d/wk; 6 hr/d | | | | 0.5 | F | (congestion and perivascular cuffing of the lung)
| | | Hepatic | | | 0.05^b^ | F | (hyaline degeneration of the gall bladder)
| | | | | | 0.5 | F | (congestion of the liver)
| | | Bd Wt | 5 | F
18 | Mouse; (ICR) | 6 mo; 5 d/wk; 6 hr/d | Hepatic | | | 1 | F | (moderate fatty liver changes) | 5 | F | (severe fatty liver changes, cytoplasmic vacuolization) | Haun and Kinkead 1973; H
19 | Mouse; (ICR) | 6 mo; (cont) | Hepatic | | | 0.2^c^ | F | (moderate fatty liver changes) | 1 | F | (severe fatty liver changes, cytoplasmic vacuolization) | Haun and Kinkead 1973; H
20 | Hamster; (Syrian Golden) | 6 mo; 5 d/wk; 6 hr/d | Hemato | 5 | M | | | | | | | Haun et al. 1984; 11DMH
21 | Dog; (Beagle) | 13-26 wk; 5 d/wk; 6 hr/d | Resp | 5 | M | | | | 25 | M | (alveolar hemorrhage, emphysema, and atelectasis) | Rinehart et al. 1960; 11DMH
| | | Cardio | 25 | M
| | | Gastro | 25 | M
| | | Hemato | | | 5 | M | (mild anemia) | 25 | M | (anemia)
| | | Hepatic | 5 | M | 25 | M | (hemosiderosis)
| | | Renal | 25 | M
| | | Bd Wt | | | 5 | M | (13% body weight loss)
22 | Dog; (Beagle) | 6 mo; 5 d/wk; 6 hr/d | Hemato | 5 | B | | | | | | | Haun et al. 1984; 11DMH
| | 6 mo; 5 d/wk; 6 hr/d | Hepatic | 5 | B
| | | Bd Wt | 5 | B
23 | Dog; (Beagle) | 6 mo; (cont) | Hemato | 0.2 | M | 1 | M | (decreased hemoglobin, hematocrit, and red blood cell count) | | | | Haun and Kinkead 1973; H
| | | Hepatic | 0.2 | M | 1 | M | (fatty changes)
| | | Bd Wt | 0.2 | | 1 | M | (unspecified decrease in body weight gain)
| Neurological
24 | Rat; (Wistar) | 6-7 wk; (cont) | | | | | | | 75 | M | (occasional tremors) | Rinehart et al. 1960; 11DMH
25 | Mouse; (CF-1) | 6-7 wk; (cont) | | | | | | | 75 | F | (occasional tremors) | Rinehart et al. 1960; 11DMH
26 | Dog; (Beagle) | 13-26 wk; 5 d/wk; 6 hr/d | | 5 | M | | | | | | | Rinehart et al. 1960; 11DMH
27 | Dog; (Beagle) | 3 d; 6 hr/d | | 5 | M | | | | 25 | M | (depression, ataxia, salivation, emesis, and seizures after 3 days) | Rinehart et al. 1960; 11DMH
28 | Dog; (Beagle) | 6 mo; (cont) | | 0.2 | M | | | | 1 | M | (tonic convulsions) | Haun and Kinkead 1973; H
| Cancer
29 | Rat; (F-344/CrIBR) | 6 mo; 5 d/wk; 6 hr/d | | | | | | | 0.05 | M | (CEL: pancreatic islet cell adenoma, pituitary chromophobe adenoma, mononuclear cell leukemia) | Haun et al. 1984; 11DMH
30 | Mouse; (C57BL/6) | 6 mo; 5 d/wk; 6 hr/d | | | | | | | 0.05 | F | (CEL: adenoma of the pituitary, hemangiosarcoma, and Kupffer cell sarcoma) | Haun et al. 1984; 11DMH
| | | | | | | | | 0.5 | F | (CEL: thyroid follicular cell carcinoma)
| CHRONIC EXPOSURE
| Death
31 | Hamster; (Syrian Golden) | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 0.25 | M | (increased mortality) | Vernot et al. 1985; H
| Systemic
32 | Rat; (Fischer-344) | 1 yr; 5 d/wk; 6 hr/d | Resp | 1 | B | 5 | B | (inflammation, hyperplasia, and metaplasia of the upper respiratory tract) | | | | Vernot et al. 1985; H
| | | Hepatic | 0.25 | B | 1 | B | (focal cellular change in females)
33 | Mouse; (C57BL/6) | 1 yr; 5 d/wk; 6 hr/d | Resp | | | 5 | F | (inflammation, hyperplasia, metaplasia, and dysplasia of the nasal mucosa) | | | | Haun et al. 1984; 11DMH
| | | Hepatic | | | 5 | F | (angiectasis in liver)
| | | Bd Wt | | | 5 | F | (15% decreased body weight gain)
34 | Mouse; (C57BL/6) | 1 yr; 5 d/wk; 6 hr/d | Resp | 1 | F | | | | | | | Vernot et al. 1985; H
| | 1 yr; 5 d/wk; 6 hr/d | Resp | 1 | F
| | | Gastro | 1 | F
| | | Musc/skel | 1 | F
| | | Hepatic | 1 | F
| | | Renal | 1 | F
| | | Derm | 1 | F
35 | Hamster; (Syrian Golden) | 1 yr; 5 d/wk; 6 hr/d | Hepatic | | | 0.25 | M | (amyloidosis, hemosiderosis, and bile duct hyperplasia) | | | | Vernot et al. 1985; H
| | | Renal | | | 0.25 | M | (amyloidosis and mineralization)
| | | Bd Wt | | | 0.25 | M | (up to 14% loss of body weight)
36 | Dog; (Beagle) | 1 yr; 5 d/wk; 6 hr/d | Hepatic | 0.25 | B | 1 | M | (focal areas of highly vacuolated cells, elevated serum glutamic oxaloacetic transaminase) | | | | Vernot et al. 1985; H
| Reproductive
37 | Rat; (Fischer-344) | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 5 | B | (atrophy of the ovaries and inflammation of the endometrium and uterine tube) | Vernot et al. 1985; H
38 | Hamster; (Syrian Golden) | 1 yr; 5 d/wk; 6 hr/d | | 0.25 | M | | | | 1 | M | (senile testicular atrophy) | Vernot et al. 1985; H
| Cancer
39 | Rat; (Fischer-344) | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 1 | M | (CEL: nasal adenomatous polyps in males) | Vernot et al. 1985; H
| | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 5 | M | (CEL: thyroid carcinoma in males)
40 | Mouse; (C57BL/6) | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 5 | F | (CEL: alveolar/ bronchiolar adenoma, hepatocellular adenoma, lymphoma, papilloma of the nose, osteoma, hemangioma) | Haun et al. 1984; 11DMH
41 | Hamster; (Golden Syrian) | 1 yr; 5 d/wk; 6 hr/d | | | | | | | 5 | M | (CEL: nasal adenomatous polyp) | Vernot et al. 1985; H

a The number corresponds to entries in Figure 2-1.

b Used to derive an intermediate inhalation minimal risk level (MRL) of 2 X 10^−4^ ppm for 1,1-dimethylhydrazine; dose adjusted for intermittent exposure, converted to Human Equivalent Concentration (HEC), and divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans following conversion to HEC and 10 for human variability).

c Used to derive an intermediate inhalation minimal risk level (MRL) of 4 X 10^−3^ ppm for hydrazine; converted to Human Equivalent Concentration (HEC), and divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans following conversion to HEC, and 10 for human variability).

11DMH = 1,1-dimethylhydrazine; Bd Wt = body weight; Cardio = cardiovascular; CEL = cancer effect level; (cont) = continuous; d = day(s); Derm/oc = dermal/ocular; Gastro = gastrointestinal; H = hydrazine; Hemato = hematological; hr = hour(s); LOAEL = lowest-observed-adverse-effect level; mo = month(s); Musc/skel = musculoskeletal; NOAEL = no-observed-adverse-effect level; ppm = parts per million; Resp = respiratory; wk = week(s); yr = year(s).

Figure 2-1 Levels of Significant Exposure to Hydrazines - Inhalation

Acute (≤14 days)

Intermediate (15-364 days)

Chronic (≥365 days)

No adverse effects were noted on the cardiovascular system of dogs exposed intermittently to 25 ppm 1,1-dimethylhydrazine for 13-26 weeks (Rinehart et al. 1960). In mice exposed to 0.05-5 ppm 1,l-dimethylhydrazine for 6 months to 1 year, the blood vessels were abnormally dilated (angiectasis) (Haun et al. 1984). However, no clinical or histopathological effects were noted on the cardiovascular system of mice exposed intermittently to 1 ppm hydrazine for 1 year (Vernot et al. 1985). The findings of the animal studies are inconsistent with the effects reported in the human case study and suggest that effects noted may not have been related to exposure. However, this is not certain.

Gastrointestinal Effects. No studies were located regarding gastrointestinal effects in humans after inhalation exposure to hydrazines.

No histopathological changes were observed in the gastrointestinal tract of dogs intermittently exposed to 25 ppm 1,l-dimethylhydrazine for 13-26 weeks (Rinehart et al. 1960) or in mice intermittently exposed to 1 ppm hydrazine for 1 year (Vernot et al. 1985). Although these data are limited, they suggest that the gastrointestinal system is not a primary target of the noncarcinogenic effects of hydrazine or 1,l -dimethylhydrazine.

Hematological Effects. No studies were located regarding the hematological effects in humans after inhalation exposure to hydrazines.

Mild anemia (17-26% decreases in red blood cell count, hemoglobin, and hematocrit) was observed in dogs intermittently exposed (5 days/week, 6 hours/day) to 5 ppm l,l-dimethylhydrazine for 24 weeks (Rinehart et al. 1960). Anemia was more pronounced (28-60% decreases in above described parameters) at a higher concentration (25 ppm) of l,l-dimethylhydrazine after 4 weeks of intermittent exposure. In dogs exposed continuously to 1 ppm hydrazine for 6 months, hemoglobin, hematocrit, and red blood cell count were all significantly reduced (approximately 25-30%) (Haun and Kinkead 1973). These effects were not observed in dogs exposed to 0.2 ppm hydrazine in this study. Hematological effects were not observed in rats, dogs, and hamsters exposed to 0.5 and3 ppm 1,1-dimethylhydrazine for 6 months (Haun et al. 1984). The lack of an anemic effect of purified l,ldimethylhydrazines in the dogs of this study is inconsistent with the observations made by Rinehart et al. (1960) in dogs exposed to the same concentration for a shorter duration. It is possible that impurities of the l,l-dimethylhydrazine (for example, dimethylnitrosamine) used by Rinehart et al. (1960) contributed to the anemic response. Alternatively, the anemic effects of hydrazine and l,l-dimethylhydrazine may be related to their ability to react with pyridoxine (see Section 2.35); a deficiency of this vitamin results in anemia (NAS 1989).

No adverse effects were reported for a large number of hematological parameters in rats or monkeys exposed to 1 ppm hydrazine continuously for 6 months (Haun and Kinkead 1973). In dogs, the anemic effects of hydrazine in this study and l,l-dimethylhydrazine in the Rinehart et al. (1960) study appear to be fairly similar, and the data suggest that dogs may be particularly sensitive to the hematological effects of these compounds. However, some questions remain, considering the results with dogs seen by Haun et al. (1984), cited above. Rats (Haun and Kinkead 1973; Haun et al. 1984), monkeys (Haun and Kinkead 1973), and hamsters (Haun et al. 1984) appear to be relatively insensitive to the hematological effects of these compounds.

Musculoskeletal Effects. No studies were located regarding musculoskeletal effects in humans after inhalation exposure to hydrazines.

No studies were located regarding musculoskeletal effects in animals after inhalation exposure to 1,l -dimethylhydrazine. No musculoskeletal effects were observed in mice exposed intermittently to 1 ppm hydrazine for 1 year (Vernot et al. 1985).

Hepatic Effects. A single case study reported areas of focal necrosis and cell degeneration in the liver of a worker exposed to an undetermined concentration of hydrazine in air once a week for 6 months (Sotaniemi et al. 1971). Studies of workers exposed to l,l-dimethylhydrazine have reported changes indicative of a hepatic effect including elevated serum alanine aminotransferase activity, fatty degeneration, and a positive cephalin flocculation test (Petersen et al. 1970; Shook and Cowart 1957). Although the levels of hydrazine and l,l-dimethylhydrazine exposure were not determined, these studies indicate qualitatively that the liver is a target for both hydrazines.

In dogs exposed intermittently to 5 ppm l,l-dimethylhydrazine for 8.5 weeks, cytoplasmic degeneration of the liver was observed (Haun 1977). Hemosiderosis of the spleen was observed in dogs exposed intermittently to 5 ppm 1,1-dimethylhydrazine for 26 weeks, and the same effect was observed in the Kupffer cells of the liver after exposure to 25 ppm for 13 weeks (Rinehart et al. 1960). Dogs exposed to 5 ppm 1,1-dimethylhydrazine for 6 months showed transitory increases in serum glutamic pyruvic transaminase (SGPT) levels which returned to normal during the postexposure recovery period (Haun et al. 1984). This study also found impaired liver function at the same dose level as measured by retention of injected bromosulphalein after a 6-month exposure to 1,l-dimethylhydrazine. Fatty changes were observed in the livers of mice, dogs, and monkeys exposed continuously to 0.2-1 ppm hydrazine for 6 months (Haun and Kinkead 1973). The hepatotoxic effects of hydrazine were notably more severe in mice than in dogs or monkeys and were responsible for the increased mortality observed in this species. Based on a LOAEL of 0.2 ppm for liver effects in mice, an intermediate inhalation MRL of 4X10^−3^ ppm was calculated for hydrazine as described in footnote “c” in Table 2-1. Intermittent exposure to 0.25-1 ppm hydrazine for 1 year resulted in a number of hepatic effects in rats, dogs, and hamsters including focal cellular change, vacuolated cells, elevated serum transaminases, amyloidosis, hemosiderosis, and bile duct hyperplasia (Vemot et al. 1985). The NOAEL values for hepatic effects range from 0.25 to 1 ppm for rats, mice, and dogs in this study. In addition, hamsters appeared to be the most sensitive species to hydrazineinduced hepatic effects, whereas mice appeared to be the most resistant.

In rats and mice, exposure to 0.05-5 ppm l,l-dimethylhydrazine for 6 months to 1 year produced fatty changes, angiectasis, hyaline degeneration of the gall bladder, and congestion in the liver (Haun et al. 1984). Based on a LOAEL of 0.05 ppm, an intermediate inhalation MRL of 2X10^−4^ ppm was calculated for 1, 1-dimethylhydrazine as described in footnote “b” in Table 2-1.

Collectively, these data clearly indicate that the liver is a target for hydrazine and l,l-dimethylhydrazine toxicity. Furthermore, species differences are apparent in the sensitivity to hepatotoxicity. However, these data are inconsistent (mice were the most sensitive in one study but the most resistant in another) and suggest that strain differences in sensitivity may also exist in mice. It should be noted that dimethylnitrosamine, a potent liver toxin, occurs as a contaminant of technical grades of l,l-dimethylhydrazine and may contribute to the hepatotoxic effects observed in animals following exposure to this compound (Haun 1977). A single study reported hyaline degeneration of the gall bladder in mice exposed to 0.05 ppm l,l-dimethylhydrazine for 6 months (Haun et al. 1984).

Renal Effects. No studies were located regarding renal effects in humans after inhalation exposure to 1,1 -dimethylhydrazine. A single case study reported renal effects including tubular necrosis, hemorrhaging, inflammation, discoloration, and enlargement in a worker exposed to 0.07 mg/m^3^ (0.05 ppm) hydrazine once a week for 6 months (Sotaniemi et al. 1971). These renal effects were severe and were a contributing factor in the death of this worker.

Renal effects were not observed in dogs exposed intermittently to 25 ppm l,l-dimethylhydrazine for 13-26 weeks (Rinehart et al. 1960). Mild renal effects including amyloidosis and mineralization were observed in hamsters exposed intermittently to 0.25 ppm hydrazine for 1 year (Vemot et al. 1985); however, no effects were noted in the kidneys of mice exposed intermittently to 1 ppm hydrazine for 1 year (Vemot et al. 1985). The findings of these animal studies are inconsistent with the severe effects observed in the human case study. However, more severe effects on the kidney have been observed in animals exposed to hydrazines by other routes (see Sections 2.2.2.2 and 2.4).

Ocular Effects. No studies were located regarding ocular effects in humans after inhalation exposure to l,l-dimethylhydrazine. A single case of a worker exposed to an undetermined concentration of hydrazine once a week for 6 months reported conjunctivitis (Sotaniemi et al. 1971). Since the conjunctivitis was repeatedly observed on each day the worker was exposed, continuing through to the following day, this effect is clearly related to hydrazine exposure.

No studies were located regarding ocular effects in animals after inhalation exposure to 1,l -dimethylhydrazine. Minimal irritation of the eyes was noted in monkeys during the first few weeks of exposure to 1 ppm hydrazine (Haun and Kinkead 1973). This effect was not observed in monkeys exposed to 0.2 ppm hydrazine (Haun and Kinkead 1973), or in mice exposed intermittently to 1 ppm hydrazine for 1 year (Vemot et al. 1985). Although these data are internally inconsistent, the data from monkeys are consistent with the human data which suggest that hydrazine acts as an irritant to the eyes.

Body Weight Effects. No studies were located regarding body weight effects in humans after inhalation exposure to hydrazine or l,l-dimethylhydrazine.

Several studies in animals have reported decreased body weight gain. Male and female rats and male hamsters experienced significantly decreased body weight gains compared to controls during a lo-week period of exposure to 750 ppm hydrazine (1 hour/week) (Latendresse et al. 1995). Weight gains returned to normal during the subsequent recovery period. Body weight gain was reduced in rats and dogs exposed continuously to 1 ppm hydrazine for 6 months (Haun and Kinkead 1973), and in dogs exposed to 5 ppm l,l-dimethylhydrazine 6 hours/day, 5 days/week, for 26 weeks (Rinehart et al. 1960), or 5 ppm hydrazine for the same dosing regimen (Comstock et al. 1954). No effects in body weight gain were observed in several species exposed to concentrations of 0.2-1 ppm hydrazine or 5 ppm l,l-dimethylhydrazine for 6 months (Haun and Kinkead 1973; Haun et al. 1984). Chronic exposure to 0.25 ppm hydrazine caused a 14% loss of body weight in hamsters (Vernot et al. 1985). A similar decrease in body weight gain was noted in mice exposed to 5 ppm l,l-dimethylhydrazine for 1 year (Haun et al. 1984).

#### 2.2.1.3 Immunological and Lymphoreticular Effects

No studies were located regarding immunological and lymphoreticular effects in humans or animals after inhalation exposure to hydrazines.

#### 2.2.1.4 Neurological Effects

Data regarding the neurological effects of hydrazines in humans are limited to several case studies. Acute exposure to an undetermined concentration of a hydrazine/l,l-dimethylhydrazine mixture in air resulted in trembling, twitching, clonic movements, hyperactive reflexes, and weakness in two cases (Frierson 1965). Nausea, vomiting, and tremors were observed in a worker exposed to an undetermined levels of hydrazine in air once a week for 6 months (Sotaniemi et al. 1971). Difficulties in concentration, comprehension, memory, and task performance, as well as changes in mood status were noted in a water technician occupationally exposed to an undetermined concentration of hydrazine in air (Richter et al. 1992). Slow, gradual improvement was noted in the latter case after the subject was removed from exposure. Although limited, these studies suggest that inhalation exposure to hydrazine and l,l-dimethylhydrazine can adversely affect the central nervous system in humans.

In dogs exposed intermittently to 25 ppm l,l-dimethylhydrazine, depression, ataxia, salivation, emesis, and seizures were noted after 3 days (Rinehart et al. 1960). These effects were not observed in dogs exposed to 5 ppm for 26 weeks. Tonic convulsions were noted in one of eight dogs exposed continuously to 1 ppm hydrazine for 6 months but were not observed in any dogs exposed to 0.2 ppm (Haun and Kinkead 1973). Tremors were observed occasionally in rats and mice exposed continuously to 75 ppm l,l-dimethylhydrazine (Rinehart et al. 1960). These data confirm the observations from human studies and indicate that the central nervous system is a target for the toxicity of inhaled hydrazine or l,l-dimethylhydrazine. The highest NOAEL values and all LOAEL values from each reliable study for neurological effects resulting from inhalation exposure to hydrazines are recorded in Table 2-1 and plotted in Figure 2-1.

#### 2.2.1.5 Reproductive Effects

No studies were located regarding reproductive effects in humans after inhalation exposure to hydrazines.

Endometrial cysts were noted in female mice exposed to 0.05 ppm l,l-dimethylhydrazine for 6 months (Haun et al. 1984). The incidence of endometrial cysts were also elevated in female mice exposed to 5 ppm l,l-dimethylhydrazine for 1 year (Haun et al. 1984); however, this increase was not statistically significant. Furthermore, this type of lesion is common to aged female mice and therefore may not be related to treatment. In female rats exposed intermittently to 5 ppm hydrazine for 1 year, atrophy of the ovaries and inflammation of the endometrium and fallopian tube were noted (Vernot et al. 1985). Senile testicular atrophy was observed in male hamsters exposed to 1 ppm hydrazine for 1 year but not in hamsters exposed to 0.25 ppm hydrazine (Vernot et al. 1985). An absence of sperm production was observed in hamsters exposed to 5 ppm. The study authors noted that the changes observed in male hamsters are normally associated with aging and that exposure to hydrazine seemed to accelerate these changes. However, available studies suggest that hydrazine and l,l-dimethylhydrazine can produce serious reproductive effects. A complete assessment of the reproductive toxicity of hydrazines cannot be made since reproductive function was not determined in these studies. The highest NOAEL values and all LOAEL values from each reliable study for reproductive effects resulting from inhalation exposure to hydrazines are recorded in Table 2-1 and plotted in Figure 2-1.

#### 2.2.1.6 Developmental Effects

No studies were located regarding developmental effects in humans or animals after inhalation exposure to hydrazines.

#### 2.2.1.7 Genotoxic Effects

No studies were located regarding genotoxic effects in humans or animals after inhalation exposure to hydrazines.

Genotoxicity studies are discussed in Section 2.5.

#### 2.2.1.8 Cancer

A single epidemiological study reported no significant increase in cancer mortality in a group of men (n=427) occupationally exposed to an undetermined concentration of hydrazine in air (Wald et al. 1984). Although this study reported no evidence of a carcinogenic effect for hydrazine, the follow-up period was relatively short and only 49 deaths were observed. However, when the workers were observed for another 10 years, there was still no significant increase in cancer mortality (Morris et al. 1995).

Exposure to 0.05-0.5 ppm l,l-dimethylhydrazine for 6 months produced an increased incidence of leukemia and tumors of the pancreas, pituitary, blood vessels, liver, and thyroid in mice and/or rats (Haun et al. 1984). Tumors of the lung, liver, nasal cavity, bone, and blood vessels were observed in mice exposed to 5 ppm l,l-dimethylhydrazine for 1 year (Haun et al. 1984). A significantly increased incidence (p≤0.05) of nasal tumors and thyroid carcinomas was observed in male rats exposed intermittently to 1 and 5 ppm hydrazine, respectively, for 1 year (Vernot et al. 1985). Hamsters and rats exposed to 750 ppm hydrazine once for 1 hour, or 1 hour per week for 10 weeks, exhibited increased incidences of squamous metaplasia, hyperplasia, and neoplasia in the nose (Latendresse et al. 1995). Nasal tumors were also noted in hamsters and female rats intermittently exposed to 5 ppm hydrazine for 1 year (Vemot et al. 1985). Tumor incidence was not significantly increased in mice and dogs exposed intermittently to 1 ppm hydrazine for 1 year (Vernot et al. 1985). The studies suggest that hydrazine and l,l-dimethylhydrazine are carcinogenic by the inhalation route. All CEL values from each reliable study resulting from inhalation exposure to hydrazines are recorded in Table 2-1 and plotted in Figure 2-1.

The EPA has derived an inhalation unit risk of 0.0049 (µg/m^3^)^−1^ for hydrazine based on nasal cavity tumors, and an inhalation unit risk of 0.001 (µg/m^3^)^−1^ for l,l-dimethylhydrazine based ontumor of the respiratory system (HEAST 1992; IRIS 1995). Although no studies were located regarding the carcinogenic effects of 1,2-dimethylhydrazine following inhalation exposures, EPA has derived an inhalation unit risk of 0.011 (µg/m^3^)^−1^ for 1,2-dimethylhydrazine (HEAST 1992), based on extrapolation of cancer data for oral exposures (see Section 2.2.2.8). The concentrations of hydrazine, 1, 1-dimethylhydrazine, and 1,2-dimethylhydrazine corresponding to excess cancer risks of 10^−4^ to 10^−7^. are shown in Figure 2-1.

### 2.2.2 Oral Exposure

#### 2.2.2.1 Death

No studies were located regarding lethal effects in humans after oral exposure to hydrazines.

Acute oral LD_50_ values of 11.7 and 27.1 mg/kg have been reported for 1,2-dimethylhydrazine in male and female mice, respectively (Visek et al. 1991). Mortality was 100% in mice given a single dose of 90 mg/kg 1,2-dimethylhydrazine (Visek et al. 1991) and in mice given 133 mg/kg/day hydrazine or 533 mg/kg/day l,l-dimethylhydrazine for 5 days (Roe et al. 1967). Death occurred in two of two dogs administered weekly doses of 60 mg/kg 1,2-dimethylhydrazine for 2 weeks (Wilson 1976). For intermediate exposures, doses of 2.3 and 4.9 mg/kg/day hydrazine for 15-25 weeks increased mortality in mice and hamsters, respectively (Biancifiori 1970). Exposure to 33 mg/kg/day l,l-dimethylhydrazine killed two of five mice exposed for 4-21 weeks (Roe et al. 1967). Mortality was 62.5-100% following intermediate-duration exposures to 1,2-dimethylhydrazine in rats given 13.6 mg/kg/day (Teague et al. 1981), guinea pigs given 60 mg/kg/day (Wilson 1976), dogs administered 15 mg/kg/day (Wilson 1976), pigs administered 60 mg/kg/day (Wilson 1976), and in mice given 4.5-5.1 mg/kg/day (Visek et al. 1991). Mortality in mice was 100% after chronic exposure to 0.95 mgfkg/day via the drinking water (Toth and Patil 1982). These data indicate that large doses of hydrazines are lethal by the oral route. Furthermore, male mice were 2-3 times more sensitive to the acutely lethal effects of 1,2-dimethylhydrazine than female mice (Visek et al. 1991), suggesting that there may be important sex differences. However, this was only observed in a single study. All LOAEL values from each reliable study for lethality are recorded in Table 2-2 and plotted in Figure 2-2.

#### 2.2.2.2 Systemic Effects

No studies were located regarding any systemic effects in humans after oral exposure to hydrazines. Also, no studies were located regarding the hematological effects in animals after oral exposure to hydrazines. The available studies regarding systemic effects in animals after oral exposure to hydrazines are described below. The highest NOAEL values and all LOAEL values for systemic effects in animals resulting from oral exposure to hydrazines are recorded in Table 2-2 and plotted in Figure 2-2.

Respiratory Effects. No adverse histological effects were observed in the lungs of mice exposed to 9.5 mg/kg/day hydrazine via the drinking water for 2 years (Steinhoff et al. 1990). No other studies were located regarding respiratory effects in animals ingesting hydrazines.

Cardiovascular Effects. Focal myocytolysis, fibrosis, and calcification of the heart were observed in mice receiving 1.6 mg/kg/day 1,2-dimethylhydrazine in the feed for 5 months (Visek et al. 1991). These effects were not observed in mice receiving 0.75 mg/kg/day. No adverse histological effects were observed in the hearts of mice receiving 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). These data are too limited to make firm conclusions regarding the cardiovascular effects of hydrazines.

Gastrointestinal Effects. Although oral exposure to hydrazine has produced nausea in humans, this effect is probably due to effects on the central nervous system and is therefore discussed in Section 2.2.2.4.

Proliferative foci were noted in the colons of rats receiving two doses of 25 mg/kg 1,2-dimethylhydrazine within a 4-day period (Cademi et al. 1991). No adverse histological effects were observed in the gastrointestinal tracts of mice receiving 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). These data are too limited to make firm conclusions regarding the gastrointestinal effects of hydrazines.

Musculoskeletal Effects. No adverse effects were observed in the muscle tissue of mice receiving 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). No other studies were located regarding the effects of hydrazines on the musculoskeletal system.

Hepatic Effects. A number of studies in animals have reported effects on the liver after oral exposure to hydrazines. In rats and mice, relatively mild effects on the liver such as megamitochondria formation, increased lipogenesis, and fatty changes occurred following acute exposure to 49-650 mg/kg/day hydrazine (Marshall et al. 1983; Preece et al. 1992b; Wakabayashi et al. 1983). More notable effects, including degeneration, hemorrhage, and necrosis of the liver, were observed in dogs administered weekly doses of 60 mg/kg 1,2-dimethylhydrazine for 2 weeks (Wilson 1976). Intermediate-duration exposure to 1,2-dimethylhydrazine produced liver damage (hemosiderosis, necrosis, hepatitis, fibrosis, ascites and/or failure) in rats receiving 4.2 mg/kg/day (Bedell et al. 1982), guinea pigs receiving 30 mg/kg/day or more (Wilson 1976), mice receiving 0.75 mg/kg/day or more (Visek et al. 1991), dogs receiving 5 mg/kg/day or more (Wilson 1976), and pigs receiving 30 mg/kg/day (Wilson 1976). Cirrhosis, reticuloendothelial cell proliferation, bile duct proliferation, and degenerative fibrous cells were observed in the livers of hamsters exposed to 4.9 mg/kg/day hydrazine for 15-20 weeks (Biancifiori 1970). No adverse effects were observed in the livers of mice receiving 9.5 mg/kg/day hydrazine for 2 years (Steinhoff et al. 1990). Collectively, these data indicate that hydrazine and 1,2-dimethylhydrazine are hepatotoxic by the oral route. Based on a LOAEL of 0.75 mg/kg/day for hepatic effects in mice (Visek et al. 1991), an intermediate oral MRL of 8X10^−4^ mg/kg/day was calculated for 1,2-dimethylhydrazine as described in footnote “b” in Table 2-2.

TABLE 2-2 Levels of Significant Exposure to Hydrazines - Oral

Key^a^ to figure | Species/(Strain) | Exposure/Duration/Frequency (Specific Route) | System | NOAEL (mg/kg/day) | | LOAEL | | | | | | Reference Chemical Form
Key^a^ to figure | Species/(Strain) | Exposure/Duration/Frequency (Specific Route) | System | NOAEL (mg/kg/day) | | Less Serious (mg/kg/day) | | | Serious (mg/kg/day) | | | Reference Chemical Form
| ACUTE EXPOSURE
| Death
1 | Mouse; (B6C3F1) | Once; (GW) | | | | | | | 11.7 | M | (LD50) | Visek et al. 1991; 12DMH
| | | | | | | | | 27.1 | F | (LD50)
2 | Mouse; (B6C3F1) | Once; (GW) | | | | | | | 90 | B | (100% mortality) | Visek et al. 1991; 12DMH
3 | Mouse; (Swiss) | 1 wk; 5 ×/wk; (GW) | | | | | | | 533 | F | (5/5 deaths) | Roe et al. 1967; 11DMH
4 | Mouse; (Swiss) | 1 wk; 5 ×/wk; (GW) | | | | | | | 133 | F | (5/5 deaths) | Roe et al. 1967; H
5 | Dog; (NS) | 2 wk; 1 ×/wk; (GW) | | | | | | | 60 | M | (2/2 deaths) | Wilson 1976; 12DMH
| Systemic
6 | Rat; (Sprague-Dawley) | 4 d; 2 ×; (G) | Gastro | | | 25 | F | (proliferative foci in colon) | | | | Caderni et al. 1991; 12DMH
7 | Rat; (Sprague-Dawley) | Once; (GW) | Hepatic | 27 | M | 81 | M | (fatty liver) | | | | Preece et al. 1992a; HS
8 | Rat; (Wistar) | Once; (GW) | Hepatic | | | 49 | F | (increased lipogenesis) | | | | Marshall et al. 1983; HS
9 | Dog; (NS) | 2 wk; 1 ×/wk; (GW) | Hepatic | | | | | | 60 | M | (hepatic degeneration and hemorrhagic necrosis) | Wilson 1976; 12DMH
| | 2 wk; 1 ×/wk; (GW) | Bd Wt | | | 60 | M | (unspecified decrease in weight loss)
| Developmental
10 | Hamster; (Syrian Golden) | Once; Gd 12; (GW) | | 166 | F | | | | | | | Schiller et al. 1979; H
11 | Hamster; (Syrian Golden) | Once; Gd 12; (GW) | | 68 | F | | | | | | | Schiller et al. 1979; 12DMH
| Cancer
12 | Rat; (Fischer) | Once; (GW) | | | | | | | 15.8 | M | (CEL: colonic epithelial polypoid tumors) | Schiller et al. 1980; 12DMH
13 | Rat; (Sprague-Dawley) | Once; (G) | | | | | | | 30 | M | (CEL: colon adenocarcinomas) | Craven and DeRubertis 1992; 12DMH
14 | Rat; (Sprague-Dawley) | Once; (GW) | | | | | | | 15.8 | M | (CEL: colonic adenocarcinomas or mucinous adenocarcinomas | Watanabe et al. 1985; 12DMH
| INTERMEDIATE EXPOSURE
| Death
15 | Rat; (DA, HS, AS2) | 10 wk; 1 ×/wk; (GW) | | | | | | | 13.6 | B | (100% mortality) | Teague et al. 1981; 12DMH
16 | Mouse; (B6C3F1) | 6 wk; ad libitum; (F) | | | | | | | 5.1 | M | (100% mortality in males) | Visek et al. 1991; 12DMH
| | 6 wk; ad libitum; (F) | | | | | | | 4.5 | F | (100% mortality in females)
17 | Mouse; (CBA) | 25 wk; 150 ×; (GW) | | 1.1 | B | | | | 2.3 | B | (38/50 deaths by 80 weeks) | Biancifiori 1970; HS
18 | Mouse; (Swiss) | 4-21 wk; 5×/wk; (GW) | | | | | | | 33 | F | (2/5 deaths) | Roe et al. 1967; 11DMH
19 | Hamster; (Syrian golden) | 15-20 wk; 60-100 ×; (GW) | | | | | | | 4.9 | B | (32/35 deaths by week 50) | Biancifiori 1970; HS
20 | Dog; (NS) | 4-10 wk; 1 ×/wk; (GW) | | | | | | | 15 | M | (9/10 deaths) | Wilson 1976; 12DMH
21 | Pig; (Miniature) | 10 wk; 1 ×/wk; (GW) | | | | | | | 60 | M | (5/8 deaths) | Wilson 1976; 12DMH
22 | Gn pig; (Hartley) | 7-10 wk; 1 ×/wk; (GW) | | | | | | | 60 | M | (5/6 deaths) | Wilson 1976; 12DMH
| Systemic
23 | Rat; (Fischer-344) | <10 mo; ad libitum; (W) | Hepatic | | | | | | 4.2 | M | (hepatic DNA alteration) | Bedell et al. 1982; 12DMH
24 | Rat; (Sprague-Dawley) | 9 wk; 1 ×/wk; (GW) | Bd Wt | 15 | B | 30 | B | (10% decrease in body weight gain) | | | | Barbolt and Abraham 1980; 12DMH
25 | Mouse; (B6C3F1) | 5 mo; ad libitum; (F) | Cardio | 0.75 | M | | | | 1.6 | M | (myocytolysis, fibrosis, and calcification | Visek et al. 1991; 12DMH
| | 5 mo; ad libitum; (F) | Hepatic | | | 0.75 ^b^ | M | (mild hepatitis) | 1.6 | M | (hepatitis, centrilobular necrosis, and hepatocellular hypertrophy)
| | | Renal | 0.75 | M | | | | 1.6 | M | (interstitial nephritis and pyelonephritis)
26 | Mouse; (B6C3F1) | 6 wk; ad libitum; (F) | Hepatic | | | 1.4 | B | (decrease of 1.3% in relative liver weight) | | | | Visek et al. 1991; 12DMH
27 | Mouse; (CBA) | 25 wk; 150 ×; (GW) | Endocr | | | 1.1 | F | (brown degeneration of the adrenals) | | | | Biancifiori 1970; HS
28 | Hamster; (Golden) | 15-20 wk; 60-100 ×; (GW) | Hepatic | | | | | | 4.9 | B | (cirrhosis, cell proliferation, degenerative changes) | Biancifiori 1970; HS
| | 15-20 wk; 60-100 ×; (GW) | Endocr | 5.3 | B
29 | Dog; (NS) | 4-10 wk; 1 ×/wk; (GW) | Hepatic | | | | | | 5 | M | (mild hepatic fibrosis, hemosiderosis, and ascites) | Wilson 1976; 12DMH
| | 4-10 wk; 1 ×/wk; (GW) | | | | | | | 15 | M | (hepatic failure)
30 | Pig; (Miniature) | 10 wk; 1 ×/wk; (GW) | Hepatic | | | | | | 30 | M | (focal megalocytosis and postfibrotic necrosis of the liver) | Wilson 1976; 12DMH
31 | Gn pig; (Hartley) | 7-10 wk; 1 ×/wk; (GW) | Hepatic | | | | | | 30 | M | (hepatic necrosis and ascites) | Wilson 1976; 12DMH
| | 7-10 wk; 1 ×/wk; (GW) | Bd Wt | | | | | | 30 | M | (severe but unspecified decrease in body weight gain)
| Immunological/Lymphoreticular
32 | Rat; (Sprague-Dawley) | 5 wk; 1 ×/wk; (GW) | | 27.1 | M | | | | | | | Locniskar et al. 1986; 12DMH
| Neurological
33 | Human | 1-47 d; 3 ×/d; (C) | | | | 0.6 | B | (dizziness) | | | | Spremulli et al. 1979; HS
34 | Human | 1-6 mo; 3 ×/d; (C) | | | | | | | 0.6 | B | (nausea, vomiting, dizziness, excitement, insomnia, and polyneuritic syndrome) | Gershanovich et al. 1981; HS
35 | Human | 30 d; 3 ×/d; (C) | | | | 0.7 | B | (nausea, transient dizziness) | | | | Chlebowski et al. 1984; HS
| Reproductive
36 | Mouse; (CBA) | 25 wk; 150 ×; (GW) | | 9.3 | B | | | | | | | Biancifiori 1970; HS
37 | Hamster; (Golden) | 15-20 wk; 60-100 ×; (GW) | | 5.3 | B | | | | | | | Biancifiori 1970; HS
| Cancer
38 | Rat; (DA, HS, AS2) | 10 wk; 1 ×/wk; (GW) | | | | | | | 4.5 | B | (CEL: liver angiosarcoma, cholangioma, hepatocellular carcinoma, bowel adenocarcinoma) | Teague et al. 1981; 12DMH
| | | | | | | | | 13.6 | B | (CEL: ear canal papilloma)
39 | Rat; (Fischer-344) | 5 wk; 1 ×/wk; (GO) | | | | | | | 30 | M | (CEL: adenomas and adenocarcinomas of the small intestine and colon) | Calvert et al. 1987; 12DMH
40 | Rat; (Fischer-344) | <10 mo; ad libitum; (W) | | | | | | | 4.2 | M | (CEL: angiosarcoma of the liver and lung, hepatocellular carcinoma, renal adenoma and mesenchymal tumors) | Bedell et al. 1982; 12DMH
41 | Rat; (NS) | 11 wk; 1 ×/wk or 5 d/wk; (G) | | | | | | | 3 | NS | (CEL: hemangioendotheliomas of the liver) | Druckrey 1970; 12DMH
| | 11 wk; 1 ×/wk or 5 d/wk; (G) | | | | | | | 21 | NS | (CEL: carcinomas of the colon, small intestine, and rectum)
42 | Rat; (S-D, Lobund-Wistar, Buffalo) | 10 wk; 1 ×/wk; (GW) | | | | | | | 30 | B | (CEL: gastrointestinal adenocarcinomas) | Asano and Pollard 1978; 12DMH
43 | Rat; (Sprague-Dawley) | 4-8 wk; 1 ×/wk; (GW) | | | | | | | 30 | M | (CEL: colon and squamous cell carcinoma of the ear) | Wilson 1976; 12DMH
44 | Rat; (Sprague-Dawley) | 5 wk; 1 ×/wk; (GW) | | | | | | | 27.1 | M | (CEL: carcinomas of the colon and small intestine) | Locniskar et al. 1986; 12DMH
45 | Rat; (Sprague-Dawley) | 9 wk; 1 ×/wk; (GW) | | | | | | | 30 | M | (CEL: gastrointestinal adenomas and adenocarcinomas) | Abraham et al. 1980; 12DMH
46 | Rat; (Sprague-Dawley) | 9 wk; 1 ×/wk; (GW) | | | | | | | 15 | B | (CEL: colon adenoma and adenocarcinoma) | Barbolt and Abraham 1980; 12DMH
| | | | | | | | | 30 | B | (CEL: duodenal adenocarcinoma)
47 | Rat; (Wistar) | 10 wk; 1 ×/wk; (GW) | | | | | | | 9 | M | (CEL: colorectal adenoma, adenocarcinoma, and signet ring cell carcinoma) | Thorup et al. 1992; 12DMH
48 | Mouse; (A/J) | 33-48 wk; ad libitum; (W) | | | | | | | 0.46 | M | (CEL: lung adenomas and adenocarcinomas) | Yamamoto and Weisburger 1970; HS
49 | Mouse; (BALB/c) | 24 wk; 1 ×/wk; (GW) | | | | | | | 30 | F | (CEL: angiosarcomas predominantly in the liver, adenomas and adenocarcinomas of the lungs and large intestines, and squamous cell carcinomas of the anus) | Izumi et al. 1979; 12DMH
50 | Mouse; (Balb/c) | 46 wk; 1 ×/d; (GW) | | | | | | | 9.3 | F | (CEL: pulmonary adenomas and adenocarcinomas) | Biancifiori and Ribacchi 1962; HS
51 | Mouse; (BALB/c) | 10-48 wk; ad libitum; (W) | | | | | | | 1.9 | B | (CEL: hemangiomas and hemangioendotheliomas predominantly in the liver, adenomas and adenocarcinomas of the lungs) | Izumi et al. 1979; 12DMH
| | | | | | | | | 15.2 | B | (CEL: adenomas and adenocarcinomas of the large intestine and squamous cell carcinomas of the anus)
52 | Mouse; (CBA) | 25 wk; 150 ×; (GW) | | | | | | | 2.3 | B | (CEL: hepatomas) | Biancifiori 1970; HS
53 | Mouse; (CBA) | 36 wk; 7 d/wk; 1 ×/d; (GW) | | | | | | | 9.2 | B | (CEL: lung adenomas adenocarcinomas, hepatomas) | Biancifiori et al. 1964; HS
54 | Mouse; (Swiss) | 40 wk; 5 ×/wk; (GW) | | | | | | | 16.7 | F | (CEL: lung adenomas and adenocarcinomas) | Roe et al. 1967; H
55 | Mouse; (Swiss) | 40 wk; 5 ×/wk; (GW) | | | | | | | 33 | F | (CEL: lung adenomas and adenocarcinomas) | Roe et al. 1967; 11DMH
56 | Mouse; (Swiss, A, C17, ICRC×C3H) | 4-11 mo; 6 ×/wk; (G) | | | | | | | 9 | B | (CEL: adenocarcinomas of the lungs and breast) | Bhide et al. 1976; HS
57 | Gn pig; (Hartley) | 7-10 wk; 1 ×/wk; (GW) | | | | | | | 30 | M | (CEL: hepatomas and bile duct cell carcinomas) | Wilson 1976; 12DMH
| CHRONIC EXPOSURE
| Death
58 | Mouse; (Swiss) | Lifetime; ad libitum; (W) | | | | | | | 0.95 | B | (100% mortality by week 70) | Toth and Patil 1982; 12DMH
| Systemic
59 | Mouse; (NMRI) | 2 yr; ad libitum; (W) | Resp | 9.5 | B | | | | | | | Steinhoff et al. 1990; HH
| | | Cardio | 9.5 | B
| | | Gastro | 9.5 | B
| | | Musc/skel | 9.5 | B
| | | Hepatic | 9.5 | B
| | | Renal | 9.5 | B
| | | Derm | 9.5 | B
| | | Bd Wt | 1.9 | B | 9.5 | B | (reduced body weight gain by 10%, and ruffled coats)
| Cancer
60 | Rat; (CBRI/SE) | 68 wk; 215 ×; (GW) | | | | | | | 12 | B | (CEL: lung adenomas and carcinomas) | Biancifiori et al. 1966; HS
61 | Mouse; (Swiss) | 55 wk; 5 d/wk; 1 ×/d; (GW) | | | | | | | 9 | B | (CEL: lung tumors) | Maru and Bhide 1982; HS
62 | Mouse; (Swiss) | Lifetime; ad libitum; (W) | | | | | | | 1.9 | B | (CEL: lung adenomas) | Toth 1972b; H
63 | Mouse; (Swiss) | Lifetime; ad libitum; (W) | | | | | | | 19 | B | (CEL: angiosarcomas predominantly in the liver, hepatomas, adenomas and adenocarcinomas of the lungs, and adenomas of the kidneys) | Toth 1973a; 11DMH
64 | Mouse; (Swiss) | Lifetime; ad libitum; (W) | | | | | | | 0.059 | B | (CEL: angiomas and angiosarcomas) | Toth and Patil 1982; 12DMH
65 | Mouse; (Swiss, A, C17, ICRC×C3H) | 13-18 mo; 6 ×/wk; (G) | | | | | | | 9 | B | (CEL: adenocarcinomas of the lungs and breast) | Bhide et al. 1976; HS
66 | Mouse; (Swiss, C3H, AKR) | Lifetime; ad libitum; (W) | | | | | | | 5.6 | B | (CEL: lung adenomas and adenocarcinomas) | Toth 1969; HS
67 | Hamster; (Syrian Golden) | 2 yr; ad libitum; (W) | | | | | | | 8.3 | M | (CEL: hepatocellular carcinoma, adrenal cortical adenoma) | Bosan et al. 1987; HS
68 | Hamster; (Syrian Golden) | Lifetime; (W) | | | | | | | 1.1 | B | (CEL: angiosarcomas predominantly in the liver) | Toth 1972; 12DMH

a The number corresponds to entries in Figure 2-2.

b Used to derive an intermediate oral miminimal risk level (MRL) of 8X10−^4^ mg/kg/d dose 1,2-dimethylhydrazine; dose divided by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

11DMH = 1,1-dimethylhydrazine; 12DMH = 1,2-dimethylhydrazine; Bd Wt = body weight; (C) = capsule; Cardio = cardiovascular; CEL = cancer effect level; d = day(s); Derm = dermal; Endocr = endocrine; (F) = feed; (G) = gavage (not specified); Gastro = gastrointestinal; GD = gestation day(s); Gn pig = guinea pig; (GO) = gavage (oil); (GW) = gavage (water); H = hydrazine; HS = hydrazine sulfate; HH = hydrazine hydrate; LD50 = lethal dose (50% kill); LOAEL = lowest-observed-adverse-effect level; mg/kg/d = milligram per kilogram per day; mo = month(s); Musc/skel = musculoskeletal; NOAEL = no-observed-adverse-effect level; NS = not specified; Resp = respiratory; (W) = drinking water; wk = week(s); × = times(s); yr = year(s)

Figure 2-2 Levels of Significant Exposure to Hydrazines - Oral

Acute (≤14 days)

Chronic (≥365 days)

Intermediate (15-364 days)

Renal Effects. Interstitial nephritis and pyelonephritis were observed in mice receiving 1.6 mg/kg/day 1,2-dimethylhydrazine in feed for 5 months (Visek et al. 1991). These effects were not observed in mice similarly exposed to 0.75 mg/kg/day 1,2-dimethylhydrazine. No adverse effects were noted in the kidneys of mice receiving 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). These data are too limited to make firm conclusions but suggest that 1,2-dimethylhydrazine is toxic to the kidneys and hydrazine is not.

Endocrine Effects. Degeneration of the adrenals was noted in female mice exposed to 1.1 mg/kg/day or more hydrazine for 25 weeks (Biancifiori 1970). No adverse effects were noted in the thyroid of mice exposed to 9.3 mg/kg/day hydrazine for 25 weeks. Similarly, no effects were observed in the thyroid or adrenals of hamsters exposed to 5.3 mg/kg/day hydrazine for 15-20 weeks (Biancifiori 1970).

Dermal Effects. No adverse effects were observed in the skin of mice receiving 9.5 mg/kg/day hydrazine in their drinking water for 2 years (Steinhoff et al. 1990). No other studies were located regarding dermal effects in animals after oral exposure to hydrazines.

Ocular Effects. No adverse effects were observed in the eyes of mice receiving 9.5 mg/kg/day hydrazine in their drinking water for 2 years (Steinhoff et al. 1990). No other studies were located regarding ocular effects in animals after oral exposure to hydrazines.

Body Weight Effects. Body weight loss and decreased body weight gain were reported in animals exposed orally to 1,2-dimethylhydrazine and hydrazine. Weight loss was noted in dogs receiving 2 weekly doses of 60 mg/kg/day (Wilson 1976). Decreased body weight gains were reported for intermediate-duration exposure to 1,2-dimethylhydrazine for rats receiving 30 mg/kg/day (Barbolt and Abraham 1980), guinea pigs receiving 30 mg/kg/day (Wilson 1976), and in mice receiving 0.75 mg/kg/day or more (Visek et al. 1991). Decreased body weight gain was also noted in mice chronically exposed to 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). No significant effect on body weight gain was noted in mice receiving 1.9 mg/kg/day. Decreases in body weight were often accompanied by decrements in food intake, organ weights, and altered physical appearance and therefore probably represent signs of general toxicity. In some cases, decreased body weight gain may be secondary to an underlying disease (e.g., cancer).

#### 2.2.2.3 Immunological and Lymphoreticular Effects

No studies were located regarding immunological and lymphoreticular effects in humans after oral exposure to hydrazines.

A single study in rats reported that splenic natural killer cell activity was not affected after exposure to 27.1 mg/kg/day 1,2-dimethylhydrazine once a week for 5 weeks (Locniskar et al. 1986). This NOAEL value is recorded in Table 2-2 and plotted in Figure 2-2.

#### 2.2.2.4 Neurological Effects

Ingestion of hydrazine (estimated between a mouthful and a cupful) resulted in several neurological effects including episodes of violent behavior, ataxia, coma, convulsions, hypesthesia of the hands, and paraesthesia of the arms and legs (Reid 1965). Confusion, lethargy, restlessness, paresthesia, and neurogenic atrophy were observed in a 24-year-old male who swallowed a mouthful of hydrazine (Harati and Niakan 1986). Hydrazine has been used as a chemotherapeutic agent in human cancer patients. Neurological side effects have been observed in some human cancer patients (450%) treated with 0.2-0.7 mg/kg/day hydrazine as hydrazine sulfate for intermediate durations (Chlebowski et al. 1984; Gershanovich et al. 1976, 1981; Ochoa et al. 1975; Spremulli et al. 1979). For the most part, the neurological effects were relatively mild (lethargy, nausea, vomiting, dizziness, excitement, insomnia); however, two studies reported more serious effects (paresthesia, sensorimotor abnormalities, polyneuritis) (Gershanovich et al. 1976; Ochoa et al. 1975). The appearance of more serious effects in these two studies may be related to increased exposure duration. For example, Gershanovich et al. (1976, 1981) noted that polyneuritis developed only in patients receiving uninterrupted treatment with hydrazine for 2-6 months. The treatment duration used by Chlebowski et al. (1984) and Spremulli et al. (1979), which was less than 2 months in both studies, may have been sufficiently short enough to prevent the development of more serious neurological effects. Limitations in the findings of these studies lie in the fact that the test subjects were generally not healthy prior to hydrazine exposure. Therefore it is possible that some of the observed effects may be attributable to the underlying disease. However, collectively these studies strongly suggest that the central nervous systems is a target of hydrazine in humans after oral exposure. The highest NOAEL values and all LOAEL values for neurological effects resulting from oral exposure to hydrazines are recorded in Table 2-2 and plotted in Figure 2-2.

No studies were located regarding neurological effects in animals after oral exposure to hydrazines.

#### 2.2.2.5 Reproductive Effects

No studies were located regarding reproductive effects in humans after oral exposure to hydrazines. A single animal study reported no histopathological lesions in the ovaries of mice and hamsters exposed to 9.3 or 5.3 mg/kg/day hydrazine, respectively, for 15-25 weeks (Biancifiori 1970). However, the findings of this study are limited since reproductive function was not assessed. These NOAEL values for reproductive effects are recorded in Table 2-2 and plotted in Figure 2-2.

#### 2.2.2.6 Developmental Effects

No studies were located regarding developmental effects in humans after oral exposure to hydrazines.

A single study in hamsters reported no evidence of developmental toxicity or teratogenicity following exposure to a single dose of 166 mg/kg hydrazine or 68 mg/kg 1,2-dimethylhydrazine on day 12 of gestation (Schiller et al. 1979). Although these data are limited, they suggest that fetal development is not adversely affected by hydrazine or 1,2-dimethylhydrazine. These NOAEL values for developmental effects resulting from oral exposure to hydrazines are recorded in Table 2-2 and plotted in Figure 2-2.

#### 2.2.2.7 Genotoxic Effects

No studies were located regarding genotoxic effects in humans after oral exposure to hydrazines.

Alkylation of liver DNA was reported in rats acutely exposed to 30-90 mg/kg hydrazine for 1-3 days (Becker et al. 1981; Bosan et al. 1986). Micronuclei were observed in the bone marrow of mice exposed to a single oral dose of 10-50 mg/kg 1,2-dimethylhydrazine (Albanese et al. 1988; Ashby and Mirkova 1987). However, micronuclei were not observed in the bone marrow of rats after a single oral dose of 50-80 mg/kg 1,2-dimethylhydrazine (Ashby and Mirkova 1987). These data indicate that hydrazine and 1,2-dimethylhydrazine are genotoxic by the oral route. Furthermore, species differences may exist between rats and mice regarding their sensitivity to the genotoxic effects of 1,2-dimethylhydrazine.

Other genotoxicity studies are discussed in Section 2.5.

#### 2.2.2.8 Cancer

No studies were located regarding carcinogenic effects in humans after oral exposure to hydrazines.

Adenomas and adenocarcinomas of the colon have been observed in rats following a single oral exposure to 15.8-30 mg/kg 1,2-dimethylhydrazine (Craven and DeRubertis 1992; Schillm et al. 1980; Watanabe et al. 1985). Colon tumors are not common to rats and were not observed in the control animals of these studies.

Several tumor types have been observed in animals after intermediate-duration exposure to hydrazines. Exposure to 0.46-16.7 mg/kg/day hydrazine for 24-48 weeks produced a statistically significant increase in the incidence of lung, liver, and breast tumors in mice (Bhide et al. 1976; Biancifiori 1970; Biancifiori and Ribacchi 1962; Biancifiori et al. 1964; Roe et al. 1967; Yamamoto and Weisburger 1970). A single study reported an increased incidence of lung tumors in mice after daily administration of 0.25 mg hydrazine or 0.5 1,1-dimethylhydrazine (0.8 or 1.7 mg/kg/day, respectively), 5 times per week for 40-50 or 50-60 weeks (Roe et al. 1967). A large number of studies have reported tumors in rodents after intermediate exposure to 1,2-dimethylhydrazine. Statistically significant increases were reported for tumor incidences of the blood vessels (Bedell et al. 1982; Dmckrey 1970; Izumi et al. 1979; Teague et al. 1981), liver (Bedell et al. 1982; Teague et al. 1981; Wilson 1976), lung (Izumi et al. 1979), kidney (Bedell et al. 1982), ear duct (Teague et al. 1981; Wilson 1976), and most notably the intestines, colon, and anus (Abraham et al. 1980; Asano and Pollard 1978; Barbolt and Abraham 1980; Calvert et al. 1987; Drnckrey 1970; Izumi et al. 1979; Locniskar et al. 1986; Teague et al. 1981; Thorup et al. 1992; Wilson 1976). Doses of 1,2-dimethylhydrazine resulting in increased tumor incidence ranged from 1.9 mg/kg/day to 30 mg/kg/day.

Chronic oral exposure to hydrazines has also resulted in statistically significant increases in the incidence of tumors in rodents. Exposure to 1.9-12 mg/kg/day hydrazine resulted in lung tumor formation in rats and mice (Biancifiori et al. 1966; Bhide et al. 1976; Maru and Bhide 1982; Toth 1969, 1972b). In hamsters, exposure to 8.3 mg/kg/day hydrazine produced an increased incidence of liver and kidney tumors (Bosan et al. 1987). The difference in target organ specificity for the carcinogenic effects of hydrazine may represent an important species difference between hamsters and other laboratory rodents. Several tumor types, including those of the blood vessels, lung, kidney, and liver were noted at elevated incidences in mice chronically exposed to 19 mg/kg/day l,l-dimethylhydrazine in the drinking water (Toth 1973a). Studies have reported a statistically significant increase in the incidence of blood vessel tumors in mice exposed to 0.059 mg/kg/day 1,2-dimethylhydrazine (Toth and Patil 1982) and in hamsters exposed to 1.1 mg/kg/day 1,2-dimethylhydrazine in the drinking water for life (Toth 1972c).

Collectively, these data indicate that hydrazines are carcinogenic by the oral route following acute, intermediate, or chronic exposure, and are capable of producing tumors in multiple tissue sites in several different animal species. Clearly, 1,2-dimethylhydrazine is the most potent carcinogen of the three hydrazines, since significant tumor incidences have been reported following single doses (Craven and DeRubertis 1992; Schiller et al. 1980; Watanabe et al. 1985) and at very low chronic doses (Toth and Patil 1982). Hydrazine and l,l-dimethylhydrazine are less potent carcinogens, producing tumors primarily in the lungs (Bhide et al. 1976; Biancifiori et al. 1966; Maru and Bhide 1982; Roe et al. 1967). All CEL values from each reliable study resulting from oral exposure to hydrazines are recorded in Table 2-2 and plotted in Figure 2-2.

The EPA has derived oral slope factors of 30 (mg/kg/day)^−1^ for hydrazine based on liver tumors, 2.6 (mg/kg/day)^−1^ for1,1-dimethylhydrazine based on tumors of the cardiovascular system, and 37 (mg/kg/day)^−1^ for 1,2-dimethylhydrazine based on tumors of the cardiovascular system (HEAST 1992; IRIS 1993). Doses of hydrazine, 1, 1-dimethylhydrazine, and 1,2-dimethylhydrazine corresponding to excess cancer risks of 10^−4^ to 10^−7^ are shown in Figure 2-2.

### 2.2.3 Dermal Exposure

#### 2.2.3.1 Death

No studies were located regarding lethal effects in humans after dermal exposure to hydrazines.

In rabbits and guinea pigs, the dermal LD_50_ values ranged from 93 to 190 mg/kg, 1,341 to 1,680 mg/kg, and 158 to 563 mg/kg for hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine, respectively (Rothberg and Cope 1956). One out of four dogs administered a single dermal dose of 300 mg/kg 1,1-dimethylhydrazine died 6 hours after exposure (Smith and Clark 1971). All dogs (three out of three) exposed to a single dermal dose of 1,800 mg/kg l,l-dimethylhydrazine died within 6 hours. In dogs exposed to hydrazine, two of three died following exposure to a single dermal dose of 96 mg/kg (Smith and Clark 1972). Additional deaths were noted in this study at higher dermal doses of hydrazine. These data indicate that acute dermal exposure to large doses of hydrazines can be lethal. These LOAEL values are recorded in Table 2-3. The lack of repeat dermal exposure studies in animals is probably due to the corrosiveness of hydrazines and their ability to induce dermal sensitization reactions.

#### 2.2.3.2 Systemic Effects

No studies were located regarding respiratory, cardiovascular, gastrointestinal, musculoskeletal, hepatic, or renal effects in humans or animals after dermal exposure to hydrazines. All LOAEL values for hematological, dermal, and ocular effects from each reliable study are recorded in Table 2-3.

TABLE 2-3 Levels of Significant Exposure to Hydrazines - Dermal

Species/(Strain) | Exposure/Duration/Frequency/(Specific Route) | System | NOAEL (mg/kg/day) | LOAEL | | | | | | Reference Chemical Form
Species/(Strain) | Exposure/Duration/Frequency/(Specific Route) | System | NOAEL (mg/kg/day) | Less Serious (mg/kg/day) | | | Serious (mg/kg/day) | | | Reference Chemical Form
ACUTE EXPOSURE
Death
Dog; (Mongrel) | Once | | | | | | 300 | M | (1/4 deaths) | Smith and Clark 1971; 11DMH
Dog; (Mongrel) | Once | | | | | | 96 | M | (2/3 deaths) | Smith and Clark 1972; H
Rabbit; (Albino) | Once | | | | | | 467 | NS | (LD50) | Rothberg and Cope 1956; 12DMH
Rabbit; (Albino) | Once | | | | | | 1059 | NS | (LD50) | Rothberg and Cope 1956; 11DMH
Rabbit; (Albino) | Once | | | | | | 93 | NS | (LD50) | Rothberg and Cope 1956; H
Gn pig; (NS) | Once | | | | | | 190 | NS | (LD50) | Rothberg and Cope 1956; H
Gn pig; (NS) | Once | | | | | | 1327 | NS | (LD50) | Rothberg and Cope 1956; 11DMH
Gn pig; (NS) | Once | | | | | | 131 | NS | (LD50) | Rothberg and Cope 1956; 12DMH
Systemic
Dog; (Mongrel) | Once | Derm | | 300 | M | (slight irritation of the skin) | | | | Smith and Clark 1971; 11DMH
Dog; (Mongrel) | Once | Derm | | 96 | M | (discoloration and edema of the skin) | | | | Smith and Clark 1972; H
Dog; (NS) | Once | Hemato | | 300 | NS | (decreased thromboplastin generation time) | | | | Smith and Castaneda 1970; 11DMH
| | Ocular | | 300 | NS | (corneal swelling)

11DMH = 1,1-dimethylhydrazine; 12DMH = 1,2-dimethylhydrazine; Derm = dermal; Gn pig = guinea pig; H = hydrazine; Hemato = hematological; LD50 = lethal dose (50% kill); LOAEL = lowest-observed-adverse-effect level; mg/kg = milligram per kilogram; NOAEL = no-observed-adverse-effect level; NS = not specified.

Hematological Effects. No studies were located regarding hematological effects in humans after dermal exposure to hydrazines.

Data in animals regarding hematological effects are limited to a single study. A decreased thromboplastin generation time was noted in dogs exposed to a single dose of 300 mg/kg l,l-dimethylhydrazine (Smith and Castaneda 1970). No other blood coagulation parameters were significantly affected.

Dermal Effects. Dermal exposure to hydrazine produces contact dermatitis. A number of studies have reported contact dermatitis in humans after dermal exposure to solutions containing 0.00005% to 1% hydrazine (Frost and Hjorth 1959; Hovding 1967; Suzuki and Ohkido 1979; Van Ketel 1964; Wrangsjo and Martensson 1986). These studies clearly indicate that hydrazine is a sensitizing agent.

Exposure to a single dermal dose of 93-190 mg/kg hydrazine resulted in discoloration of the exposed area in rabbits and guinea pigs (Rothberg and Cope 1956). Dermal discoloration and edema of the skin (application area) were observed in dogs dermally exposed to a single dose of 96 mg/kg hydrazine or more (Smith and Clark 1972). Discoloration was also observed in dogs after dermal exposure to a single dose of 300 mg/kg 1,1-dimethylhydrazine (Smith and Clark 1971).

Ocular Effects. No studies were located regarding ocular effects in humans after dermal exposure to hydrazines. A single application of 3 µL of hydrazine, 1,1-dimethylhydrazine, or 1,2-dimethylhydrazine directly to the eyes produced conjunctivitis and erythema of the eyelids in rabbits (Rothberg and Cope 1956). Comeal damage was also noted in rabbits exposed to hydrazine but not in rabbits exposed to 1,1-dimethylhydrazine or 1,2-dimethylhydrazine. Dermal exposure to a single dose of 5 mmole/kg 1,1-dimethylhydrazine produced comeal swelling in dogs (Smith and Castaneda 1970). Although the ocular effects observed in this study may have resulted from hydrazine that was absorbed systemically, it is also possible that direct exposure of the eyes to hydrazine vapors was responsible for this effect. These data indicate that all three hydrazines can produce effects on the eyes.

#### 2.2.3.3 Immunological and Lymphoreticular Effects

Data regarding the immunological or lymphoreticular effects of hydrazines in humans after dermal exposure are limited to a single case study. A female laboratory worker intermittently exposed to an undetermined amount of hydrazine developed a lupus erythematosus-like disease (Reidenberg et al. 1983). Symptoms included a photosensitive rash, fatigue, anthragias, and a breaking off of frontal hair. The subject also possessed antinuclear antibodies and antibody to DNA. A positive skin patch test response was obtained after a dermal challenge to hydrazine was administered. The study authors concluded that hydrazine can induce a lupus erythematosus-like disease in predisposed persons. In support of this view, a number of other hydrazine derivatives have been linked to the induction of lupus erythematosus in humans (Pereyo 1986). As discussed in Section 2.2.3.2, dermal exposure to hydrazine also produces allergic contact dermatitis in humans.

No data were located regarding the immunological or lymphoreticular effects in animals after dermal exposure to hydrazines.

#### 2.2.3.4 Neurological Effects

Data regarding neurological effects in humans after dermal exposure to hydrazines are limited to two case studies. A man who suffered bums during an industrial hydrazine explosion became comatose 14 hours after the explosion (Kirklin et al. 1976). Rapid recovery from the coma was facilitated by pyridoxine treatment. Another man who suffered bums during an industrial 1,1-dimethylhydrazine explosion exhibited abnormal EEG readings and narcosis within 40 hours after exposure (Dhennin et al. 1988). Recovery from these symptoms was also facilitated by pyridoxine treatment. Several months after the incident the latter worker developed polyneuritis. The findings from these studies are limited because the subjects were burn patients. The trauma from the bums may have played a role in some of the neurological effects observed. In addition, pyridoxine is also known to produce neurological effects at high doses, and may have been partially responsible for the delayed polyneuritis.

Mild convulsions were noted in 3 of 13 dogs receiving a single dermal dose of 300-1,800 mg/kg l,l-dimethylhydrazine (Smith and Clark 1971). Similarly, convulsions were noted in 3 of 25 dogs administered a single dermal dose of 96-480 mg/kg hydrazine (Smith and Clark 1972). The data from animal studies support the findings of the human case studies which indicate that hydrazine and 1,1 -dimethylhydrazine adversely affect the central nervous system following large dermal exposures, No studies were located regarding the following effects in humans or animals after dermal exposure to hydrazines:

2.2.3.5 Reproductive Effects
2.2.3.6 Developmental Effects

#### 2.2.3.7 Genotoxic Effects

Genotoxicity studies are discussed in Section 2.5.

#### 2.2.3.8 Cancer

No studies were located regarding cancer effects in humans or animals after dermal exposure to hydrazines.

## 2.3 TOXICOKINETICS

No data were located regarding the toxicokinetics of hydrazines in humans after inhalation, oral, or dermal exposure to hydrazines. Inhalation, oral, and dermal studies in animals indicate that hydrazines are rapidly absorbed into the blood. Animal studies also indicate that hydrazines readily distribute to tissues without preferential accumulation at any specific site. Hydrazines with a free amino group are able to react with endogenous alpha-keto acids and in so doing produce a variety of adverse health effects. In vivo and in vitro studies indicate that hydrazines are metabolized by several pathways, both enzymatic and nonenzymatic. Free radical and carbonium ion intermediates are produced during the metabolism of hydrazines and may also be involved in adverse health effects produced by exposure to hydrazines. Limited data from animal studies indicate that metabolites of hydrazines are excreted principally in the urine and expired air. Although the data are limited, animal studies appear to indicate that the toxicokinetics of hydrazines may vary among animal species.

### 2.3.1 Absorption

#### 2.3.1.1 Inhalation Exposure

No studies were located regarding absorption in humans after inhalation exposure to hydrazines. A single animal study was located which investigated the absorption of hydrazine in the lungs. Groups of eight rats were exposed to concentrations of 10, 60, or 500 ppm hydrazine in a nose-only chamber for 1 hour (Llewellyn et al. 1986). Based on the levels of hydrazine and its metabolites excreted in the urine within 48 hours, the absorption of hydrazine was estimated to be at least 8.4-29.5%. However, because a large percentage of the dose may have been retained in the body or excreted by fecal or pulmonary routes, absorption in the lungs is probably significantly higher than 8.4-29.5%.

#### 2.3.1.2 Oral Exposure

No studies were located regarding absorption in humans after oral exposure to hydrazines. It should be noted, however, that the drug isoniazid, which is used to treat tuberculosis, is metabolized to hydrazine, and thus patients administered isoniazid exhibit elevated levels of hydrazine in their blood plasma (Blair et al. 1985).

A single animal study was located which investigated the oral absorption of hydrazine. Groups of 15 rats were administered a single dose of hydrazine, ranging from 2.9 to 81 mg/kg (Preece et al. 1992a). Based on the levels of hydrazine and its metabolites excreted in the urine within 24 hours, at least 19-46% of the administered dose was absorbed. However, since the analytical method employed in this study cannot detect certain metabolites of hydrazine, and since 24 hours may have been too short a time period to collect all urinary metabolites, the absorption of hydrazine in the gastrointestinal tract is most likely higher than 19-46%. In a more detailed description of presumably the same study, Preece et al. (1992b) reported dose saturation effects with respect to urinary excretion and liver concentration of hydrazine. Both the ratio of plasma to liver hydrazine levels and the proportion of hydrazine and acetylhydrazine excreted in the urine declined with the dose. These authors also reported that evidence of fatty liver and reduction in liver and body weights occurred only at the highest dose examined (81 mg/kg).

#### 2.3.1.3 Dermal Exposure

No studies were located regarding absorption in humans after dermal exposure to hydrazines. Two studies in dogs reported that hydrazine and 1,1-dimethylhydrazine were detected in the blood within 30 seconds of exposure to a single dermal dose (Smith and Clark 1971, 1972). In dogs exposed to a single dermal dose of 96-480 mg/kg hydrazine, maximum levels of hydrazine in the blood (approximately 70 µg/L) were detected 3 hours after exposure (Smith and Clark 1972). Similarly, in dogs exposed to a single dermal dose of 300-1,800 mg/kg 1,1-dimethylhydrazine, the highest levels of l,l-dimethylhydrazine (approximately 130 µg/mL) were detected 3 hours after exposure (Smith and Clark 1971). These data indicate that hydrazine and 1,1-dimethylhydrazine are rapidly absorbed from the skin into the blood. However, these studies do not provide enough information to estimate the extent to which hydrazine and 1,1-dimethylhydrazine are absorbed. The lack of repeat dermal exposure studies in animals is probably due to the corrosiveness of hydrazines and their ability to induce dermal sensitization reactions.

### 2.3.2 Distribution

#### 2.3.2.1 Inhalation Exposure

No studies were located regarding distribution in humans or animals after inhalation exposure to hydrazines.

#### 2.3.2.2 Oral Exposure

No studies were located regarding distribution in humans after oral exposure to hydrazines.

A single study in animals reported limited information on the distribution of hydrazine after oral exposure. Following a single oral dose of 2.9-81 mg/kg hydrazine, peak levels of hydrazine in the plasma and liver of rats were achieved within 30 minutes (Preece et al. 1992a). These levels ranged from approximately 0.0003 to 0.01 mg/mL in the plasma and from 0.0006 to 0.006 mg/kg in the liver. The levels of hydrazine in other tissues were not reported. In a more detailed description of presumably the same study, Preece et al. (1992b) found that there was a fivefold greater amount of hydrazine in the liver than in blood plasma 24 hours after dosing. No acetylhydrazine was found at that time. The concentration of hydrazine in the liver (other organs were not examined) did not increase proportionately with the dose, suggesting saturation effects. Similarly, the urinary excretion was dose-dependent, with a greater portion of hydrazine and acetylhydrazine being excreted at lower doses than at higher doses.

#### 2.3.2.3 Dermal Exposure

No studies were located regarding distribution in humans or animals after dermal exposure to hydrazines.

#### 2.3.2.4 Other Routes of Exposure

No studies were located regarding distribution in humans after exposure to hydrazines.

In rats administered a single dose of 9.9 mg/kg hydrazine by subcutaneous injection, hydrazine was observed to rapidly distribute to tissues (Kaneo et al. 1984). Maximum tissue levels were observed within 30 minutes in the liver, lung, plasma, and particularly the kidney. Hydrazine was detected in the brain of rats at levels of 0.5-1 µg/g following intravenous injection of 5.1 mg/kg hydrazine (Matsuyama et al. 1983). The levels of hydrazine in various tissues in rats were reported to decrease with half-times ranging from 2.3 to 3.3 hours (Kaneo et al. 1984).

In a series of experiments, groups of rats, rabbits, cats, dogs, and monkeys were administered a single intraperitoneal dose of l,l-dimethylhydrazine ranging from 10 to 50 mg/kg (Back et al. 1963). The plasma levels of l,l-dimethylhydrazine in all species reached maximum values within 1 hour of the injection, accounting for up to 14.3% of the dose in dogs and 8.7% of the dose in cats. Plasma levels were not detectable in rats after 2-24 hours, indicating that 1,1-dimethylhydrazine was rapidly distributed to tissues or was excreted. Plasma levels in monkeys tended to drop off after1 hour and were not detectable after 24 hours. In a limited study, male rats were subcutaneously injected with 50 mg/kg 1,1-dimethylhydrazine or 100 mg/kg 1,2-dimethylhydrazine (Fiala and Kulakis 1981). Plasma levels of these two hydrazines decreased rapidly after exposure, with half-lives of approximately 1 hour for each chemical.

In rats administered a single dose of 0.78-80 mg/kg 1,1-dimethylhydrazine by intraperitoneal injection, approximately 71 .1% of the dose was retained in the body after 4 hours (Mitz et al. 1962), and approximately 7.1-38.7% of the dose was retained in the body after 53 hours (Dost et al. 1966). Low levels of 1,1-dimethylhydrazine (approximately 0.1-3.1% of the dose) were detected in tissues (brain, liver, kidney, heart, blood) of rats administered a single dose of 11-60 mg/kg 1,1-dimethylhydrazine by intraperitoneal injection (Mitz et al. 1962; Reed et al. 1963). Preferential accumulation of 1,1-dimethylhydrazine was not observed in any organ. Although higher concentrations of 1,1-dimethylhydrazine were detected in the liver and colon of rabbits within 2 hours after receiving a single intravenous or intraperitoneal dose (Back et al. 1963), this was not judged to be evidence of preferential accumulation by the study authors. The highest levels in these rabbits were detected in the liver (8.9%) and colon (11.6%) after 2 hours, whereas other tissue levels ranged from 0.02 to 4.18% of the dose.

These data indicate that hydrazines distribute rapidly to all tissues without preferential accumulation following injection of a single dose. Furthermore, tissue levels of hydrazine and 1,1-dimethylhydrazine tend to reach maximal values within 1 hour and are generally not detectable after 24 hours.

### 2.3.3 Metabolism

Several enzymatic and nonenzymatic pathways are involved in the metabolism of hydrazines. Humans with a slow acetylator genotype may accumulate more hydrazine in the plasma because of an impaired ability to metabolize and excrete the compound (Blair et al. 1985). Although the extent to which each pathway contributes to total metabolism may depend somewhat on the route of exposure (a first-pass metabolic effect for oral exposure, for example), the types of pathways involved and metabolites formed do not appear to be dependent on route. Therefore this section discusses the data without reference to route of exposure. While the metabolic pathways of hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine are similar in some ways, there are some important differences. Therefore, data from in vivo and in vitro studies regarding the metabolism of hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine are discussed separately below.

Hydrazine. In rats exposed to 10-500 ppm hydrazine for 1 hour, approximately 2-10% of the inhaled dose was excreted in the urine unchanged, 1.74% as acetyl hydrazine, and 4.5-11.4% as diacetyl hydrazine (Llewellyn et al. 1986). In rats exposed to a single dose of 16-64 mg/kg hydrazine, approximately 20% was excreted in the urine as an unspecified hydrazine derivative, 30% was excreted in the urine unchanged, and 25% of the nitrogen in hydrazine was released in expired air as nitrogen gas (Springer et al. 1981). In rats administered a single dose of 2-81 mg/kg hydrazine, a small percentage of the dose (1-19%) was recovered in the urine as acetyl hydrazine and/or diacetyl hydrazine within 2448 hours of exposure (Kaneo et al. 1984; Llewellyn et al. 1986; Preece et al. 1992a). Following exposure to larger doses of 427 mg/kg hydrazine, a number of metabolites were excreted in the urine, including acetyl hydrazine, diacetyl hydrazine, pyruvate hydrazone, urea, and a cyclic compound (1,4,5,6-tetrahydro-6-oxo-3-pyridazine carboxylic acid, a product of the reaction between 2-oxoglutarate and hydrazine) (Preece et al. 1991). These data indicate that hydrazine undergoes acetylation and can react with cellular molecules in vivo.

Hydrazine is rapidly metabolized by rat liver microsomes in vitro (Timbrell et al. 1982). Oxygen, nicotinamide-adenine dinucleotide phosphate (NADPH), and active enzyme were required for maximal activity. Metabolism of hydrazine by rat liver hepatocytes was increased when rats were pretreated with cytochrome P-450 inducers (phenobarbital and rifampicin) and was decreased by the addition of cytochrome P-450 inhibitors (metyrapone and piperonyl butoxide) (Noda et al. 1987). Cytochrome P-450 inhibitors and inducers were also reported to increase and decrease hydrazine toxicity, respectively, indicating a relationship between metabolism and toxicity (Timbrell et al. 1982). Free radical formation was reported to occur when hydrazine was incubated with purified NADPHcytochrome P-450 reductase (Noda et al. 1988). This reaction required NADPH and oxygen, was stimulated by FAD, inhibited by superoxide dismutase, and was unaffected by carbon monoxide. Free radicals were also noted when hydrazine was metabolized in perfused rat livers (Sinha 1987). These free radicals included acetyl, hydroxyl, and hydrogen radicals, the type of which was dependent upon the addition of an activating system (horseradish peroxidase or copper ion) to the perfusate. The occurrence of an acetyl radical suggests that hydrazine is acetylated prior to radical formation. These data indicate that hydrazine is metabolized by cytochrome P-450 but that transformation via other enzyme systems (peroxidases) or nonenzymatic reactions (copper ion-mediated) may occur as well. The formation of free radicals during the metabolism of hydrazine may be important to the mechanism of action of hydrazine toxicity.

l,l-Dimethylhydrazine. In rats administered a single dose of 0.78-60 mg/kg 1,1-dimethylhydrazine, approximately 12-27% of the dose was detected in expired air as carbon dioxide (Dost et al. 1966; Reed et al. 1963). Four hours after receiving a single dose of 40 mg/kg 1,1-dimethylhydrazine, less than 2% of the dose was released in expired air (Mitz et al. 1962). Approximately 3-10% and 20-25% of the dose was recovered in the urine as the glucose hydrazone of 1,1-dimethylhydrazine and an unidentified metabolite (Mitz et al. 1962). The study authors speculated that the unidentified metabolite was another hydrazone of 1,1-dimethylhydrazine. These data indicate that 1,1-dimethylhydrazine undergoes demethylation and can react with cellular molecules in vivo.

N-demethylation of 1,1-dimethylhydrazine by rat and hamster liver microsomes in vitro required the presence of NADPH and oxygen and was decreased by the addition of flavin-containing monooxygenase inhibitor (methimazole) but not by the addition of cytochrome P-450 inhibitors (Prough et al. 1981). 1,1-Dimethylhydrazine was also noted to be a good substrate for N-oxidation by amine oxidase (Prough 1973). In rat liver microsomes and S-9 fractions, both a nonenzymatic and an enzymatic component were identified for the metabolism of 1,1-dimethylhydrazine (Godoy et al. 1983). Formaldehyde was produced by both components, although the nonenzymatic component dominated the formation of a reactive protein-binding species. In contrast, rat liver slices metabolized 1,1-dimethylhydrazine to carbon dioxide and did not generate any reactive protein-binding species (Godoy et al. 1983), suggesting that in vitro metabolic studies may not be presenting an accurate picture of 1,1-dimethylhydrazine metabolism as it occurs in vivo. The formation of formaldehyde by rat colon microsomes was decreased by the addition of lipoxygenase and cyclooxygenase inhibitors (indomethacin and eicosatetranoic acid) and was stimulated by the addition of fatty acids, suggesting that lipoxygenase and cyclooxygenase may be involved in the colonic metabolism of 1,1-dimethylhydrazine (Craven et al. 1985).

Several studies have shown that the reactive binding species generated by 1,1-dimethylhydrazine metabolism may be free radical intermediates. Rat liver microsomes and rat hepatocytes are capable of metabolizing 1,1-dimethylhydrazine to form methyl radical intermediates (Albano et al. 1989; Tomasi et al. 1987). The formation of these radicals was inhibited by the addition of inhibitors of cytochrome P-450 (SKF 525A, metyrapone, and carbon monoxide) and inhibitors of the flavin-containing monooxygenase system (methimazole). The formation of free radicals could also be supported nonenzymatically by the presence of copper ion (Tomasi et al. 1987). These data indicate that at least two independent enzyme systems and one nonenzymatic pathway may be involved in the metabolism of 1,1-dimethylhydrazine.

1,2-Dimethylhydrazine. In vivo studies indicate that 1,2-dimethylhydrazine is metabolized to form azomethane, azoxymethane, methylazoxymethanol, ethane, and carbon dioxide. In rats administered a single dose of 20-200 mg/kg 1,2-dimethylhydrazine, approximately 4-24% and 14-23% of the dose was detected in expired air as carbon dioxide and azomethane, respectively (Fiala et al. 1976; Harbach and Swenberg 1981). Azoxymethane and methylazoxymethanol were detected in the urine of rats injected with 21 mg/kg 1,2-dimethylhydrazine (Fiala et al. 1977). It has been proposed that 1,2-dimethylhydrazine undergoes sequential oxidations to form azomethane, which in turn is metabolized to form azoxymethane and then methylazoxymethanol (Druckrey 1970). Ethane was detected in the expired air of rats exposed to a single dose of 9-91 mg/kg 1,2-dimethylhydrazine (Kang et al. 1988). The study authors proposed that ethane was formed by a dimerization of methyl radicals originating from 1,2-dimethylhydrazine metabolism. These data indicate that oxidation can occur at both the nitrogen and the carbon of 1,2-dimethylhydrazine in vivo and suggest that free radicals may be formed as well.

Human colon microsomes and human colon cancer cells were capable of generating formaldehyde from 1,2-dimethylhydrazine in vitro (Newaz et al. 1983). The formation of formaldehyde was decreased by the addition of cytochrome P-450 inhibitors and was increased by the pretreatment of cancer cells with cytochrome P-450 inducers. Interestingly, the study authors noted a gradient with respect to 1,2-dimethylhydrazine metabolism activity in the colon (ascending < transverse < descending). Other studies have reported that the greatest capacity to produce DNA-binding intermediates from 1,2-dimethylhydrazine is in the ascending colon of humans (Autrup et al. 1980a). Rat colon epithelial cells were found to metabolize 1,2-dimethylhydrazine to azoxymethane, methylazoxymethanol, and a reactive binding species (Glauert and Bennink 1983). In the hamster colon cells, surface columnar epithelial cells were found to metabolize 1,2-dimethylhydrazine 2-3 times as well as crypt cells (Sheth-Desai et al. 1987). In addition, metabolism was inhibited by an alcohol dehydrogenase inhibitor (pyrazole). In a rat liver perfusion study, the metabolites of 1,2-dimethylhydrazine were identified as azomethane, azoxymethane, and methylazoxymethanol (Wolter et al. 1984). Rat liver microsomes were found to metabolize 1,2-dimethylhydrayine to azomethane (N-N oxidation) and formaldehyde (C-N oxidation) (E&son and Prough 1986). These activities were increased in rats pretreated with cytochrome P-450 inducers (phenobarbital) indicating the involvement of this enzyme. Mitochondrial amine oxidase demonstrated considerable activity as well (Coomes and Prough 1983; Erikson and Prough 1986), although 1,2-dimethylhydrazine was not as good a substrate for this enzyme as was l,l-dimethylhydrazine (Prough 1973). Likewise, 1,2-dimethylhydrazine was not as good a substrate as 1,1-dimethylhydrazine for flavin-containing monooxygenase-mediated metabolism (Prough et al. 1981) or colonic cyclooxygenase and lipoxygenase (Craven et al. 1985). Since 1,2-dimethylhydrazine is a potent colon carcinogen while 1,1-dimethylhydrazine is not carcinogenic for the rodent colon, the significance of these findings is uncertain.

Reactive intermediates are formed during the metabolism of 1,2-dimethylhydrazine. In vitro studies indicate that methylazoxymethane can form a reactive species (probably a methyldiazonium ion) either spontaneously (Nagasawa and Shirota 1972) or enzymatically by alcohol dehydrogenase and/or cytochrome P-450 (Feinberg and Zedeck 1980; Sohn et al. 1991). Other in vitro studies suggest that free radicals are formed during the metabolism of 1,2-dimethylhydrazine. For example, as observed with 1,1-dimethylhydrazine, the formation of methyl free radicals from 1,2-dimethylhydrazine in rat liver microsomes and rat hepatocytes was inhibited by cytochrome P-450 inhibitors (SKF 525A, metyrapone, and carbon monoxide) (Albano et al. 1989; Tomasi et al. 1987). However, unlike 1,1-dimethylhydrazine, the formation of methyl radicals was not decreased by the addition of a flavin-containing monooxygenase inhibitor (methimazole), suggesting that this enzyme is not involved in the production of free radicals from 1,2-dimethylhydrazine. Carbon-centered radicals were observed when 1,2-dimethylhydrazine was metabolized by horseradish peroxidase (Augusto et al. 1985; Netto et al. 1987). These data indicate differences exist between the enzyme systems involved in metabolism of 1,2-dimethylhydrazine and 1,1-dimethylhydrazine to reactive intermediates.

Reactive intermediates produced during the metabolism of 1,2-dimethylhydrazine are most likely responsible for DNA adducts observed in vivo (Becker et al. 1981; Netto et al. 1992; Pozharisski et al. 1975) and in vitro (Autrup et al. 1980a; Harris et al. 1977; Kumari et al. 1985). There is evidence for both the methyldiazonium and methyl radical as reactive species derived from 1,2-dimethylhydrazine, and it is clear that metabolism of the compound is required for its carcinogenicity. Inhibition of metabolism by disulfiram and other thiono sulfur compounds (Fiala et al. 1977) resulted in inhibition of DNA alkylation (Swenberg et al. 1979) and colon carcinogenicity (Wattenberg 1975):. Moreover, azoxymethane and methylazoxymethanol, two metabolites of 1,2-dimethylhydrazine, are also potent colon and liver carcinogens (Williams and Weisburger 1991).

### 2.3.4 Excretion

#### 2.3.4.1 Inhalation Exposure

No studies were located regarding excretion in humans after inhalation exposure to hydrazines.

Forty-eight hours after a l-hour exposure to 10-500 ppm hydrazine, approximately 8.4-29.5% of the inhaled dose was excreted in the urine of rats (Llewellyn et al. 1986). Most of the recovered dose was excreted during the first 24 hours. Three metabolites were identified in the urine as unchanged hydrazine, acetyl hydrazine, and diacetyl hydrazine. No other studies were located regarding excretion in animals after inhalation exposure to hydrazine.

#### 2.3.4.2 Oral Exposure

No studies were located regarding excretion in humans after oral exposure to hydrazines.

A single study was located that reported excretion in animals after oral exposure to hydrazine. Twenty-four hours after a single oral dose of 2.9-81 mg/kg hydrazine, approximately 19-46% of the dose was recovered in the urine of exposed rats (Preece et al. 1992a). Two metabolites were identified in the urine as unchanged hydrazine and acetyl hydrazine. Fecal excretion and release of the compound in expired air were not investigated in this study.

#### 2.3.4.3 Dermal Exposure

No studies were located regarding excretion in humans after dermal exposure to hydrazines. Data in animals regarding the excretion of hydrazines are limited to two studies. In dogs administered a single dermal dose of 300-1,800 mg/kg 1,1-dimethylhydrazine, levels of up to 600 µg/L 1,1-dimethylhydrazine were detected in the urine within 5 hours (Smith and Clark 1971). Similarly, in dogs administered a single dermal dose of 96-480 mg/kg hydrazine, levels of up to 70 µg/mL were detected in the urine within 3 hours (Smith and Clark 1972). However, neither of these studies examined fecal excretion nor did they provide sufficient information to estimate the fraction of the dose excreted in the urine.

#### 2.3.4.4 Other Exposure

No studies were located regarding excretion in humans after other exposures to hydrazines.

The levels of hydrazine in the blood were reported to decrease in a biphasic manner in rats administered 16-64 mg/kg hydrazine via indwelling catheters, with half-times of 0.74 and 26.9 hours (Springer et al. 1981). In dogs administered a single dose of 16-64 mg/kg hydrazine via an indwelling cannula, approximately 25% and 50% of the dose was recovered within 48 hours in the expired air and urine, respectively (Springer et al. 1981). Forty-eight hours after receiving a single intravenous dose of 2-12 mg/kg hydrazine, rats excreted approximately 13.8-37.3% of the dose in the urine (Llewellyn et al. 1986). Approximately 29.2% of a single subcutaneous dose of 9.9 mg/kg hydrazine was excreted in the urine of rats after 48 hours (Kaneo et al. 1984). Although these data are limited by the lack of information on fecal excretion, they suggest that the majority of an absorbed dose of hydrazine is excreted in the urine but that a significant fraction of the dose may be released in expired air.

In rats administered a single dose of 0.78-80 mg/kg 1,1-dimethylhydrazine, approximately 18.9-76% of the carbon dose was recovered in the urine and 2-23% of the carbon dose was excreted in expired air within 4-53 hours (Dost et al. 1966; Mitz et al. 1962; Reed et al. 1963). Approximately 34.8-39.1% of the carbon dose was excreted in the urine within 5 hours in dogs intraperitoneally injected with 50 mg/kg 1,1-dimethylhydrazine (Back et al. 1963). Approximately 37.2-51.2% of the carbon dose was recovered in the urine within 6 hours in cats intraperitoneally injected with 10-50 mg/kg 1,1-dimethylhydrazine (Back et al. 1963). These studies typically employed a carbon radiolabel (^14^C-1,1-dimethylhydrazine). This radiolabel can become separated from the rest of the molecule during the demethylation of 1,1-dimethylhydrazine; therefore, these studies may not accurately depict the metabolic fate of the nitrogen contained within the dose. In addition, fecal excretion of 1,1-dimethylhydrazine was not determined in these studies. Despite these limitations, these data suggest that the majority of the carbon from an absorbed dose of 1,1-dimethylhydrazine is excreted in the urine but that a significant fraction of the carbon dose may be released in expired air. In rats treated subcutaneously with 21 mg/kg ^14^C-labelled 1,2-dimethylhydrazine, approximately 13-16% of the radioactivity was released in expired air as CO_2_ within 24 hours, while 14-15% was expired as azomethane and 17% was released in urine (Fiala et al. 1977). A similar rat study found that the levels of radiolabel in expired CO_2_ and azomethane after 24 hours were 11% and 14%, respectively, when the dose was 21 mg/kg 1,2-dimethylhydrazine, and 4% and 23%, respectively, when the dose was 200 mg/kg (Fiala et al. 1976). Likewise, rats injected with 20 mg/kg 1,2-dimethylhydrazine expired about 22% of the radioactive dose as azomethane and about 16% as CO_2_ after 12 hours (Harbach and Swenberg 1981). By quantitating the radioactivity released as azomethane, which contains both nitrogens from the 1,2-dimethylhydrazine, the metabolic fate of these nitrogens can be followed, in contrast to studies which only measure expired CO_2_. Female mice injected with 15 mg/kg ^14^C-labelled 1,2-dimethylhydrazine expired about 24% of the radioactivity as CO_2_ within 24 hours, while 10% was excreted in the urine (Hawks and Magee 1974). This same study found that 0.9% of the radioactivity was excreted in the bile after a dose of 200 mg/kg. These data suggest that a significant fraction of the carbon dose of 1,2-dimethylhydrazine may be released in expired air and urine, whereas fecal excretion is relatively low.

## 2.4 MECHANISMS OF ACTION

Studies in animals indicate that hydrazines are rapidly absorbed through the skin (Smith and Clark 1971, 1972), and presumably in the lungs and gastrointestinal tract as well. Although the mechanism by which hydrazines are absorbed into the blood has not been studied, this most likely does not occur by passive diffusion because of the polar nature of these compounds.

A number of studies have investigated the mechanisms by which hydrazines produce adverse health effects. These data suggest there are at least two distinct mechanisms of action for hydrazines: one involving the direct binding of those hydrazines with a free amino group (hydrazine and 1,1-dimethylhydrazine) to key cellular molecules, and the other involving the generation of reactive species such as free radical intermediates or methyldiazonium ions as a result of metabolism. Studies which support the existence of these mechanisms are discussed below.

In vitro studies have shown that hydrazine reacts with alpha-keto acids to form hydrazoines compounds (O’Leary and Oikemus 1956). By binding to keto acids and forming hydrazones, hydrazine inhibited oxygen consumption with mitochondrial substrates in vitro (Fortney 1967). This mechanism may well account for the hyperlactemic and hypoglycemic effects of hydrazine observed in humans (Ochoa et al. 1975) and dogs in vivo (Fortney 1967). Hydrazine and 1,1-dimethylhydrazine can form hydrazones with vitamin B_6_ derivatives (Comish 1969). By binding to vitamin B_6_ derivatives, hydrazine and 1,1-dimethylhydrazine are able to inhibit reactions that require vitamin B_6_ as a cofactor. These reactions include transamination reactions, decarboxylation and other transformations of amino acids, the metabolism of lipids and nucleic acids, and glycogen phosphorylation (NRC 1989). Deficiency of vitamin B_6_ can produce convulsions, dermatitis, and anemia. These data suggest that the convulsions and anemia observed in animal studies are the result of the formation of hydrazone derivatives of vitamin B_6_. In addition, some authors have proposed that a free amino group, as found in hydrazine and 1,1-dimethylhydrazine, is required for hydrazone formation (Comish 1969). This would explain why convulsions are associated with exposures to hydrazine and 1,1-dimethylhydrazine, and not 1,2-dimethylhydrazine. It should be noted that pyridoxine (one of the forms of vitamin B_6_) is commonly used to treat humans exposed to hydrazine or 1,1-dimethylhydrazine.

A number of in vitro studies have reported the production of reactive intermediates during the metabolism of hydrazines (see Section 2.3.3). Evidence for the production of radicals including methyl, acetyl, hydroxyl, and hydrogen radicals has been observed during the metabolism of hydrazine (Ito et al. 1992; Noda et al. 1988; Runge-Morris et al. 1988; Sinha 1987), l,l-dimethylhydrazine (Albano et al. 1989; Tomasi et al. 1987), and 1,2-dimethylhydrazine (Albano et al. 1989; Augusto et al. 1985; Netto et al. 1987; Tomasi et al. 1987). Multiple pathways, both enzymatic and nonenzymatic, appear to be involved in free radical generation. Free radicals have been implicated in protein (hemoglobin) damage associated with hydrazine in human erythrocytes (Runge-Morris et al. 1988), suggesting that free radicals may be involved in the anemic effects of hydrazines observed in animals in vivo (Haun and Kinkead 1973; Rinehart et al. 1960). It has also been proposed that metabolism of 1,2-dimethylhydrazine yields a reactive, methyldiazonium ion (Feinberg and Zedeck 1980; Sohn et al. 1991). The production of reactive species during the metabolism of hydrazines may also explain their genotoxic effects, such as the formation of DNA and RNA adducts in vivo (Becker et al. 1981; Beranek et al. 1983; Bolognesi et al. 1988; Bosan et al. 1986; Netto et al. 1992; Pozharisski et al. 1975; Quintero-Ruiz et al. 1981). DNA and RNA adducts may well be responsible for gene mutations observed in a number of in vitro studies (DeFlora and Mugnoli 1981; Hawks and Magee 1974; Kang 1994; Kerklaan et al. 1983; Levi et al. 1986; Malaveille et al. 1983;Noda et al. 1986; Oravec et al. 1986; Parodi et al. 1981; Rogers and Back 1981; Sedgwick 1992; Wilpart et al. 1983) and may also serve as the initiating event for cancers induced by hydrazines in vivo.

## 2.5 RELEVANCE TO PUBLIC HEALTH

Data regarding the toxic effects of hydrazines in humans are limited to a few case studies of accidental exposure and chemotherapy trials in cancer patients. Studies consistently indicate that the central nervous system is the primary target for hydrazine and 1,1-dimethylhydrazine following inhalation, oral, and dermal exposures. In some cases, neurological effects were delayed, but most effects were observed either during exposure or soon after. Quantitative data on human exposures are available only for oral exposures of intermediate durations.

Studies in animals, which support the findings from human studies, report neurological effects following inhalation, dermal, and parenteral exposures to hydrazine and 1,1-dimethylhydrazine. Neurological effects do not appear to be of concern following exposure to 1,2-dimethylhydrazine. Effects on the liver have been consistently reported in animal studies following exposure to all three hydrazines. Limited studies in animals suggest that exposure to hydrazines by the inhalation, oral, and parenteral routes may cause reproductive and developmental effects. A number of species-, sex-, and strain-specific differences have been observed for sensitivity to the toxic effects of hydrazines. All three hydrazines are carcinogenic in animals following oral and inhalation exposures. 1,2-Dimethylhydrazine is a potent carcinogen in animals and can induce tumors following single oral or parenteral doses.

Data regarding the toxicokinetics of hydrazines are limited but suggest that in animals hydrazines are rapidly absorbed and distributed to all tissues and that metabolites are excreted largely in the urine or released in expired air. Limited data in humans suggest that people with a slow acetylator genotype do not clear hydrazine from the body as well as those who are fast acetylators and therefore may be more susceptible to the toxic effects of hydrazine.

### Minimal Risk Levels for Hydrazines

#### Inhalation MRLs

- An MRL of 4X10^−3^ ppm has been derived for intermediate-duration inhalation exposure to hydrazine. This MRL is based on a LOAEL of 0.2 ppm for moderate fatty liver changes observed in female mice (Haun and Kinkead 1973). In this study, groups of 40 female ICR mice were exposed for 6 months to either 0, 0.2, or 1 ppm hydrazine continuously, or to 0, 1, or 5 ppm intermittently (6 hours/day, 5 days/week). The study authors also investigated the effects of inhaled hydrazine in other species. In support of this MRL, fatty liver changes were also observed in dogs exposed to 1 ppm hydrazine for 6 months and in monkeys exposed to 0.2 ppm for 6 months.
- An MRL of 2x10^−4^ ppm has been derived for intermediate inhalation exposure to 1,1 -dimethylhydrazine. This MRL is based on a LOAEL of 0.05 ppm for hepatic effects (hyaline degeneration of the gall bladder) in female mice (Haun et al. 1984). In this study, female C57BL/6 mice were exposed for 6 months to 0, 0.05, 0.5, or 5 ppm l,l-dimethylhydrazine for 6 hours/day, 5 days/week. The MRL is supported by other studies in humans (Petersen et al. 1970; Shook and Cowart 1957), rats (Haun et al. 1984), and dogs (Haun 1977; Rinehart et al. 1960), which indicate that the liver is a target of 1,1-dimethylhydrazine after inhalation exposure.

No inhalation MRLs were derived for exposures to hydrazines for acute or chronic durations. Although data from animal studies indicate that inhalation exposures to hydrazines produce adverse effects on the liver and central nervous system following acute (Rinehart et al. 1960) and chronic exposures (Vemot et al. 1985), these studies do not define the threshold exposure level for these effects with confidence.

#### Oral MRLs

- An MRL of 8×10^−4^ mg/kg/day has been derived for intermediate oral exposure to 1,2-dimethylhydrazine. This MRL is based on a LOAEL of 0.75 mg/kg/day for mild hepatitis in mice (Visek et al. 1991). In this study, groups of 25 male mice were administered 0, 0.75, 1.6, or 2.7 mg/kg/day 1,2-dimethylhydrazine in the diet for 5 months. This MRL is supported by studies reporting LOAELs for hepatic effects ranging from 4.2-30 mg/kg/day 1,2-dimethylhydrazine in several other species, including rats (Bedell et al. 1992), guinea pigs (Wilson 1976), dogs (Wilson 1976), and pigs (Wilson 1976).

No oral MRLs were derived for exposures to hydrazine or for exposure to l,l-dimethylhydrazine for acute and chronic durations. Although data are available for neurological effects in humans after intermediate-duration exposure to hydrazine (Chlebowski et al. 1984; Gershanovich et al. 1976, 1981; Ochoa et al. 1975; Spremulli et al. 1979), the effects levels were inconsistent among studies. Studies in animals have reported effects on the liver following acute-duration (Marshall et al. 1983; Wakabayashi et al. 1983; Wilson 1976) and intermediate-duration exposures (Biancifiori 1970). However, these data do not define the threshold dose for hepatic effects with confidence.

No acute-, intermediate-, or chronic-duration dermal MRLs were derived for hydrazines because of the lack of an appropriate methodology for the development of dermal MRLs.

Death. Data regarding the lethal effects of hydrazines in humans are limited to a single case study involving inhalation exposure to hydrazine. Death was reported in a male worker exposed to an undetermined concentration of hydrazine once a week for 6 months (Sotaniemi et al. 1971). Death in this case was due to lesions of the kidneys and lungs with complicating pneumonia. The effects on the kidneys and lungs, as well as effects in other tissues, were comparable to those observed in animals exposed to hydrazine. Therefore, death in this case is most likely attributed to hydrazine exposure.

A number of animal studies have reported acute lethality after exposure by most routes to hydrazines. For inhalation exposures, deaths were observed in dogs and mice after acute exposure to 25-140 ppm 1,1-dimethylhydrazine (Rinehart et al. 1960). No studies were located that examined lethality after acute-duration inhalation exposure to hydrazine or 1,2-dimethylhydrazine. For oral exposures, doses of 133 mg/kg hydrazine, 533 mg/kg/day 1,1-dimethylhydrazine, and 11.7-90 mg/kg 1,2-dimethylhydrazine caused deaths in mice and/or dogs (Roe et al. 1967; Visek et al. 1991; Wilson 1976). For dermal exposures, LD_50_ values ranging from 93 to 1,680 mg/kg were reported for all three hydrazines in rabbits and guinea pigs (Rothberg and Cope 1956). Deaths were noted in dogs after application of a single dose of 96 mg/kg hydrazine or 300 mg/kg 1,1-dimethylhydrazine (Smith and Clark 1971, 1972). A large number of studies have reported deaths in several animal species following injections of 8-400 mg/kg/day hydrazine (Bodansky 1923; Lee and Aleyassine 1970; O’Brien et al: 1964; Roberts and Simonsen 1966; Rothberg and Cope 1956; Wakebayashi et al. 1983), 71-125 mg/kg/day l,l-dimethylhydrazine (Back and Thomas 1962; Furst and Gustavson 1967; Geake et al. 1966; O’Brien et al. 1964; Rothberg and Cope 1956), and 44-60 mg/kg 1,2-dimethylhydrazine (Rothberg and Cope 1956; Wilson 1976). These doses are comparable to those producing death following oral exposure, suggesting that hydrazines are absorbed fairly well by the oral route. Limited information from a single oral study suggests that male animals are more sensitive to the lethal effects of hydrazine than females (Visek et al. 1991).

A number of studies have reported increased mortality following exposure to hydrazines for intermediate durations. Following inhalation exposures, increased mortality was noted in mice and dogs exposed to 1 ppm hydrazine (Haun and Kinkead 1973), and in mice exposed to 75 ppm 1,1-dimethylhydrazine (Rinehart et al. 1960), but not in several species following intermediate exposure to 0.05-5 ppm l,l-dimethylhydrazine (Haun et al. 1984). Oral exposures of 2.3-4.9 mg/kg/day hydrazine (Biancifiori 1970), 33 mg/kg/day 1,1-dimethylhydrazine (Roe et al. 1967), and 4.5-60 mg/kg/day 1,2-dimethylhydrazine (Teague et al. 1981; Visek et al. 1991; Wilson 1976) caused deaths in a number of animal species. Increased mortality was observed in several animal species after injections of 20-21.8 mg/kg/day hydrazine (Bodansky 1923; Patrick and Back 1965), 30 mg/kg/day l,l-dimethylhydrazine (Comish and Hartung 1969), and 15-60 mg/kg/day 1,2-dimethylhydrazine (Wilson 1976).

Data regarding lethality effects in animals after chronic exposure to hydrazines are limited to two studies. Mortality was significantly increased in hamsters exposed to 0.25 ppm hydrazine in air for 1 year (Vernot et al. 1985), and in mice exposed to 0.95 mg/kg/day hydrazine via the drinking water (Toth and Patil 1982). These exposures are notably lower than those producing fatalities after acuteand intermediate-duration exposure to hydrazine.

### Systemic Effects

Respiratory Effects. Pneumonia, tracheitis, and bronchitis were observed in a man occupationally exposed to an undetermined concentration of hydrazine in air once a week for 6 months (Sotaniemi et al. 1971). Dyspnea and pulmonary edema were observed in two men exposed to a mixture of hydrazine and 1,1-dimethylhydrazine (Frierson 1965). Hyperplasia was observed in the lungs of rats and mice exposed to 0.05 ppm 1,1-dimethylhydrazine for 6 months (Haun et al. 1984). Lung irritation and damage has been noted in dogs after intermediate-duration exposure to 25 ppm l,l-dimethylhydrazine but not 5 ppm l,l-dimethylhydrazine (Rinehart et al. 1960). Similarly, pulmonary effects were observed in rats chronically exposed to 5 ppm hydrazine but not in mice chronically exposed to 1 ppm hydrazine (Vernot et al. 1985). Effects on the nasal mucosa, including inflammation, hyperplasia, and dysplasia were noted in mice chronically exposed to 5 ppm 1,1-dimethylhydrazine (Haun et al. 1984). Pulmonary edema, congestion, and pneumonia were observed in rats injected with 20 mg/kg/day hydrazine but not in rats injected with 10 mg/kg/day hydrazine (Patrick and Back 1965). No adverse effects were observed in the lungs of mice exposed to 9.5 mg/kg/day hydrazine via the drinking water for 2 years (Steinhoff et al. 1990). These data suggest that effects on the lungs and upper respiratory tract are of concern primarily following inhalation exposures to hydrazines.

Cardiovascular Effects. Data regarding the cardiovascular effects of hydrazines in humans are limited to a single case study involving inhalation exposure to hydrazine. Intermittent exposure of a worker to an undetermined concentration of hydrazine in air for 6 months produced atria1 fibrillation, enlargement of the heart, and degeneration of heart muscle fibers (Sotaniemi et al. 1971). The findings from animal studies have been inconsistent. No adverse effects were noted on the cardiovascular system of dogs exposed to 25 ppm l,l-dimethylhydrazine or mice exposed to 1 ppm hydrazine for intermediate and chronic durations (Rinehart et al. 1960; Vernot et al. 1985). Mice exposed to 0.05-5 ppm l,l-dimethylhydrazine for 6 months to 1 year had abnormally dilated blood vessels (angiectesis) (Haun et al. 1984). Focal myocytolysis, fibrosis, and calcification of the heart were noted in mice receiving 1.6 mg/kg/day 1,2-dimethylhydrazine in the feed for 5 months (Visek et al. 1991). Slight accumulation of fat was observed in the myocardium of monkeys receiving 5 mg/kg/day hydrazine by intraperitoneal injection for l-4 weeks (Patrick and Back 1965). Changes in blood pressure were noted in dogs following a single injection of 100 mg/kg 1,1-dimethylhydrazine (Back and Thomas 1962). Cardiovascular effects were not observed in mice receiving 0.75 mg/kg/day 1,2-dimethylhydrazine (Visek et al. 1991). No adverse effects were observed in the hearts of rats injected with 20 mg/kg/day hydrazine for 5 weeks (Patrick and Back 1965) or in mice receiving 9.5 mg/kg/day hydrazine in the drinking water for 2 years (Steinhoff et al. 1990). The findings of the animal studies, although inconsistent, suggest that the cardiovascular effects observed in the human case study are related to hydrazine exposure.

Gastrointestinal Effects. Oral exposure to hydrazine has produced nausea and vomiting in human cancer patients. These effects could be due to direct irritation of the gastrointestinal tract but could also be due to effects on the central nervous system. Studies in animals generally have not reported effects on the gastrointestinal system following intermediate and chronic inhalation exposures to 25 ppm l,l-dimethylhydrazine (Rinehart et al. 1960) or 1 ppm hydrazine (Vernot et al. 1985). Similarly, chronic oral exposure to 9.5 mg/kg/day hydrazine were without effect on the gastrointestinal system of mice (Steinhoff et al. 1990). Proliferation, dysplasia, and hyperplasia of the colon mucosa have been observed in rats orally exposed to 25 mg/kg 1,2-dimethylhydrazine or injected with 15-20 mg/kg 1,2-dimethylhydrazine (Caderni et al. 1991; Decaens et al. 1989; Wargovich et al. 1983). These effects are most likely precursors of carcinogenic lesions induced by 1,2-dimethylhydrazine in this tissue site. Although these data suggest that the gastrointestinal system is not a primary target of the noncarcinogenic effects of hydrazines, this is not certain, particularly for 1,2-dimethylhydrazine.

Hematological Effects. No studies were located regarding hematological effects in humans after exposure to hydrazines. Studies in dogs indicate that inhalation exposure for intermediate durations to relatively high concentrations of hydrazine (1-5 ppm), but not 1,1-dimethylhydrazine, produces anemia (Haun and Kinkead 1973; Haun et al. 1984; Rinehart et al. 1960). Signs of anemia were not observed in dogs exposed to 0.2 ppm hydrazine. Hematological effects (decreased thromboplastin generation time) were also noted in dogs exposed to a single dermal dose of 5 mmol/kg 11-dimethylhydrazine (Smith and Castaneda 1970). However, hematological effects have not been observed in other species. For example, rats, hamsters, and monkeys exposed to 1 ppm hydrazine or 5 ppm 1,1-dimethylhydrazine for 6 months (Haun and Kinkead 1973; Haun et al. 1984) and rats and monkeys injected with 10-50 mg/kg/day 1,1-dimethylhydrazine (Cornish and Hartung 1969; Patrick and Back 1965) did not exhibit any hematological effects. These data suggest that dogs may be particularly sensitive to the hematological effects of hydrazines. Currently, it is not known if dogs are good animal models for the hematological effects of hydrazines in humans; therefore, it is uncertain if this effect is of concern to humans exposed to hydrazines.

Musculoskeletal Effects. No studies were located regarding musculoskeletal effects in humans after exposure to hydrazines. Data in animals are limited to a single study. No adverse effects were observed in the muscle tissue of mice chronically exposed to 9.5 mg/kg/day hydrazine (Steinhoff et al. 1990). These data are too limited to determine if effects on the musculoskeletal system are of concern for humans exposed to hydrazines.

Hepatic Effects. Areas of focal necrosis and cell degeneration were noted in the liver of a worker exposed to an undetermined concentration of hydrazine in air once a week for 6 months (Sotaniemi et al. 1971). These effects on the liver, however, were not contributing factors in the worker’s death. Elevated serum alanine aminotransferase activity, fatty degeneration, and a positive cephalin flocculation test were seen in workers exposed to 1,1-dimethylhydrazine (Petersen et al. 1970; Shook and Cowart 1957). A large number of studies in animals were located regarding the hepatotoxic effects of hydrazines. Multiple effects on the liver (hemosiderosis, degeneration, fatty changes, elevated serum enzymes, hyperplasia) have been observed in a number of species following inhalation exposure to 0.25-5 ppm hydrazine (Haun and Kinkead 1973; Vernot et al. 1985) or 0.05-25 ppm 1,1-dimethylhydrazine (Haun 1977; Haun et al. 1984; Rinehart et al. 1960). Hepatotoxic effects (fatty changes, degeneration, necrosis, hemosiderosis, hepatitis, fibrosis) were also observed in animals following oral exposure to 4.9-650 mg/kg/day hydrazine (Biancifiori 1970; Marshall et al. 1983; Preece et al. 1992a; Wakabayashi et al. 1983) and 0.75-60 mg/kg/day 1,2-dimethylhydrazine (Bedell et al. 1982; Visek et al. 1991; Wilson 1976). Similar effects were observed in animals receiving injections of 5-45 mgfkg/day hydrazine (Bodansky 1923; Patrick and Back 1965; Reinhardt et al. 1965b; Warren et al. 1984) or 3-333 mg/kg/day 1,2-dimethylhydrazine (Dixon et al. 1975; Pozharisski et al. 1976; Wilson 1976). Species differences in sensitivity were noted in individual studies, but these were not consistently observed across studies. Although data are lacking on the hepatic effects of 1,2-dimethylhydrazine by the inhalation route and 1,1-dimethylhydrazine by the oral route, these data clearly indicate that the liver is an important target organ and that hepatic effects are of potential concern for humans exposed to hydrazines.

Renal Effects. Data regarding the renal effects of hydrazines in humans are limited to a single case study. This study reported severe renal effects (tubular necrosis, hemorrhaging, inflammation, discoloration, enlargement) in a worker after exposure to an undetermined concentration of hydrazine (Sotaniemi et al. 1971). The renal effects were a significant factor in the worker’s death. Renal effects have been observed in several animal studies. Following inhalation exposure to 0.25 ppm hydrazine, mild effects were noted in the kidneys of hamsters (Vernot et al. 1985). Similarly, signs of mild renal toxicity were observed in rats and dogs injected with 16-64 mg/kg/day hydrazine (Dominguez et al. 1962; Van Stee 1965) or 50 mg/kg/day 1,1-dimethylhydrazine (Comish and Hartung 1969). More severe effects (nephritis) were noted in the kidneys of mice orally exposed to 1.6 mg/kg/day 1,2-dimethylhydrazine (Visek et al. 1991) and in dogs and monkeys injected with 20-28 mg/kg/day hydrazine (Bodansky 1923; Patrick and Back 1965). However, no effects were observed in the kidneys of dogs exposed to 25 ppm l,l-dimethylhydrazine by the inhalation route (Rinehart et al. 1960), in mice exposed to 0.75 mg/kg/day 1,2-dimethylhydrazine or 9.5 mg/kg/day hydrazine by the oral route (Steinhoff et al. 1990; Visek et al. 1991), or in rats injected with 20 mg/kg/day hydrazine (Patrick and Back 1965). These animal studies support the findings of the human case study and suggest that the kidney is an important target organ, at least following exposure to high doses of hydrazines.

Endocrine Effects. Mice exposed to hydrazine for 25 weeks exhibited degeneration of the adrenals, but no adverse effects in the thyroid, while exposed hamsters exhibited no effects in either organ (Biancifiori 1970). Overall, there is little evidence that the endocrine system is a major target of hydrazines.

Dermal Effects. Contact dermatitis has been observed in humans after dermal exposure to dilute solutions containing hydrazine (Hovding 1967; Suzuki and Ohkido 1979; Wrangsjo and Martensson 1986). Dermal effects (discoloration, irritation) and ocular effects (cornea1 swelling) were also observed in dogs, rabbits, and guinea pigs after dermal exposure to hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine (Rothberg and Cope 1956; Smith and Castaneda 1970; Smith and Clark 1971, 1972). However, by the oral route, no effects were observed in the skin of mice exposed to 9.5 mg/kg/day hydrazine (Steinhoff et al. 1990). These data indicate that direct contact with hydrazines causes irritation of the skin.

Ocular Effects. Conjunctivitis was consistently observed in a worker repeatedly exposed to an undetermined concentration of hydrazine (Sotaniemi et al. 1971). Eye irritation was noted in monkeys exposed to 1 ppm hydrazine in air but not in monkeys exposed to 0.2 ppm hydrazine (Haun and Kinkead 1973). Thus direct contact with hydrazine may cause irritation of the eyes.

Body Weight Effects. A large number of studies in animals exposed orally or by injection to hydrazines have reported decreased body weight gain. For example, oral exposure to 0.75-60 mg/kg/day 1,2-dimethylhydrazine (Barbolt and Abraham 1980; Visek et al. 1991; Wilson 1976), 5 mg/kg/day 1,1-dimethylhydrazine (Haun et al. 1984), or 9.5 mg/kg/day hydrazine (Steinhoff et al. 1990) decreased body weight gain in a number of animal species. Similarly, injection of 5-10 mg/kg/day hydrazine (Patrick and Back 1965), 10 mg/kg/day 1,1-dimethylhydrazine (Patrick and Back 1965), or 60 mg/kg/day 1,2-dimethylhydrazine (Wilson 1976) decreased animal body weight gain. These decreases in body weight gain are most likely due, at least in part, to decreased food intake. The decreased food intake may be due to taste aversion in feed studies; however; the appearance of this effect in animals exposed by other routes suggests that appetite may be decreased. Alternatively, decreases in body weight gain may be secondary to an underlying disease (e.g., cancer).

Immunological and Lymphoreticular Effects. Very little information is available regarding immunological and lymphoreticular effects of hydrazines. Several studies in humans indicate that dermal exposure to hydrazine produces contact dermatitis (Hovding 1967; Suzuki and Ohkich 1979; Wrangsjo and Martensson 1986). In addition, there are some data from case studies in humans which suggest that exposure to hydrazine and other hydrazine derivatives can produce a lupus erythematosuslike disease (Pereyo 1986; Reidenberg et al. 1983). However, this possibility warrants further investigation before firm conclusions can be made.

A single study in animals reported no effect in the splenic natural killer cell activity in rats orally exposed to 27.1 mg/kg/day 1,2-dimethylhydrazine (Locniskar et al. 1986). However, in mice injected with 75 mg/kg/day 1,1-dimethylhydrazine, a decreased T helper cell count was observed (Frazier et al. 1991). In vitro studies have reported that l,l-dimethylhydrazine induces immunomodulation (enhancing some immune functions while diminishing others) in mouse lymphocytes and splenocytes (Bauer et al. 1990; Frazier et al. 1992). These data are limited, but suggest that humans exposed to hydrazines may be at risk of developing immunological effects.

Neurological Effects. Neurological effects have been noted in humans after inhalation, oral, and dermal exposure to hydrazines. For inhalation exposure, these effects included nausea, vomiting, tremors, and impairment of cognitive functions (Richter et al. 1992; Sotaniemi et al. 1971). Neurological symptoms of nausea, vomiting, dizziness, excitement, lethargy, and neuritis have been reported in some cancer patients treated orally with 0.2-0.7 mg/kg/day hydrazine (Chlebowski et al. 1984; Gershanovich et al. 1976, 1981; Ochoa et al. 1975; Spremulli et al. 1979). Dermal exposure to hydrazine or l,l-dimethylhydrazine as a result of an industrial explosion produced narcosis, coma, and polyneuritis in two workers (Dhennin et al. 1988; Kirklin et al. 1976). Neurological effects (depression, seizures, convulsions, tremors, lethargy, behavioral changes) have also been observed in a number of animal species following inhalation exposure to 1 ppm hydrazine (Haun and Kinkead 1973), and 25-75 ppm l,l-dimethylhydrazine (Rinehart et al. 1960). Effects on the central nervous system were also observed in dogs after dermal exposure to 96-480 mg/kg hydrazine (Smith and Clark 1972) or 300-1,800 mg/kg l,l-dimethylhydrazine (Smith and Clark 1971). Similar neurological effects were noted in animals after injection of 16-350 mg/kg/day hydrazine (Floyd 1980; Mizuno et al. 1989; Patrick and Back 1965) or 4-125 mg/kg/day l,l-dimethylhydrazine (Furst and Gustavson 1967; Geake et al. 1966; Goff et al. 1967, 1970; Minard and Mushahwar 1966; O’Brien et al. 1964; Reynolds et al. 1964; Segerbo 1979; Sternran and Fairchild 1967). The studies in humans and animals convincingly demonstrate that the central nervous system is a target for persons exposed to hydrazine or l,l-dimethylhydrazine. However, based on the mechanism by which hydrazine and l,l-dimethylhydrazine affect the central nervous system, neurological effects do not appear to be of concern for humans exposed to 1,2-dimethylhydrazine.

Reproductive Effects. Data regarding the reproductive effects of hydrazines are limited to a few animal studies. Reproductive effects (ovarian and testicular atrophy, endometrial inflammation, aspermatogenesis) were observed in hamsters exposed to 1-5 ppm hydrazine by the inhalation route (Vemot et al. 1985). The incidence of endometrial cysts was significantly elevated in female mice exposed to 0.05 ppm 1,1-dimethylhydrazine (Haun et al. 1984). Sperm abnormalities and decreased caudal epididymal sperm counts were noted in mice injected with 8 mg/kg/day hydrazine or 12.5-68.8 mg/kg/day 1,1-dimethylhydrazine (Wyrobek and London 1973). These effects were not observed in hamsters exposed to 0.25 ppm hydrazine by the inhalation route (Vemot et al. 1985) or in mice and hamsters exposed to 5.3-9.5 mg/kg/day hydrazine by the oral route (Biancifiori 1970). No studies were located regarding the reproductive effects of 1,2-dimethylhydrazine. In addition, no studies were located which investigated effects of hydrazines on reproductive function. Despite the inconsistency of the findings from animal studies, the serious nature of the reproductive effects observed in the positive studies makes them one of concern for humans exposed to hydrazine.

Developmental Effects. Signs of developmental toxicity or teratogenicity were not observed in hamsters exposed to a single dose of 166 mg/kg hydrazine or 68 mg/kg 1,2-dimethylhydrazine on day 12 of gestation (Schiller et al. 1979). Likewise, Keller et al. (1984) examined the effects of 1,l -dimethylhydrazine (10-60 mg/kg/day) and 1,2-dimethylhydrazine (2-10 mg/kg/day) given intra peritoneally to pregnant rats on days 6-15 of gestation, and found no dose-related teratogenic effects. Embryotoxicity, manifested as reduced fetal weight, occurred only in the animals treated with the highest dose levels of either chemical. However, in another study increased prenatal and perinatal mortality was reported in rats injected with 8 mg/kg/day hydrazine during gestation days 11-21 (Lee and Aleyassine 1970). The data in animals are inconsistent between routes of exposure and are too limited to permit firm conclusions regarding the potential for developmental effects in humans exposed to hydrazines.

Genotoxic Effects. No studies were located regarding genotoxic effects in humans after exposure to hydrazines. Studies regarding the genotoxic effects in animals after oral or injection exposure to hydrazines are summarized in Table 2-4, while in vitro studies are presented in Table 2-5. These findings are discussed below.

Data from in vivo studies indicate that hydrazines are alkylating agents. The methylation of tissue DNA was reported in animals exposed orally to hydrazine (Becker et al. 1981; Bosan et al. 1986) or by injection to hydrazine (Bosan et al. 1986; Quintero-Ruiz et al. 1981) or 1,2-dimethylhydrazine (Beranek et al. 1983; Bolognesi et al. 1988; Hawks and Magee 1974; Netto et al. 1992; Pozharisski et al. 1975; Rogers and Pegg 1977). The mechanism by which adducts are formed may involve the generation of reactive species (methyldiazanium ions or methyl free radicals) (Albano et al. 1989; Augusto et al. 1985; Feinberg and Zedeck 1980; Netto et al. 1987, 1992). The formation of methyl adducts with DNA bases in vivo may be one of the mechanisms by which hydrazines have produced DNA damage (Parodi et al. 1981), gene mutations (Jacoby et al. 1991; Winton et al. 1990; Zeilmaker et al. 1991; Zijlstra and Vogel 1988), micronuclei (Albanese et al. 1988; Ashby and Mirkova 1987), and sister chromatid exchange (Couch et al. 1986; Neft and Conner 1989). In vivo studies on the genotoxicity of hydrazines have largely reported positive results, although hydrazine did not induce unscheduled DNA synthesis in mouse sperm cells (Sotomayor et al. 1982). In addition, 1,2-dimethylhydrazine failed to induce micronuclei in rat bone marrow cells, even though this effect has been observed in mouse bone marrow cells (Albanese et al. 1988; Ashby and Mirkova 1987).

A large number of in vitro studies have reported genotoxic effects for all three hydrazines. Hydrazines produced methyl adducts in DNA from human cells (Au&up et al. 1980a; Harris et al. 1977; Kumari et al. 1985) and in free DNA (Bosan et al. 1986; Lambert and Shank 1988), but adducts were not noted in Chinese hamster V79 cells (Boffa and Bolognesi 1986). Gene mutations have been observed in human teratoma cells (Oravec et al. 1986), mouse lymphoma cells (Rogers and Back 1981), and in several strains of bacteria (DeFlora and Mugnoli 1981; Kerklaan et al. 1983; Levi et al. 1986; Malaveille et al. 1983; Noda et al. 1986; Parodi et al. 1981; Sedgwick 1992; Wilpart et al. 1983). Other genotoxic effects observed in mammalian cells exposed to hydrazines include sister chromatid exchange (MacRae and Stich 1979), transformation (Kumari et al. 1985), and unscheduled DNA synthesis (Mori et al. 1988). The administration of 25 or 50 mg/kg hydrazine subcutaneously to neonatal rats was necrogenic to the liver (Leakakos and Shank 1994). Liver DNA isolated from these animals was shown to have site-specific damage in that one or more Mspl sites were lost or blocked.

TABLE 2-4 Genotoxicity of Hydrazines In Vivo

Species (test system) | End point | Results | Reference | Form
Mammalian cells:
Rat liver and colon | DNA alkylation | + | Netto et al. 1992 | 12DMH
Rat liver and colon | DNA alkylation | + | Hawks and Magee 1974 | 12DMH
Rat liver and colon | DNA alkylation | + | Netto et al. 1992 | 12DMH
Rat liver | DNA alkylation | + | Bosan et al. 1986 | H
Rat liver, colon, and kidney | DNA alkylation | + | Rogers and Pegg 1977 | 12DMH
Rat liver, kidney and intestines | DNA alkylation | + | Pozharisski et al. 1975 | 12DMH
Rat liver | DNA alkylation | + | Becker et al. 1981 | H
Rat liver | DNA alkylation | + | Beranek et al. 1983 | 12DMH
Mouse liver | DNA alkylation | + | Quintero-Ruiz et al. 1981 | HS
Mouse liver and colon | DNA alkylation | + | Hawks and Magee 1974 | 12DMH
Rat liver and colon | RNA alkylation | + | Kang 1994 | 12DMH
Rat liver, kidney, and colon | DNA damage | + | Bolognesi et al. 1988 | 12DMH
Mouse liver and lung | DNA damage | + | Parodi et al 1981 | 11DMH
Mouse liver and lung | DNA damage | + | Parodi et al 1981 | 12DMH
Mouse liver and lung | DNA damage | + | Parodi et al 1981 | HH
Mouse lung, liver, and kidney | Decreased DNA content | + | D’Souza and Bhide 1975 | HS
Mouse intestine | Gene mutation | + | Winton et al. 1990 | 12DMH
Rat colon | Gene mutation | + | Jacoby et al. 1991 | 12DMH
Rat colon | Gene mutation | + | Jacoby et al. 1991 | 12DMH
Rat colon | Gene mutation | + | Llor et al. 1991 | 12DMH
Mouse colon | Inhibition of DNA repair | + | Koval 1984 | 12DMH
Rat bone marrow | Micronuclei | − | Albanese et al. 1988 | 12DMH
Mouse bone marrow | Micronuclei | + | Albanese et al. 1988 | 12DMH
Mouse bone marrow | Micronuclei | + | Ashby and Mirkova 1987 | 12DMH
Mouse colon | Sister chromatid exchange | + | Couch et al. 1986 | 12DMH
Mouse bone marrow, lung, liver, and kidney | Sister chromatid exchange | + | Neft and Conner 1989 | 12DMH
Mouse blood and spleen lymphocytes | Sister chromatid exchange | + | Neft and Conner 1989 | 12DMH
Mouse sperm | Unscheduled DNA synthesis | − | Sotomayor et al. 1982 | H
Mouse sperm | Dominant lethal mutation | − | Brusick and Matheson 1976 | 11DMH
Nonmammalian cells:
Drosophila melanogaster | Gene mutation | − | Zijlstra and Vogel 1988 | 11DMH
Drosophila melanogaster | Gene mutation | -- | Zijlstra and Vogel 1988 | 12DMH
Host-mediated assays:
Mouse | Gene mutation (Escherichia coli) | + | Zeilmaker et al. 1991 | 12DMH

− = negative result; + = positive result

11DMH = 1,1-dimethylhydrazine; 12DMH = 1,2-dimethylhydrazine; DNA = deoxyribonucleic acid; H = hydrazine; HH = hydrazine hydrate; HS = hydrazine sulfate

TABLE 2-5 Genotoxicity of Hydrazines In Vitro

| | Results
Species (test system) | End point | With activation | Without activation | Reference | Form
Prokaryotic organisms:
Salmonella typhimurium | Gene mutation | + | + | Parodi et al 1981 | HH
S. Typhimurium | Gene mutation | + | + | DeFlora and Mugnoli 1981 | HH
S. Typhimurium | Gene mutation | + | + | Wilpart et al. 1983 | 12DMH
S. Typhimurium | Gene mutation | No data | − | Pence 1985 | 12DMH
S. Typhimurium | Gene mutation | + | + | Parodi et al 1981 | 12DMH
S. Typhimurium | Gene mutation | + | − | Malaveille et al. 1983 | 12DMH
S. Typhimurium | Gene mutation | + | − | Kerklaan et al. 1983 | 12DMH
S. Typhimurium | Gene mutation | + | + | DeFlora and Mugnoli 1981 | 12DMH
S. Typhimurium | Gene mutation | + | + | DeFlora and Mugnoli 1981 | 11DMH
S. Typhimurium | Gene mutation | + | + | Parodi et al 1981 | 11DMH
S. Typhimurium | Gene mutation | − | − | Brusick and Matheson 1976 | 11DMH
Saccharomyas cerevisiae | Gene mutation | − | − | Brusick and Matheson 1976 | 11DMH
Photobacterium leiognathi | Gene mutation | No data | + | Levi et al. 1986 | H
Escherichia coli | Gene mutation | + | No data | Noda et al. 1986 | H
E. coli | Gene mutation | No data | + | Sedgwick 1992 | 12DMH
E. coli | Gene mutation | No data | + | Sedgwick 1992 | 11DMH
E. coli | Gene mutation | − | − | Brusick and Matheson 1976 | 11DMH
Mammalian cells:
Human colon | DNA alkylation | No data | + | Autrup et al. 1980a | 12DMH
Human bronchi | DNA alkylation | + | No data | Harris et al. 1977 | 12DMH
Human fibroblasts | DNA alkylation | No data | + | Kumari et al. 1985 | 12DMH
Human fibroblasts | DNA alkylation | No data | + | Kumari et al. 1985 | 11DMH
Human teratoma | Gene mutation | + | No data | Oravec et al. 1986 | 12DMH
Human fibroblasts | Transformation | No data | + | Kumari et al. 1985 | 12DMH
Human fibroblasts | Transformation | No data | + | Kumari et al. 1985 | 11DMH
V79 Chinese hamster | DNA alkylation | + | − | Boffa and Bolognesi 1986 | 12DMH
Mouse lymphoma | Gene mutation | No data | + | Rogers and Back 1981 | H
Mouse lymphoma | Gene mutation | No data | + | Rogers and Back 1981 | 12DMH
Mouse lymphoma | Gene mutation | No data | + | Rogers and Back 1981 | 11DMH
Mouse lymphoma | Gene mutation | + | + | Brusick and Matheson 1976 | 11DMH
Chinese hamster ovary | Sister chromatid exchange | No data | + | MacRae and Stich 1979 | H
Chinese hamster ovary | Sister chromatid exchange | + | + | MacRae and Stich 1979 | 12DMH
Mouse hepatocytes | Unscheduled DNA synthesis | No data | + | Mori et al. 1988 | HS
Mouse hepatocytes | Unscheduled DNA synthesis | No data | + | Mori et al. 1988 | HH
Mouse hepatocytes | Unscheduled DNA synthesis | No data | + | Mori et al. 1988 | 12DMH
Rat hepatocytes | Unscheduled DNA synthesis | No data | + | Mori et al. 1988 | 12DMH
Human diploid W1-38 | Unscheduled DNA synthesis | − | (+) | Brusick and Matheson 1976 | 11DMH
Mouse hepatocytes | Unscheduled DNA synthesis | No data | + | Mori et al. 1988 | 11DMH
Noncellular assays:
Calf thymus DNA | DNA alkylation | + | − | Bosan et al. 1986 | H
Calf thymus DNA | DNA alkylation | + | − | Lambert and Shank 1988 | H
Plasmid DNA | DNA damage | No data | + | Yamamoto and Kawanishi 1991 | H
Plasmid DNA | DNA damage | No data | + | Kawanishi and Yamamoto 1991 | 11DMH
Plasmid DNA | DNA damage | No data | + | Kawanishi and Yamamoto 1991 | 12DMH

− = negative result; + = positive result; (+) = weakly positive result

11DMH = 1,1-dimethylhydrazine; 12DMH = 1,2-dimethylhydrazine; DNA = deoxyribonucleic acid; H = hydrazine; HH = hydrazine hydrate; HS = hydrazine sulfate

In vitro studies regarding the genotoxic effects of hydrazines have generally reported positive results, with and without metabolic activation. Taken together with the in vivo studies discussed above, these data clearly indicate that all three forms of hydrazine are genotoxic.

Cancer. No significant increase in cancer mortality was observed in a single epidemiology study of workers exposed to hydrazine (Morris et al. 1995; Wald et al. 1984), or in a U.S. Public Health Service survey of tuberculosis patients with isoniazid (Glassroth et al. 1977), which is metabolized to hydrazine. However, a large number of studies in animals have reported increased tumor incidence following inhalation, oral, and parenteral exposures to hydrazines. Following inhalation exposures to 5 ppm hydrazine, increased nasal and thyroid tumor incidences were reported in mice and hamsters (Vemot et al. 1985). Tumors of the lung, nasal passageways, bone, pancreas, pituitary, blood vessels, liver, and thyroid, and leukemia were observed at an increased incidence in mice or rats exposed to 0.05-5 ppm 1,1-dimethylhydrazine (Haun et al. 1984). It is possible that some of the carcinogenic effects of impure grades of l,l-dimethylhydrazine may be attributable to the presence of dimethylnitrosamine, a potent carcinogen, as a contaminant (Haun 1977).

Following oral exposures, doses of 0.46-16.7 mg/kg/day hydrazine increased the incidence of liver, kidney, breast, and particularly lung tumors in several animal species (Bhide et al. 1976; Biancifiori 1970; Biancifiori and Ribacchi 1962; Biancifiori et al. 1964, 1966; Bosan et al. 1987; Maru and Bhide 1982; Roe et al. 1967; Yamamoto and Weisburger 1970). Oral exposure to 33 mg/kg/day l,l-dimethylhydrazine increased the incidence of lung tumors in mice (Roe et al. 1967). Multiple tumor types, but most notably colon and blood vessel tumors, were induced in several animal species exposed to oral doses of 0.059-30 mg/kg/day 1,2-dimethylhydrazine (Abraham et al. 1980; Asano and Pollard 1978; Barbolt and Abraham 1980; Bedell et al. 1982; Calvert et al. 1987; Izumi et al. 1979; Locniskar et al. 1986; Teague et al. 1981; Thorup et al. 1992; Toth and Patil 1982; Wilson 1976). Colon tumors were also induced after single oral doses of 15.8-30 mg/kg 1,2-dimethylhydrazine (Craven and DeRubertis 1992; Schiller et al. 1980; Watanabe et al. 1985).

A large number of studies have reported the carcinogenic effects of 1,2-dimethylhydrazine by the injection route. These studies have reported an induction of tumor types similar to those reported for oral exposure following single injections of 15-143 mg/kg 1,2-dimethylhydrazine (Barnes et al. 1983; Decaens et al. 1989; Fujii and Komano 1989; Glauert and Weeks 1989; Karkare et al. 1991; Sunter and Senior 1983; Toth et al. 1976; Wargovich et al. 1983) and repeated injections of 3-40 mg/kg/day (Andrianopoulos et al. 1990; Barsoum et al. 1992; Decaens et al. 1989; Druckrey 1970; Hagihara et al. 1980; James et al. 1983; Nelson et al. 1992; Pozharisski et al. 1976; Shirai et al. 1983; Vinas-Salas et al. 1992). Peripheral nerve sheath tumors were observed in hamsters injected with 32.5 mg/kg/day 1,1l-dimethylhydrazine (Ernst et al. 1987).

Several government departments and regulatory offices have evaluated the evidence regarding the carcinogenicity of hydrazines. The Department of Health and Human Services has determined that hydrazine and 1,1-dimetbylhydrazine are reasonably anticipated to be carcinogens (NTP 1994). The International Agency for Research on Cancer has determined that hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine are probably carcinogenic to humans (Group 2B) (IARC 1987). The EPA has determined that hydrazine, 1,1-dimethylhydrazine, and 1,2-dimethylhydrazine are probable human carcinogens (Group B2) (HEAST 1992; IRIS 1995). The American Conference of Governmental Industrial Hygienists (ACGIH) currently lists hydrazine and 1,1-dimethylhydrazine as suspected human carcinogens (ACGIH 1994a). However, it has recently been recommended that the listing of hydrazine be changed to that of animal carcinogen, not likely to cause cancer in humans under normal exposure conditions (ACGIH 1994b).

## 2.6 BIOMARKERS OF EXPOSURE AND EFFECT

Biomarkers are broadly defined as indicators signaling events in biologic systems or samples. They have been classified as markers of exposure, markers of effect, and markers of susceptibility (NAUNRC 1989).

Due to a nascent understanding of the use and interpretation of biomarkers, implementation of biomarkers as tools of exposure in the general population is very limited. A biomarker of exposure is a xenobiotic substance or its metabolite(s), or the product of an interaction between a xenobiotic agent and some target molecule(s) or cell(s) that is measured within a compartment of an organism (NAWNRC 1989). The preferred biomarkers of exposure are generally the substance itself or substance-specific metabolites in readily obtainable body fluid(s) or excreta. However, several factors can confound the use and interpretation of biomarkers of exposure. The body burden of a substance may be the result of exposures from more than one source. The substance being measured may be a metabolite of another xenobiotic substance (e.g.g high urinary levels of phenol can result from exposure to several different aromatic compounds). Depending on the properties of the substance (e.g., biologic half-life) and environmental conditions (e.g., duration and route of exposure), the substance and all of its metabolites may have left the body by the time samples can be taken. It may be difficult to identify individuals exposed to hazardous substances that are commonly found in body tissues and fluids (e.g., essential mineral nutrients such as copper, zinc, and selenium). Biomarkers of exposure to hydrazines are discussed in Section 2.6.1.

Biomarkers of effect are defined as any measurable biochemical, physiologic, or other alteration within an organism that, depending on magnitude, can be recognized as an established or potential health impairment or disease (NAS/NRC 1989). This definition encompasses biochemical or cellular signals of tissue dysfunction (e.g., increased liver enzyme activity or pathologic changes in female genital epithelial cells), as well as physiologic signs of dysfunction such as increased blood pressure or decreased lung capacity. Note that these markers are not often substance specific. They also may not be directly adverse, but can indicate potential health impairment (e.g., DNA adducts). Biomarkers of effects caused by hydrazines are discussed in Section 2.6.2.

A biomarker of susceptibility is an indicator of an inherent or acquired limitation of an organism’s ability to respond to the challenge of exposure to a specific xenobiotic substance. It can be an intrinsic genetic or other characteristic or a preexisting disease that results in an increase in absorbed dose, a decrease in the biologically effective dose, or a target tissue response. If biomarkers of susceptibility exist, they are discussed in Section 2.8, “Populations That Are Unusually Susceptible.”

### 2.6.1 Biomarkers Used to Identify or Quantify Exposure to Hydrazines

Methods exist for measuring the levels of hydrazines and their metabolites in the plasma of humans (Blair et al. 1985) and in tissues, urine, and expired air of animals (Alvarez de Laviada et al. 1987; Back et al. 1963; Dost et al. 1966; Fiala and Kulakis 1981; Fiala et al. 1976; Harbach and Swenberg 1981; Kaneo et al. 1984; Kang et al. 1988; Matsuyama et al. 1983; Preece et al. 1991; Reed et al. 1963; Springer et al. 1981). These studies have employed calorimetric, chromatographic; and nuclear magnetic resonance techniques. Such methods require the use of expensive equipment and skilled technicians, which may limit the availability of facilities capable of monitoring exposure on a routine basis. The levels of hydrazines or their metabolites in tissues and excreta cannot presently be used to quantify past exposures. The detection of hydrazines and some of their metabolites (for example, azomethane and azoxymethane from 1,2-dimethylhydrazine) is a fairly specific biomarker of exposure. However, hydrazine is a metabolite of drugs such as isoniazid and hydralazine (Blair et al. 1985). Therefore, care must be taken to ensure that exposure to these drugs has not occurred. Other metabolites of hydrazines (for example, carbon dioxide and nitrogen) are endogenous to the body, and therefore, cannot be used as specific biomarkers of exposure.

### 2.6.2 Biomarkers Used to Characterize Effects Caused by Hydrazines

Effects on the liver are associated with exposure to hydrazines in humans (Sotaniemi et al. 1971) and animals (Haun and Kinkead 1973; Rinehart et al. 1960; Vemot et al. 1985; Wilson 1976). Therefore, assessment of serum transaminase activities may be useful in revealing liver damage in people exposed to hydrazines. Neurological effects are often observed following exposure to hydrazine and 1,1-dimethylhydrazine in humans (Chlebowski et al. 1984; Gershanovich et al. 1976; Ochoa et al. 1975; Richter et al. 1992; Sotaniemi et al. 1971) and animals (Haun and Kinkead 1973; Rinehart et al. 1960). The mechanism by which hydrazine and l,l-dimethylhydrazine produce neurological effects involves binding to vitamin B_6_ derivatives. Therefore, assessment of vitamin B_6_ status either by direct measurement in the blood, tryptophan load tests, or measurements of vitamin B_6_ -dependent activities in plasma or erythrocytes may serve to indicate if vitamin B6 status has been compromised by hydrazine or 1,1-dimethylhydrazine.

DNA adducts have been observed in animals exposed to hydrazines in vivo (Becker et al. 1991; Beranek et al. 1983; Bolognesi et al. 1988; Bosan et al. 1986; Netto et al. 1992; Pozharisski et al. 1975; Quintero-Ruiz et al. 1981; Rogers and Pegg 1977). RNA base adducts have also been observed in liver and colon after treatment of rats with 1,2-dimethylhydrazine (Hawks and Magee 1974; Kang 1994). However, these are somewhat difficult to detect and quantitate, and therefore, may not be useful as biomarkers of effect. An increased incidence of colon tumors is the most consistent effect observed following exposure to 1,2-dimethylhydrazine in animals (Abraham et al. 1980; Asano and Pollard 1978; Barbolt and Abraham 1980; Calvert et al. 1987; Izumi et al. 1979; Locniskar et al. 1986; Teague et al. 1981; Thorup et al. 1992; Wilson 1976). Simple tests for occult blood in the stools can be used as a preliminary screen for intestinal tumors. However, these types of effects can be caused by exposures to a large number of agents, and in no way are these biomarkers specific for the effects of hydrazines.

## 2.7 INTERACTIONS WITH OTHER SUBSTANCES

No studies were located regarding interactions in humans or animals after exposure to hydrazine or 1,1-dimethylhydrazine. On the other hand, a large number of studies are available in animals regarding the interactions of various treatments on 1,2-dimethylhydrazine-induced colon cancer. For example, high-fat diets, high-cholesterol diets, potassium chloride, caffeine, vitamin C, iron, ethoxyquin, and colorectal surgery were all found to increase the incidence, multiplicity, or malignancy of 1,2-dimethylhydrazine-induced intestinal tumors (Balansky et al. 1992; Bansal et al. 1978; Cruse et al. 1982; Locniskar et al. 1986; Nelson et al. 1992; Shirai et al. 1985; Siegers et al. 1992), whereas aspirin, bran, pectin, calcium, vitamin D, vitamin E, carbon tetrachloride, carbon disulfide, sodium selenate, butylated hydroxytoluene, corn oil, and calcium chloride were all found to decrease the incidence of these tumors (Balansky et al. 1992; Barnes et al. 1983; Barsoum et al. 1992; Belleli et al. 1992; Culvert et al. 1987; Colacchio et al. 1989; Craven and DeRubertis 1992; Heitman et al. 1992; Shirai et al. 1985). Other studies have reported that bran, beta-carotene, butylated hydroxyanisole, propyl gallate, and stress had no significant effect on tumors of the colon induced by 1,2-dimethylhydrazine (Andrianopoulos et al. 1990; Barbolt and Abraham 1980; Colacchio et al. 1989; Shirai et al. 1985; Thorup et al. 1992). A number of mechanisms are possible for these interactions including but not limited to interference with the metabolism of 1,2-dimethylhydrazine (Fiala et al. 1977), action as a scavenger for free radicals produced during 1,2-dimethylhydrazine metabolism, and influences at the post-initiation stage of colon carcinogenesis.

## 2.8 POPULATIONS THAT ARE UNUSUALLY SUSCEPTIBLE

A susceptible population will exhibit a different or enhanced response to hydrazines than will most persons exposed to the same level of hydrazines in the environment. Reasons include genetic makeup, developmental stage, age, health and nutritional status (including dietary habits that may increase susceptibility, such as inconsistent diets or nutritional deficiencies), and substance exposure history (including smoking). These parameters may result in decreased function of the detoxification and excretory processes (mainly hepatic, renal, and respiratory) or the pre-existing compromised function of target organs (including effects or clearance rates and any resulting end-product metabolites). For these reasons we expect the elderly with declining organ function and the youngest of the population with immature and developing organs will generally be more vulnerable to toxic substances than healthy adults. Populations who are at greater risk due to their unusually high exposure are discussed in Section 5.6, “Populations With Potentially High Exposure.”

Data from a single human study indicate that people with a slow acetylator genotype may be unusually susceptible to the effects of hydrazine. A pronounced accumulation of hydrazine was noted in the plasma of slow acetylator patients treated with isoniazid compared to those patients that were rapid acetylators (Blair et al. 1985). With 1,1-dimethylhydrazine, similar results may be observed. However, no information is available on humans for 1,1-dimethylhydrazine. Further investigation of this mechanism is warranted.

In animals, a number of studies have reported differences in susceptibility to the toxic effects of hydrazines with respect to species (Haun and Kinkead 1973; Rinehart et al. 1960; Vernot et al. 1985; Wilson 1976), strain (Asano and Pollard 1978; Bhide et al. 1976; Teague et al. 1981; Toth 1969), sex (Bhide et al. 1976; Biancifiori 1970; Teague et al. 1981; Visek et al. 1991), and age (Wakabayashi et al. 1983). Some of the differences in susceptibility may be related to differences in ability to metabolize hydrazines; however, many other differences still lack a satisfactory explanation.

## 2.9 METHODS FOR REDUCING TOXIC EFFECTS

This section describes clinical practice and research concerning methods for reducing toxic effects of exposure to hydrazines. However, because some of the treatments discussed may be experimental and unproven, this section should not be used as a guide for treatment of exposures to hydrazines. When specific exposures have occurred, poison control centers and medical toxicologists should be consulted for medical advice.

### 2.9.1 Reducing Peak Absorption Following Exposure

No data were located regarding methods for reducing absorption after inhalation exposure to hydrazines.

There are several methods by which the absorption of hydrazines can be reduced in the gastrointestinal tract. Induced emesis, gastric lavage, use of saline cathartics, or activated charcoal are all methods which are commonly used to decrease the gastrointestinal absorption of compounds such as hydrazines (Bronstein and Currance 1988; Sittig 1991; Stutz and Janusz 1988). In general, these treatments are most effective when used within a few hours after oral exposure. In some cases, these treatments may be contraindicated. For example, some authors contend that emesis should not be induced (Bronstein and Currance 1988). In addition, emesis should not be induced in obtunded, comatose, or convulsing patients. Oils should not be used as a cathartic, since they may enhance the gastrointestinal absorption of hydrazines.

Following dermal or ocular exposures to hydrazines, there are several methods by which absorption can be reduced. All contaminated clothing should be removed, and contacted skin should be washed immediately with soap and water (Bronstein and Currance 1988; Haddad and Winchester 1990; Sittig 1991; Stutz and Janusz 1988). Eyes that have come in contact with hydrazines should be flushed with copious amounts of water. Contact lenses should be removed prior to flushing with water. Proparacaine hydrochloride may be used to assist eye irrigation (Bronstein and Currance 1988).

### 2.9.2 Reducing Body Burden

Elimination of hydrazines in the urine may be enhanced by forced diuresis and acidification of the urine (Haddad and Winchester 1990). Hemodialysis and peritoneal dialysis may also be helpful, but this has not been fully studied. Activated charcoal is sometimes administered in serial doses to minimize the enterohepatic recirculation of persistent chemicals. Data regarding the enterohepatic recirculation of hydrazines were not located. However, available data suggest that hydrazines are readily cleared from the body since the levels in various tissues in animals are usually not detectable after 24 hours. In addition, studies in rats indicate that only a small percentage of a dose of 1,2-dimethylhydrazine (0.4-0.9%) is excreted in the bile (Hawks and Magee 1974). Therefore, it is not likely that efforts to minimize enterohepatic recirculation of hydrazines would be of much use.

### 2.9.3 Interfering with the Mechanism of Action for Toxic Effects

There are at least two distinct mechanisms by which hydrazines produce adverse health effects. Methods for interfering with these mechanisms are discussed below. The first mechanism involves the reaction of hydrazine or 1,1-dimethylhydrazine with endogenous alpha-keto acids such as vitamin B, (pyridoxine). The formation of hydrazones of pyridoxine is the proposed mechanism by which hydrazine and 1,1-dimethylhydrazine produce neurological effects. Several studies have reported successful treatment of neurological effects in humans exposed to hydrazine and 1,1-dimethylhydrazine with pyridoxine (Dhennin et al. 1988; Ellenhorn and Barceloux 1988; Haddad and Winchester 1990; Kirklin et al. 1976). In addition, several animal studies reported that pyridoxine diminished, and in some cases completely abolished, the lethal and neurological effects of hydrazine and 1,1-dimethylhydrazine (Geake et al. 1966; Lee and Aleyassine 1970; O’Brien et al. 1964; Segerbo 1979).

However, treatment with pyridoxine is not without risk. For example, some authors suggested that pyridoxine is also capable of producing neuropathy (Harati and Niakan 1986). This effect has been noted in humans exposed to hydrazines and treated with pyridoxine (Dhennin et al. 1988; Harati and Niakan 1986; Ochoa et al. 1975), but it is difficult to ascribe this effect to exposure to either hydrazines or pyridoxine alone. It is possible that the adverse effects of pyridoxine treatment may be associated with treatments using large doses. Evidence of a therapeutic window has been reported in animal studies (Geake et al. 1966). Studies in animals have also reported that the hydrazones of pyridoxine are more toxic than the corresponding hydrazine (Furst and Gustavson 1967). These data indicate that pyridoxine should be used with caution and that all potential risks and benefits should be considered prior to treatment. In any case, treatment with pyridoxine would not be expected to be beneficial for exposures to 1,2-dimethylhydrazine since this compound, unlike hydrazine and 1,1-dimethylhydrazine, does not form hydrazones.

The second mechanism by which hydrazines produce adverse health effects involves the generation of free radical intermediates. Free radicals have been detected during the metabolism of hydrazines in vitro (Albano et al. 1989; Augusto et al. 1985; Ito et al. 1992; Netto et al. 1987; Noda et al. 1988; Runge-Morris et al. 1988; Sinha 1987; Tomasi et al. 1987). Therefore, treatment with agents that act as free radical scavengers could offer a protective effect. In vitro studies have shown that glutathione is an effective scavenger of the free radicals produced from the metabolism of 1,1-dimethylhydrazine and 1,2-dimethylhydrazine (Tomasi et al. 1987). A number of animal studies have reported that aspirin, vitamin C, vitamin E, and butylated hydroxytoluene decreased the incidence, multiplicity, or malignancy of 1,2-dimethylhydrazine-induced intestinal tumors (Belleli et al. 1992; Colacchio et al. 1989; Cook and McNamara 1980; Craven and DeRubertis 1992; Shirai et al. 1985). It is possible that this protective effect may occur via inhibition of metabolic activation or a free radical scavenging mechanism, and if so, treatment would be most effective if administered relatively soon after exposure; however, the mechanism is not known conclusively and warrants further investigation.

Since reactive intermediates are produced as a result of the metabolism of hydrazines, the administration of inhibitors of the cytochrome P-450 or the flavin-containing monooxygenase system may offer some protective effect. For example, disulfiram, an inhibitor of cytochrome P45011E1 (Guengerich et al. 1991), decreased the oxidation of azomethane (a metabolite of 1,2-dimethylhydrazine) to azoxymethane, and the further oxidation of azoxymethane to methylazoxymethanol (Fiala et al. 1977). The inhibition of the activation pathway of 1,2-dimethylhydrazine by disulfiram resulted in decreased DNA methylation in the liver and colon of rats (Swenberg et al. 1979), and inhibition of l,2-dimethylhydrazine-induced colon carcinogenesis (Wattenberg 1975). Although disulfiram is a toxic compound which is known to inhibit other enzyme systems, it has been used in humans as an alcohol deterrent (Ellenhorn and Barceloux 1988). In cases of significant exposure to 1,2-dimethylhydrazine, the potential benefits of disulfiram in preventing colon cancer may outweigh the potential risk of adverse toxic effects.

## 2.10 ADEQUACY OF THE DATABASE

Section 104(i)(5) of CERCLA, as amended, directs the Administrator of ATSDR (in consultation with the Administrator of EPA and agencies and programs of the Public Health Service) to assess whether adequate information on the health effects of hydrazines is available. Where adequate information is not available, ATSDR, in conjunction with the National Toxicology Program (NTP), is required to assure the initiation of a program of research designed to determine the health effects (and techniques for developing methods to determine such health effects) of hydrazines.

The following categories of possible data needs have been identified by a joint team of scientists from ATSDR, NTP, and EPA. They are defined as substance-specific informational needs that if met would reduce the uncertainties of human health assessment. This definition should not be interpreted to mean that all data needs discussed in this section must be filled. In the future, the identified data needs will be evaluated and prioritized, and a substance-specific research agenda will be proposed.

### 2.10.1 Existing Information on Health Effects of Hydrazines

The existing data on health effects of inhalation, oral, and dermal exposure of humans and animals to hydrazines are summarized in Figure 2-3. The purpose of this figure is to illustrate the existing information concerning the health effects of hydrazines. Each dot in the figure indicates that one or more studies provide information associated with that particular effect. The dot does not necessarily imply anything about the quality of the study or studies, nor should missing information in this figure be interpreted as a “data need.” A data need, as defined in ATSDR’s Decision Guide for Identifying Substance-Specific Data Needs Related to Toxicological Profiles (ATSDR 1989), is substance-specific information necessary to conduct comprehensive public health assessments. Generally, ATSDR defines a data gap more broadly as any substance-specific information missing from the scientific literature.

As shown in Figure 2-3, data are available in humans regarding lethal, neurological, and carcinogenic effects after inhalation exposure to hydrazines. Data are also available for the systemic effects observed in humans exposed to hydrazines by the inhalation route for intermediate durations. By the oral route, information is only available for the neurological effects in humans exposed to hydrazines. Acute systemic, immunological, and neurological effects have been reported in humans after dermal exposure to hydrazines.

Considerably more information on the health effects of hydrazines is available from animal studies. These are data for all effect categories from animal studies for oral exposure to hydrazines. The lethal, neurological, reproductive, carcinogenic, and systemic effects for all exposure durations are available from studies in animals exposed to hydrazines by the inhalation route. For dermal exposures to hydrazines, animal data are available regarding the lethal, neurological, and acute systemic effects.

### 2.10.2 Identification of Data Needs

Acute-Duration Exposure. Data are available for the acute toxicity of hydrazine in humans after inhalation and dermal exposures, and in several animal species after oral and dermal exposures. Although a human case study suggests neurological effects are of concern following inhalation exposure to hydrazine (Frierson 1965), quantitative data are not available for the acute toxicity of hydrazine after inhalation exposure. Data from animal studies (rats, dogs) indicate that the liver is the primary target organ after oral exposures (Marshall et al. 1983; Preece et al. 1992a; Wakabayashi et al 1983), and that the skin is the most sensitive target in humans and animals (rabbits, guinea pigs, dogs) following dermal exposures (Hovding 1967; Suzuki and Ohkido 1979). These data do not sufficiently define the threshold dose for these effects and do not support the derivation of an MRL.

FIGURE 2-3 Existing Information on Health Effects of Hydrazines

Data are available for the acute toxicity of 1,1-dimethylhydrazine after inhalation exposure in humans, and inhalation, oral, and dermal exposures in animals. A human case study suggests that neurological effects are of concern following acute inhalation exposure to 1,1-dimethylhydrazine (Frierson 1965). Data from a study in dogs indicate that the central nervous system is affected following inhalation of 1,1-dimethylhydrazine (Rinehart et al. 1960). This finding is supported by data in rats, mice, cats, and monkeys acutely exposed to 1,1-dimethylhydrazine by injection (Furst and Gustavson 1967; Furst et al. 1969; Geake et al. 1966; Goff et al. 1967, 1970; Minard and Mushahwar 1966; O’Brien et al. 1964; Reynolds et al. 1963, 1964; Segerbo 1979; Sterman and Fairchild 1967). Data regarding the effects of acute oral exposure to 1,1-dimethylhydrazine are limited to a lethality study in mice (Roe et al. 1967). Animal studies (rabbits, dogs) have reported hematological and ocular effects following dermal exposure to 1,1-dimethylhydrazine (Rothberg and Cope 1956; Smith and Castaneda 1970; Smith and Clark 1971). These studies do not define the threshold for effect with confidence, and do not support the derivation of an MRL.

Data are available for the acute toxicity of 1,2-dimethylhydrazine in animals after acute oral and dermal exposures. No human studies were located regarding the acute toxicity of 1,2-dimethylhydrazine. Two studies in rats and dogs were located which reported effects on the colon, liver, and body weight after oral exposure (Caderni et al. 1991; Wilson 1976). Studies in rabbits and guinea pigs indicate that acute dermal exposure to 1,2-dimethylhydrazine can produce irritation and death (Rothberg and Cope 1956). These studies do not define the effect level for 1,2-dimethylhydrazine with confidence and do not support the derivation of an MRL. Studies are also available on the carcinogenic effects of 1,2-dimethylhydrazine after acute oral exposure (Craven and DeRubertis 1992; Schiller et al. 1980; Watanabe et al. 1985). No animal studies were located regarding the effects of acute inhalation exposure to 1,2-dimethylhydrazine.

Additional animal studies to investigate the acute effects of hydrazines after inhalation, oral, and dermal exposures would better define the threshold dose for adverse health effects. Such studies would be useful in predicting adverse health effects in humans following acute exposures.

Intermediate-Duration Exposure. Data are available on the toxicity of hydrazine and 1,1-dimethylhydrazine in humans and several animal species after intermediate-duration exposure by the inhalation and oral routes. These studies reported effects on the central nervous system in humans following oral exposure (Chlebowski et al. 1984; Gershanovich et al. 1976, 1981; Ochoa et al. 1975) and in animals (rats, mice, dogs) after inhalation exposure (Haun and Kinkead 1973), and effects on the liver in animals (mice, dogs, monkeys, rats) after inhalation exposure (Biancifiori 1970; Haun and Kinkead 1973; Haun et al. 1984; Rinehart et al. 1960). The data were sufficient to support the derivation of inhalation MRLs of 4×10^−3^ ppm for hydrazine and 2X10^−4^ ppm for 1,1-dimethylhydrazine based on hepatic effects. No data were located regarding the toxicity of hydrazine or l,l-dimethylhydrazine following dermal exposure for an intermediate duration. Studies are also available for the carcinogenic effects of hydrazine and 1,1-dimethylhydrazine after intermediate duration exposures (Haun et al. 1984; Roe et al. 1967).

No studies were located regarding the toxicity of 1,2-dimethylhydrazine in humans after intermediate duration exposure. Data on the toxicity of 1,2-dimethylhydrazine in animals after intermediateduration exposure are limited to those regarding the oral route. These studies have generally reported hepatic effects in rats, guinea pigs, mice, and pigs (Bedell et al. 1982; Visek et al. 1991; Wilson 1976), and support the derivation of an intermediate oral MRL of 8X10^−4^ mg/kg/day for 1,2-dimethylhydrazine. In addition, a large number of studies report the carcinogenic effects of 1,2-dimethylhydrazine after intermediate exposures (Izumi et al. 1979; Teague et al. 1981; Wilson 1976).

Additional studies in animals to investigate the effects of hydrazines after intermediate-duration inhalation, oral, and dermal exposures would better define the threshold dose for adverse health effects. Such studies would be useful in predicting adverse health effects in humans exposed for intermediate-durations to hydrazines.

Chronic-Duration Exposure and Cancer. Data are available on the toxicity of hydrazine and l,l-dimethylhydrazine in animals after chronic-duration exposure by the inhalation and oral routes. Effects on the liver, lung, and body weight gain are the most consistent findings observed in rats, mice, dogs, and hamsters (Haun et al. 1984; Steinhoff et al. 1990; Vernot et al. 1985). However, these studies do not define the threshold dose level for these effects with confidence, and therefore do not support the derivation of an MRL. Data regarding the noncarcinogenic effects of 1,2-dimethylhydrazine after chronic exposures are largely lacking. Additional studies which investigate the effects of hydrazines in animals after chronic inhalation, oral, and dermal exposures would help define the threshold dose for adverse health effects. Such studies would be useful in predicting adverse health effects in humans chronically exposed to hydrazines.

As discussed in the previous sections, hydrazines can cause cancer in animals following acute- or intermediate-duration exposure by the oral and inhalation route. In addition, several studies reported carcinogenic effects in a number of animal species exposed to hydrazine (Bhide et al. 1976; Bosan et al. 1987; Maru and Bhide 1982; Toth 1969, 1972b; Vernot et al. 1985), 1,1-dimethylhydrazine (Haun et al. 1984; Toth 1973a), and 1,2-dimethylhydrazine (Toth and Patil 1982), following chronic oral and inhalation exposures. These studies demonstrate that hydrazines are carcinogenic in animals following chronic oral and inhalation exposures. Epidemiological studies which investigate the carcinogenic effects in humans exposed occupationally or therapeutically to hydrazine would confirm whether or not the cancer effects observed in animal studies also occur in humans.

Genotoxicity. Data regarding the genotoxicity of hydrazines in humans are not available. A large number of studies are available that report the genotoxic effects of hydrazines in animals in vivo (Albanese et al. 1988; Ashby and Mirkova 1987; Becker et al. 1981; Beranek et al. 1983; Bolognesi et al. 1988; Bosan et al. 1986; Couch et al. 1986; Jacoby et al. 1991; Netto et al. 1992; Parodi et al. 1981; Pozharisski et al. 1975; Quintero-Ruiz et al. 1981; Winton et al. 1990; Zeilmaker et al. 1991; Zijlstra and Vogel 1988) and in a number of cell lines in vitro (Autrup et al. 1980a; Bosan et al. 1986; DeFlora and Mugnoli 1981; Harris et al. 1977; Kerklaan et al. 1983; Kumari et al. 1985; Lambert and Shank 1988; Levi et al. 1986; Malaveille et al. 1983; Noda et al. 1986; Oravec et al. 1986; Parodi et al. 1981; Rogers and Back 1981; Sedgwick 1992; Wilpart et al. 1983). These studies convincingly demonstrate that all three hydrazines are genotoxic. Additional genotoxicity studies in humans exposed to hydrazines, either occupationally or therapeutically would determine whether or not the effects observed in animals and in cells are also observed in humans.

Reproductive Toxicity. Data regarding the reproductive toxicity of hydrazines in humans are not available. Data regarding the reproductive effects of hydrazines are limited to a few animal studies regarding inhalation, oral, and parenteral exposure to hydrazine (Biancifiori 1970; Vernot et al. 1985; Wyrobek and London 1973) and inhalation exposure to 1,1-dimethylhydrazine (Haun et al. 1984). The serious nature of the effects caused by the inhalation of hydrazines suggests they may be of concern in humans similarly exposed. Studies that investigate the reproductive effects of 1,2-dimethylhydrazine, hydrazine, and 1,1-dimethylhydrazine, particularly those which also evaluate reproductive function over several generations, would be valuable in determining if the reproductive system is adversely affected in humans exposed to hydrazines.

Developmental Toxicity. Data regarding the developmental toxicity of hydrazines in humans are not available. Data regarding the developmental effects of hydrazines in animals are limited to a study which reported increased fetal and neonatal mortality following exposure to hydrazine by the parenteral route (Lee and Aleyassine 1970). No apparent developmental effects were seen after oral exposure of pregnant hamsters to 1,2-dimethylhydrazine dihydrochloride (Schiller et al. 1979). Studies that investigate the developmental effects of 1,1-dimethylhydrazine for any exposure route, as well as studies that better define the dose-response relationship for the developmental effects of hydrazine and 1,2-dimethylhydrazine for any exposure route, would be useful in determining whether developmental effects are of concern in humans exposed to hydrazines.

Immunotoxicity. The data regarding the immunological effects of hydrazines are limited. There is some suggestive evidence from human studies that exposure to hydrazine and other hydrazine derivatives can produce a lupus erythematosus-like disease (Pereyo 1986; Reidenberg et al. 1983). Data in animals reported immunological effects in mice with parenteral exposure to 1,1-dimethylhydrazine (Frazier et al. 1991) but not in rats with oral exposure to 1,2-dimethylhydrazine (Locniskar et al. 1986). In vitro studies suggest 1,1-dimethylhydrazine produces immunomodulatory effects (Bauer et al. 1990; Frazier et al. 1992). Additional case studies in humans and studies in animals which better define the dose-response relationship for the immunological effects of all three hydrazines would help determine if these effects are of concern to humans exposed to hydrazines.

Neurotoxicity. Data are available for the neurological effects of hydrazines in humans following inhalation, oral, and dermal exposures to hydrazine (Chlebowski et al. 1984; Gershanovich et al. 1976, 1981; Haun and Kinkead 1973; Ochoa et al. 1975; Richter et al. 1992; Sotaniemi et al. 1971; Spremulli et al. 1979) and 1,1-dimethylhydrazine (Dhennin et al. 1988; Kirklin et al. 1976; Rinehart et al. 1960). Effects on the central nervous system were also observed in animals following dermal and parenteral exposures to hydrazine (Floyd 1980; Mizuno et al. 1989; Patrick and Back 1965; Smith and Clark 1972) and 1,1-dimethylhydrazine (Furst and Gustavson 1967; Geake et al. 1966; Goff et al. 1970; Minard and Mushahwar 1966; O’Brien et al. 1964; Reynolds et al. 1964; Segerbo 1979; Smith and Clark 1971). Although these studies convincingly demonstrate that the central nervous system is a primary target of hydrazine and 1,1-dimethylhydrazine, these data do not define the threshold dose and more fully characterize neurological effects with confidence. Additional studies which better define the threshold dose for the neurological effects of hydrazine and l,l-dimethylhydrazine would be useful in determining the risk of neurological effects in humans exposed to these hydrazines. Preliminary neurological screening studies on 1,2-dimethylhydrazine in animals may determine if neurological effects are of concern for humans exposed to this chemical.

Epidemiological and Human Dosimetry Studies. Only one epidemiological study was located regarding the effects of hydrazine. This study showed no significant increase in cancer mortality in 427 hydrazine workers (Wald et al. 1984). However, the number of deaths examined was relatively small and the follow-up period may not have been sufficient for detecting a weak carcinogenic effect. Additional epidemiological studies investigating the neurological, hepatic, renal, and carcinogenic effects of hydrazines, particularly studies which also provide quantitative information on exposure, would be valuable in estimating the risk of adverse health effects in persons exposed to hydrazines in the workplace or therapeutically.

Biomarkers of Exposure and Effect

Exposure. Methods are available for determining the levels of hydrazine in the plasma of humans (Blair et al. 1985), and the levels of all three hydrazines and their metabolites and in tissues, urine, and expired air of animals (Alvarez de Laviada et al. 1987; Back et al. 1963; Dost et al. 1966; Fiala et al. 1976; Harbach and Swenberg 1981; Kaneo et al. 1984; Kang et al. 1988; Matsuyama et al. 1983; Preece et al. 1991; Reed et al. 1963; Springer et al. 1981). The detection of hydrazines and some of their metabolites (for example, the metabolites of 1,2-dimethylhydrazine-azoxymethane and methylazoxymethanol) are fairly specific for exposures to hydrazines. However, it should be kept in mind that treatment with certain drugs such as isoniazid or hydralazine can result in the presence of hydrazine in human plasma (Blair et al. 1985); therefore, care should be taken to ensure subjects have not been exposed to these drugs. Other metabolites of hydrazines (for example, carbon dioxide and nitrogen) are endogenous to the body, and therefore, cannot be used as specific biomarkers of exposure. Studies which investigate the quantitative relationship between exposure intensity, time since exposure, and the levels of hydrazines or their unique metabolites detected in biological samples, particularly in the urine, would be useful for estimating human exposures to hydrazines: Studies that identify biomarkers of exposure that are specific to 1,1-dimethylhydrazine and hydrazine could lead to the development of a reliable method for estimating recent exposures to hydrazines.

Effect. Exposure to hydrazine and 1,1-dimethylhydrazine is associated with the development of neurological and hepatic effects in humans (Chlebowski et al. 1984; Gershanovich et al. 1976; Ochoa et al. 1975; Richter et al. 1992; Sotaniemi et al. 1971) and animals (Haun and Kinkead 1973; Rinehart et al. 1960; Vernot et al. 1985; Wilson 1976). Studies which investigate if serum transaminase levels or vitamin B_6_ status could be used to predict effects of hydrazines could be useful, if they are coupled with confirmed exposures to hydrazines. The carcinogenic effects of hydrazines have also been amply demonstrated in animal studies (Abraham et al. 1980; Asano and Pollard 1978; Barbolt and Abraham 1980; Calvert et al. 1987; Izumi et al. 1979; Locniskar et al. 1986; Teague et al. 1981; Thorup et al. 1992; Wilson 1976). Studies which investigate if tests for occult blood in stools could be used to predict intestinal tumors induced by 1,2 dimethylhydrazine could be useful. However, the etiology of colon cancer is multifactional and may not be related to exposures to 1,2-dimethylhydrazine. Studies which identify biomarkers of effect that are specific to exposures to hydrazines could lead to the development of a reliable method for predicting past exposures to hydrazines.

Absorption, Distribution, Metabolism, and Excretion. Data regarding the toxicokinetics of hydrazines are limited to in vitro metabolic assays (Albano et al. 1989; Augusto et al. 1985; Coomes and Prough 1983; Craven et al. 1985; Erikson and Prough 1986; Glauert and Bennink 1983; Godoy et al. 1983; Netto et al. 1987; Newaz et al. 1983; Noda et al. 1987, 1988; Prough 1973; Prough et al. 1981; Sheth-Desai et al. 1987; Sinha 1987; Timbrell et al. 1982; Tomasi et al. 1987; Wolter et al. 1984) and in vivo studies in rats exposed via inhalation (Llewellyn et al. 1986), rats exposed orally (Preece et al. 1992b), dogs exposed dermally (Smith and Clark 1971, 1972), and in several species exposed by parenteral routes (Back et al. 1963; Dost et al. 1966; Fiala et al. 1976; Harbach and Swenberg 1981; Kaneo et al. 1984; Mitz et al. 1962; Reed et al. 1963; Springer et al. 1981). These studies invariably employed a single radiolabel (either 14C or i5N), and therefore, in the case of l,l-dimethylhydrazine and 1,2-dimethylhydrazine, the metabolic fate data (expressed as a carbon or nitrogen dose) were often incomplete. Studies which investigate the toxicokinetics of hydrazines for all routes and durations, particularly those which employ both a carbon and nitrogen label, would enhance the current understanding of the metabolic fate of hydrazines in humans exposed at hazardous waste sites.

Comparative Toxicokinetics. Studies in humans (Dhennin et al. 1988; Kirklin et al. 1976; Sotaniemi et al. 1971) and several animal species (Biancifiori 1970; Haun and Kinkead 1973; Marshall et al. 1983; Rinehart et al. 1960; Vernot et al. 1985; Wakabayashi et al. 1983) indicate that the liver and central nervous system are the primary target organs affected following oral, inhalation, and dermal exposures to hydrazine and 1,1-dimethylhydrazine. Studies in several animal species indicate that the intestinal tract and liver are the primary target organs affected following oral exposure to 1,2 dimethylhydrazine (Bedell et al. 1992; Wilson et al. 1976). Data regarding the toxicokinetics of hydrazines are lacking in humans and are limited in animals. These data are not sufficient to conclude which animal species is best for modeling human exposures. Similarly, these data do not reveal the basis of species differences in the toxicokinetics or pharmacodynamics of hydrazines which may underlie the species differences in toxicity. For example, dogs appear to be particularly sensitive to the hematological effects of hydrazine and 1,1-dimethylhydrazine (Haun and Kinkead 1973; Haun et al. 1984; Rinehart et al. 1960; Smith and Castaneda 1970). Additional studies which investigate the toxicokinetics in multiple species, including humans or human tissues, would be useful in developing an appropriate animal model for humans exposed to hydrazines at hazardous waste sites.

Methods for Reducing Toxic Effects. General methods exist for reducing the absorption of chemicals from the eyes, skin, and gastrointestinal tract (Bronstein and Currance 1988; Sittig 1991; Stutz and Janusz 1988). However, none of these methods are specific for exposures to hydrazines. No data were located for reducing body burden after exposure to hydrazines. Pyridoxine, which interferes with the mechanism of action of hydrazine and 1,1-dimethylhydrazine, is often administered to humans exposed to these hydrazines (Dhennin et al. 1988; Kirklin et al. 1976). However, exposure to pyridoxine may also be associated with adverse health effects. Additional studies that investigate the threshold dose for adverse effects of pyridoxine, and studies that investigate alternative agents that interfere with the mechanism of action of hydrazines could lead to a safer method of treatment. Inhibitors of metabolic activation (Fiala et al. 1977) and free radical scavengers may also be useful in interfering with the mechanism of action of hydrazines (Belleli et al. 1992; Colacchio et al. 1989; Cook and McNamara 1980; Craven and DeRubertis 1992; Shirai et al. 1985; Tomasi et al. 1987). Additional studies that investigate the effects of metabolic inhibitors and various free radical scavengers in humans occupationally exposed to hydrazines and in animals could lead to other methods of interfering with the mechanism of action of hydrazines.

### 2.10.3 On-going Studies

A number of researchers are continuing to investigate the toxicity and toxicokinetics of 1,2-dimethylhydrazine. Table 2-6 summarizes studies sponsored by agencies of the U.S. federal government.

TABLE 2-6 On-going Studies on the Health Effects of Hydrazines^*^

Investigator | Affiliation | Research description | Sponsor
Brasitus, TA | University of Chicago | Colonic epithelial cell plasma membranes in rats treated with 1,2-dimethylhydrazine | NIH, NCI
Goldman, P | Harvard School of Public Health | Metabolism of 1,2-dimethylhydrazine by rat intestinal bacteria | NIH, NCI
Kazarinoff, MN | Cornell University | Induction of ornithine decarboxylase by 1,2-dimethylhydrazine | USDA
McGarrity, TJ | Milton S Hershey Medical Center | Cellular changes in 1,2-dimethylhydrazine-induced colon tumors in the rat | NIH, NCI
Pretlow, TP | Case Western Reserve University | Colonic putative preneoplastic foci in rats by metabolite, azoxymethane | NIH, NCI
Shank, RC | University of California | Environmental hydrazines and methylation of DNA in rats and hamsters | NIH, NIEHS
Strobel, HW | University of Texas Medical School | Identification of cytochrome P-450 isozymes involved in the metabolism of 1,2-dimethylhydrazine | NIH, NCI

* Source: CRISP (1993)

NCI = National Cancer Institute; NIEHS = National Institute of Environmental Health Sciences; NIH = National Institute of Health; USDA = U.S. Department of Agriculture