# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the US. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Hydrazine Intermediate Inhalation

MINIMAL RISK LEVEL WORKSHEETS

Chemical Name: | Hydrazine
CAS Number: | 302-01-2
Date: | September 5, 1996
Profile Status: | Draft 3
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 19
Species: | mouse

[underlined: Minimal Risk Level]: [underlined: 4 ×10^−3^ ppm] [ ] mg/kg/day [X] ppm

[underlined: Reference]: Haun and Kinkead 1973

[underlined: Experimental design]:(human study details or strain, number of animals per exposure/control groups, sex, dose administration details): 40 female ICR mice per group, exposed by inhalation to 0, 0.2, or 1.0 ppm continuously for 6 months.

[underlined: Effects noted in study and corresponding doses]: Moderate to severe fatty liver changes were seen at both exposure levels.

Calculations:

LOAEL(_HEC_)= LOAEL × [(V_A_/BW)_A_÷ (V_A_/BW)_H_]

LOAEL(_HEC_)= LOAEL × [(V_A_/BW)_A_÷ (V_A_/BW)_H_]

LOAEL(_HEC_) = 0.2 ppm × [(0.043 m^3^/day ÷ 0.026 kg) ÷ (20 m^3^/day ÷ 70 kg)]

LOAEL(_HEC_) = 1.154 ppm

MRL = LOAEL(_HEC_)÷Uncertainty Factor

MRL = 1.154 ppm ÷300

MRL=4× 10^−3^ppm

[underlined: Dose and endpoint used for MRL derivation]:

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans following conversion to HEC
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?]

If so, explain: No

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: V_A_ mouse = 0.043 m^3^/day, BW = 0.026 kg

V_A_ human = 20 m^3^ / day , BW = 70 kg

Other additional studies or pertinent information which lend support to this MRL: The authors (Haun and Kinkead 1973) also investigated the effects of inhaled hydrazine in other species. Fatty liver changes were also observed in dogs exposed to 1 ppm hydrazine for 6 months and in monkeys exposed to 0.2 ppm for 6 months.

Agency Contact (Chemical Manager): Hugh Hansen

[underlined: Agency Review Date:] 1° review:___________

2° review:_____________

## 1,1 -Dimethylhydrazine Intermediate Inhalation

Chemical Name: | 1,1 -Dimethylhydrazine
CAS Number: | 57-14-7
Date: | September 5, 1996
Profile Status: | Draft 3
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 17
Species: | mouse

[underlined: Minimal Risk Level]: 2 × 10^−4^ [ ] mg/kg/day [X] ppm

[underlined: Reference]: Haun et al. 1984

[underlined: Experimental design]:(human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Groups of 400 female C57BL/6 mice per group, exposed by inhalation to 0, 0.05, 0.5, or 5 ppm for 6 months, 5 days per week, 6 hours per day.

[underlined: Effects noted in study and corresponding doses]: Hyaline degeneration in the gallbladder was significantly increased in the 0.05, 0.5, and 5 ppm groups compared to controls. Thus, the LOAEL is set at 0.05 ppm.

Calculations:

LOAEL(_HEC_) = LOAEL(ADJ)× [(VA/BW)A÷ (V_A_/B W)_H_]

LOAEL(_HEC_) = (0.05 ppm × 6 hr/24 hr × 5 d/7 d) × [(V_A_/BW)_A_ + (V_A_/BW)_H_]

LOAEL(_HEC_) = 0.0089 ppm × [(0.043 m^3^/day ÷ 0.026 kg) ÷20 m^3^/day + 70 kg)]

LOAEL(_HEC_)= 0.05 ppm

MRL = LOAEL(_HEC_)÷ Uncertainty Factor

MRL = 0.05 ppm + 300

MRL = 2 × 10^−4^ ppm

[underlined: Dose and endpoint used for MRL derivation]:

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans following conversion to HEC
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?]

If so, explain: No

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] V_A_ mouse = 0.043 m^3^/day, BW = 0.026 kg

V_A_ human = 20 m^3^ / day , BW = 70 kg

Other additional studies or pertinent information which lend support to this MRL: Studies of workers exposed to 1,1-dimethylhydrazine have reported changes indicative of a hepatic effect (elevated serum alanine aminotransferase activity, positive cephalin flocculation test) (Petersen et al. 1970; Shook and Cowart 1957). Angiectasis was observed in the livers of all exposed mice. Hepatic congestion was noted in mice exposed to 0.5 or 5 ppm 1,1-dimethylhydrazine (Haun et al. 1984). No NOAEL was identified.

Agency Contact (Chemical Manager): Hugh Hansen

[underlined: Agency Review Date:] 1° review:____________

2°review:_____________

## 1,2-Dimethylhydrazine Intermediate Oral

Chemical Name: | 1,2-Dimethylhydrazine
CAS Number: | 540-73-8
Date: | September 5, 1996
Profile Status: | Draft 3
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 25
Species: | mouse

[underlined: Minimal Risk Level]: [underlined: 8 × 10^−4^] [X] mg/kg/day [ ] ppm

[underlined: Reference:] Visek et al. 199 1

[underlined: Experimental design]:(human study details or strain, number of animals per exposure/control groups, sex, dose administration details): 25 male mice per group, exposed to 0, 0.75, 1.6, or 2.7 mg/kg/day in the diet for 5 months. Although 2 diet preparations were administered (one containing 10% protein, the other containing 40% protein), the doses of 1,2-dimethylhydrazine were judged not to differ significantly between the two groups.

[underlined: Effects noted in study and corresponding doses]: Mild hepatitis and small decreases in body weight gain and relative organ weights were observed in mice exposed to the lowest dose (0.75 mg/kg/day). These effects were more severe in animals exposed to higher doses. For example, doses of 1.6 mg/kg/day produced frank toxic hepatitis, as characterized by lobular disorganization, hepatocellular hypertrophy, and centrilobular necrosis. Portal fibrosis and bile duct hyperplasia, two effects noted in only a few animals exposed to 1.6 mg/kg/day, were more frequently observed in animals receiving the highest dose (2.7 mg/kg/day).

Calculations:

MRL = LOAEL ÷ Uncertainty Factor

MRL = 0.75 mg/kg/day ÷1000

MRL = 8 × 10^s4^ mg/kg/day

[underlined: Dose and endpoint used for MRL derivation]:

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose?]

If so, explain: 0.058 mg/day (daily food intake provided by authors) ÷ 0.035 kg (body weight provided by authors) × 0.45 (molecular weight adjustment for use of dihydrochloride salt) = 0.75 mg/kg/day.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:] N/A

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Hepatic effects (hepatotoxicity, necrosis, fibrosis, hemosiderosis, ascites, cirrhosis, degeneration) have been observed in rats (Bedell et al. 1982), guinea pigs (Wilson 1976), dogs (Wilson 1976), and pigs (Wilson 1976) subchronically exposed to 4.2-30 mg/kg/day 1,2-dimethylhydrazine by the oral route.

[underlined: Agency Contact (Chemical Manager):] Hugh Hansen

[underlined: Agency Review Date:] 1° review:___________

2°review:____________