# 8 REFERENCES

*Cited in text

*Abdul AS, Gibson TL, Kia SF. 1990. Contamination of soil and groundwater by automatic transmission fluid: Site description and problem assessment. J Hydrol 121:133–133.
*Abou-Donia MB. 1983. Interaction between neurotoxicities induced by organophosphorus and long-chain hexacarbon compounds. Neurotoxicology 4:117–117.6686866
*Abou-Donia MB, Lapadula DM. 1990. Mechanisms of organophosphorus ester-induced delayed neurotoxicity: Type I and Type II. Ann Rev Pharmacol Toxicol 30:405–405.2188574
*Abou-Donia MB, Lapadula DM, Campbell G, . 1985. The joint neurotoxic action of inhaled methyl butyl ketone vapor and dermally applied O-ethyl O-4-nitrophenyl phenylphosphonothioate in hens: Potentiating effect. Toxicol Appl Pharmacol 79:69–69.4049408
*Abou-Donia MB, Nomeir AA, Bower JH, . 1990b. Absorption, distribution, excretion, and metabolism of a single oral dose of [‘“Cl tri-ortho-cresyl phosphate (TOCP) in the male rat. Toxicology 65:61–61.2274970
*Abou-Donia MB, Suwita E, Nomeir AA. 1990a. Absorption, distribution, and elimination of a single oral dose of [‘4C]tri-ortho-cresy1 phosphate in hens. Toxicology 61: 13–25.2315948
*Adams WJ, Ziegenfuss PS, Renaudette WJ, . 1986. Comparison of laboratory and field methods for testing the toxicity of chemicals sorbed to sediments. In: Poston TM, Purdy R, eds. Aquatic toxicology and environmental fate Vol. 9. American Society for Testing and Materials Special Technical Publication 921, 494–513.
*Akzo. 1988. Material Safety Data Sheet for Fyrquel LT. 11/88. Akzo Chemicals, Inc., Chicago, IL.
*Akzo. 1989. Material Safety Data Sheet for Fyrquel 150. 2/89. Akzo Chemicals, Inc., Chicago, IL.
*Akzo. 1991. Material Safety Data Sheet for Fyrquel EHC. 2/91. Akzo Chemicals, Inc., Chicago, IL.
*Akzo. 1992. Material Safety Data Sheet for Fyrquel220. 1/92. Akzo Chemicals, Inc., Chicago, IL.
*Akzo. 1993. Facsimile cover sheet. June 14, 1993. Akzo Chemicals Inc., Chicago, IL.
*Anonymous. 1967. Mineral oil in human tissues. Nutr Rev 25:46–46.5342492
*ASTM. 1966. Fire Resistance of Hydraulic Fluids. American Society for Testing and Materials, Philadelphia, PA..
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR. 1993a. Technical report on ethylene glycol and propylene glycol. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR. 1993b. Toxicological Profile for PCBs. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR. 1993c. Case studies in environmental medicine - cholinesterase inhibiting pesticide toxicity. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR. 1995. Toxicological profile for automotive gasoline. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Baldridge HD, Jenden DJ, Knight CE, . 1959. Toxicology of a triaryl phosphate oil. Arch Ind Health 20:86–86.
*Banerjee BD, Saha S, Ghosh KK, . 1992. Effect of tricresyl phosphate on humoral and cell-mediated immune responses in albino rats. Bull Environ Contam Toxicol 49:312–312.1611256
*Barnard PWC, Bunton CA, Llewellyn DR, . 1961. The reactions of organic phosphate: Part V. The hydrolysis of triphenyl and trimethyl phosphates. J Chem Sot 2670–2676.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Baron RL. 1981. Delayed neurotoxicity and other consequences of organophosphate esters. Ann Rev Entomo 126:29–29.
*Bates TS, Hamilton SE, Cline JP. 1984. Vertical transport and sedimentation of hydrocarbons in the central main basin of Puget Sound, Washington. Environ Sci Technol 18:299–299.22280074
*Beck BE, Wood CD, Whenham GR. 1977. Triaryl phosphate poisoning in cattle. Vet Path01 14:128–128.
*Bollinger JN. 1970. Metabolic fate of mineral oil adjuvants using 14C-labeled tracers. I. Mineral Oil. J Pharm Sci 59:1084–1084.4989723
*Bouldin TW, Cavanagh JB. 1979a. Organophosphorus neuropathy. I. A teased-fiber study of the spatio-temporal spread of axonal degeneration. Am J Path01 94:241–241.
*Bouldin TW, Cavanagh JB. 1979b. Organophosphorus neuropathy. I. A fine-structural study of the early stages of axonal degeneration. Am J Path01 94:253–253.
*Brinkerhoff CR, Sharma RP, Boucier DR. 1981. The effects of Tri-ortho-tolyl Phosphate (TOTP) on the immune system of mice. Ecotoxicology and Environmental Safety 5:368–368.7028450
*Brunton LL. 1985. Laxatives. In: Gilman AG, Goodman LS, Rall TW, . eds. The Pharmacological Basis of Therapeutics. New York: MacMillan Publishing Company 994–1003.
*Camarasa JG, Serra-Baldrich E. 1992. Allergic contact dermatitis from triphenyl phosphate. Contact Dermatitis 26:264–264.1395566
*Cannon PR. 1940. The problem of lipid pneumonia. J Am Med Assoc. 115:2176–2176.
*Carlsen L, Andersen KE, Egsgaard H. 1986. Triphenyl phosphate allergy from spectacle frames. Contact Dermatitis 15:274–274.3816190
*Carlton BD, Basaran AH, Mezza LE, . 1987. Examination of the reproductive effects of tricresyl phosphate administered to Long-Evans rats. Toxicology 46:321–321.3672537
*Carpenter HM, Jenden DJ, Shulman NR, . 1956. The toxicology of cellulube 220: III Experimental Toxicology Research Report. Naval Medical Research Institute, National Naval Medical Center 14:725–725.
*Carpenter HM, Jenden DJ, Shulman NR, . 1959. Toxicology of a triaryl phosphate oil: I. Experimental toxicology. Arch Ind Health 20:62,234–252.
*Carrington CD, Burt CT, Abou-Donia MB. 1988. In viva 31 P nuclear magnetic resonance studies on the absorption triphenyl phosphate and tri-or&-cresyl phosphate following subcutaneous administration in hens. Drug Metab Distrib 104–109.
*Carrington CD, Lapadula DM, Othman M, . 1989. Assessment of the delayed neurotoxicity of tributyl phosphate, tributoxyethyl phosphate, and dibutylphenyl phosphate. Toxicol Ind Health 6 (3/4):415–423.
*CAS. 1995. Chemical Abstract Service. On-line database. May 13, 1995.
*Casida JE, Eto M, Baron RL. 1961. Biological activity of a tri-ortho-cresyl phosphate metabolite. Nature 191:1396–1396.13877086
*Cautreels W, VanCauwenberghe K. 1978. Experiments on the distribution of organic pollutants between airborne particulate matter and the corresponding gas phase. Atmos Environ 12: 1133–1141.
*Cavanagh JB, Patangia GN. 1965. Changes in the central nervous system in the cat as the result of tri-ortho-cresyl phosphate poisoning. Brain 88: 165–180.14280272
*CELDS. 1992. Computer Aided Environmental Legislative Data System. February 1992.
*Chapin RE, George JD, Lamb JC IV. 1988. Reproductive toxicity of tricresyl phosphate in a continuous breeding protocol in Swiss (CD-l) Mice. Fundam Appl Toxicol 10:344–344.3356322
*Chapin RE, Phelps JL, Burka LT, . 1991. The effects of tri-ortho-cresyl phosphate and metabolites on rat Sertoli cell function in primary culture. Toxicol Appl Pharmacol 108:194–194.1902005
*Chapin RE, Phelps JL, Somkuti SG, . 1990. The interaction of sertoli and leydig cells in-the testicular toxicity of triortho-cresyl phosphate. Toxicol Appl Pharmacol 104:483–483.2385838
*ChemID. 1993. On-line database. May 1933.
*Chemiak MG. 1988. Toxicological screening for organophosphorus-induced delayed neurotoxicity: Complications in toxicity testing. Neurotoxicology 9:249–249.2462700
*Chevron. 1994. Tributyl Phosphate. Chevron International Oil Company, San Francisco, CA.
*Chrisope DR, Landry JF. 1993. Automatic transmission fluid. In: Shubkin RL, ed. Synthetic Lubricants and High Performance Functional Fluids. New York: Marcel Dekker, Inc., 351–364.
*Ciba-Geigy. 1984e. TSCA sect. S(d) submission no. 86-870000078. Hydrolysis report with cover letter dated 01/09/87. Washington, DC: Office of Toxic Substances, U.S. Environmental Protection Agency. Microfiche no. 5 13263.
*Ciba-Geigy. 1986. TSCA sec. 8(d) submission no. 86-870000077. Ecotoxicology of phosphate esters. Testing to OECD guidelines, 1982. Washington, DC: Office of Toxic Substances, U.S. Environmental Protection Agency. Microfiche no. 5 13262.
*Ciba-Geigy Ltd. 1973. Pydraul50E: Neurotoxicity study in domestic hens. Ciba-Geigy Limited, Basle, Switzerland.
*Ciba-Geigy Ltd. 1978a. Salmonella/mammalian-microsome mutagenicity test with TK 10 509 (REOFOS 95). Experiment No. 78-2506. Ciba-Geigy Limited, Basle, Switzerland. NTIS OTS0507280.
*Ciba-Geigy Ltd. 1978b. Salmonella/mammalian-microsome mutagenicity test with TK 10507 (REOFOS 50) with cover letter from J.L. Greig. Experiment No. 78-2507. Ciba-Geigy Limited, Basle, Switzerland. NTIS/OTS0507280.
*Ciba-Geigy Ltd. 1983a. Salmonella/mammalian-microsome mutagenicity test TK 12 477 (REOLUBE HYD46). Project No. 830209. Ciba-Geigy Limited, Basle, Switzerland.
*Ciba-Geigy Ltd. 1983b. Sister chromatid exchange studies on somatic cells of Chinese hamsters TK 12 477 (REOLUBE HYD46). Test No. 830211. Ciba-Geigy Limited, Basle, Switzerland.
*Ciba-Geigy Ltd. 1984a. Nucleus anomaly test in somatic interphase nuclei of Chinese hamster TK 10 507 (REOFOS 50) Test No. 830071. Ciba-Geigy Ltd, Basle, Switzerland. NTIS OTS0507280.
*Ciba-Geigy, Ltd. 1984b. Sister chromatid exchange studies on somatic cells of Chinese hamsters TK 10 507 (REOFOS 50) Test No. 830206. Ciba-Geigy Ltd, Basle, Switzerland. NTIS OTS0507280.
*Ciba-Geigy Ltd. 1984~. Autoradiographic DNA repair test on rat hepatocytes TK 12 477 (REOLUBE HYD46) Test No. 830208. Ciba-Geigy Ltd, Basle, Switzerland.
*Ciba-Geigy Ltd. 1984d. Autoradiographic DNA repair test on rat hepatocytes TK 10 507 (REOFOS 50) Test No. 830205. Ciba-Geigy Ltd, Basle, Switzerland. NTIS OTS0507280.
*Ciba-Geigy Ltd. 1985. In vitro absorption through human epidermis of Reofos 50 and Reolube with cover letter dated October 16, 1985. EPA/OTS Public Files. NTIS OTS05 12802. -.
*Ciba-Geigy Ltd. 1986. Ecotoxicology of phosphate ester with cover letter dated January 9, 1987. EPA/OTS Public Files. NTIS OTS05 13262.
*Collins JM. 1993. Automotive trends. In: Shubkin RL, ed. Synthetic Lubricants and High-Performance Functional Fluids. New York: Marcel Dekker, Inc., 493–508.
*Coye MJ, Lowe JA, Maddy KT. 1986. Biological monitoring of agricultural workers exposed to pesticides: I. Cholinesterase activity determinations. J Occup Med 28:619–619.3746482
*Cregler LL, Mark H. 1986. Medical complications of cocaine abuse. New Engl J Med 315:1495–1495.3537786
*Dannecker W, Schroeder B, Stechmann H. 1990. Organic and inorganic substances in highway tunnel exhaust air. Sci Total Environ 93:293–293.
*Dawson RB, Platteau C. 1993. Industrial trends. In: Shubkin RL, ed. Synthetic Lubricants and High-Performance Functional Fluids. New York: Marcel Dekker, Inc., 509–524.
*Deleon IR, Byrne CJ, Peuler EA, . 1986. Trace organic and heavy metal pollutants in the Mississippi River. Chemosphere 15:795–795.
*Dee PD, Howard PH. 1978. Combined gas-liquid chromatographic mass spectrometric analysis of some commercial aryl phosphate oils. J Assoc Off Anal Chem 61:266–266.
*Department of Defense. 1993. Military handbook: Design guide for military applications of hydraulic fluids. Department of Defense. MIL-HKBK-118.
*Dollahite JW, Pierce KR. 1969. Neurologic disturbances due to triaryl phosphate toxicity. Am J Vet Res 30:1461–1461.5816370
*Dray BF. 1993. Environmental impact. In: Shubkin RL, ed. Synthetic Lubricants and High-Performance Functional Fluids. New York: Marcel Dekker, Inc., 533–543.
*Eade NR, Taussig LM, Marks MI. 1974. Hydrocarbon pneumonitis. Pediatrics 54:351–351.4606628
*Ebert AG, Schleifer CR, Hess SM. 1966. Absorption, disposition and excretion of 3Hmineral oil in rats. J Pharm Sci 55:923–923.5918529
*Ecobichon DJ. 1991. Toxic effects of pesticides. In: Casarett and Doull’s Toxicology. 4th ed. New York: Macmillan, 565–622.
*EPA. 1978. Environmental Protection Agency. Preliminary report on aryl phosphate monitoring with attachment. Intra-Agency memorandum from A.B. Crockett, Environmental Monitoring and Support Laboratory, Office of Research and Development to M.P. Halper, Monitoring and Data Support.
*EPA. 1979. Technical grade products manufactured in 1979, Table II. Washington, DC: U.S. Environmental Protection Agency, 4.
*EPA. 1979a. Environmental Protection Agency. Analysis of aryl phosphate samples. Intra-Agency memorandum from A.B. Crockett, Environmental Monitoring and Support Laboratory, Office of Research and Development to P. Hilgard, Office of Toxic Substances.
*EPA. 1979b. U.S. Environmental Protection Agency. Designation of conventional pollutants. 40 CFR 401.16. Fed Regist 44:44501.
*EPA. 1989. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA/600/8-90/066F.
*EPA. 1990. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1992. Environmental Protection Agency. Code of Federal Regulations. 40 CFR part 704 and 799.
*EPA. 1992a. Environmental Protection Agency. Hazardous waste management system: Identification and listing of hazardous waste; recycled used oil management standards; final rule. Fed Regist 57:41566–41566.
*EPA. 1992b. Environmental Protection Agency. Aryl phosphate base stocks; proposed text rule including reporting and recordkeeping requirements. Fed Regist 57:2138–2138.
*EPA. 1994. Testing Consent Order for Aryl Phosphate Base Stocks. September 27, 1994.
*EPA. 1995. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261-60 FR 6054.
*Eta M, Casida JE, Eto T. 1962. Hydroxylation and cyclization reactions involved in the metabolism of trior&-cresyl phosphate. Biochem Pharmacol 11:337–337.13890904
*Eto M, Oshima Y, Casida JE. 1967. Plasma albumin as a catalyst in cyclization of diaryl-o(-hydroxy)-tolyl phosphates. Biochem Pharmacol 16:295–295.6029915
*Evans RT. 1986. Cholinesterase phenotyping: Clinical aspects and laboratory applications. CRC Crit Rev Clin Lab Sci 23:35–35.
*Ferrario JB, Deleon IR, Tracy RE. 1985b. Evidence for toxic anthropogenic chemicals in human thrombogenic coronary plaques. Arch Environ Contam Toxicol 14:529–529.4051565
*Ferrario JB, Lawler GC, Deleon IR, . 1985a. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34:246–246.3978262
*FMC. 1975. Gas chromatographic-mass spectral assay of Kronitex isopropylphenyl phosphates. Technical report no. CPG-75-10. FMC Corporation, Princeton, NJ.
*FMC. 1977a Neurotoxicity study in hens on commercially available phosphate ester products: II. Monsanto. ICD/T-77-047. FMC Corporation, Princeton, NJ, 1–17.
*FMC. 1977b. A neurotoxicity study in hens on commercially available phosphate ester products: I. Stauffer. ICD/T-77-040. FMC Corporation, Princeton, NJ, 1–11. (submitted for peer review),.
*FMC. 1977~. Aryl phosphates and phenols in Nitro area samples. Memorandum from J.E. Jadlocki, FMC Corporation Industrial Division to W.H. Kibble, FMC Corporation.
*FMC. 1978a. Acute oral toxicity of Pydraul50E. ICG/T-78-085. FMC Corporation, Princeton, NJ, 1–5.
*FMC. 1978b. Part of unidentified submission (exhibit G): Environmental fate of triaryl phosphate [microfiche 05 192591. FMC Corporation, Philadelphia, PA.
*FMC. 1979. Analysis of aryl phosphates and phenols in plant and environmental samples from Nitro, West Virginia. Technical report [microfiche 05 183991. FMC Corporation, Princeton, NJ, 95.
*FMC. 1980. The environmental fate and effects of aryl phosphates and phenolics in wastewaters from the production of Kronitex phosphate esters. Technical report [microfiche 05 183991. FMC Corporation, Princeton, NJ, 42.
*FMC. 1986. The subchronic (90-day) neurotoxicity study of (X096-126-1 phosphate ester to the domestic hen. FCC 45/84526. FMC Corporation, Philadelphia, PA.
*FMC. 1990a. Non-definitive acute oral toxicity study of Durad 110 in rats. Study No. 190-1143. FMC Corporation, Princeton, NJ.
*FMC. 1990b. Letter from FMC Corp to U.S. EPA containing preliminary study results for triaryl phosphates. EPA/OTS public files: 86-900000502. FMC Corporation, Princeton, NJ. NTIS OTS0530040.
*FMC. 1991a. The effects of Durad 125 on serum cholinesterase and brain neuropathy. Target esterase activity in male Long-Evans rats. Study No: 64460. FMC Corporation, Princeton, NJ.
*FMC. 1991b. Durad 125. Non-definite primary skin irritation study in rabbits. FMC Corporation, Princeton, NJ.
*FMC. 1991~. Material safety data for Durad 300 (triaryl phosphate). FMC Corporation, Princeton, NJ.
*FMC. 1991d. Material safety data for Durad 110 (triaryl phosphate). FMC Corporation, Princeton, NJ.
*FMC. 1992a. Letter submitting two enclosed non-definitive acute oral toxicity studies of Durad 550B with attachments. FMC Corporation, Princeton, NJ.
*FMC. 1992b. Durad 550B. Salmonella/mammalian-microsome plate incorporation mutagenicity assay (Ames Test). Study No. 191-1222. FMC Corporation, Philadelphia, PA.
*FMC. 1992c. Material Safety Data Sheet: Durad 550B. FMC Corporation, Princeton, NJ. July 13, 1992.
*FMC. 1992d. Material Safety Data Sheet: Durad MP 280B. FMC Corporation, Princeton, NJ. July 13, 1992.
*FMC. 1992e. Material Safety Data Sheet: Durad (R) 220B. FMC Corporation, Princeton, NJ. July 13, 1992.
*FMC. 1992f. Material Safety Data Sheet: Durad (R) 125. FMC Corporation, Princeton, NL. July 13, 1992
*FMC. 1994. Material Safety Data Sheet: Durad 220. FMC Corporation, Princeton, NJ. January 1, 1994.
*FMC. 1995. Material Safety Data Sheet: Durad 280B. FMC Corporation, Princeton, NJ. January 1, 1995.
*Francis AJ, Iden CR, Nine BJ, . 1980. Characterization of organics in leachates from low-level radioactive waste disposal sites. Nuclear Technol 50:158–158.
*Freitag D, Ballhom L, Geyer H, . 1985. Environmental hazard profile of organic chemicals. Chemosphere 14:1589–1589.
*Freudenthal RI, Rausch L, Gerhart JM. 1993. Subchronic Neurotoxicity of Oil formulations containing either Tricresyl Phosphate or Tri-Orthocresyl Phosphate. Journal of the American College of Toxicology 12(4):409–416.
*Friess, SL, Jensen DJ, Tureman, JR. 1959. Toxicology of a triaryl phosphate oil. II. A quantitative study of toxicity in different production batches. Arch Ind Health 20:253–253.
*Gatz. 1992a. Intravenous and dermal absorption, distribution, and excretion of 14C-tributyl phosphate in Yucatan minipigs: Part I. MRI Project No. 9526-F(02).
*Gatz. 1992b. Pharmacokinetics of TBP in rats: Section 1 distribution, metabolism, and excretion of i4C-tributyl phosphate. MRI Project No. 9526-F.
*Gatz. 1994. Metabolism of tributyl phosphate in Yucatan minipigs following intravenous and dermal exposure: Part Il. MRI Project No. 9526-02.
*Gaworski CL, Kinkead ER, Horton JR, . 1986. Comparative studies of the short-term toxicity of the hydraulic fluids MIL-H-19457C, MIL-H-19457B, and MIL-H-22072B. Harry G. Armstrong Aerospace Medical Research Laboratory, Wright-Patterson Air Force Base, OH. NTIS/AD-A172 172/9.
*Gerarde HW. 1963. Toxicological studies on hydrocarbons. IX. The aspiration hazard and toxicity of hydrocarbon mixtures. Arch Environ Health 6:329–329.13947290
*Giurini JM, Hopkins WE, Redner T, . 1986. Succinylcholine sensitivity and plasma cholinesterase deficiency. J Foot Surgery 25:382–382.
*Goldstein DA, McGuigan MA, Ripley BD. 1988. Acute tricresylphosphate intoxication in childhood. Human Toxicol, 7:179–179.
*Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements and other chemicals. J Assoc Off Anal Chem 71: 1200–1209.3240978
*Haines JR, Alexander M. 1974. Microbial degradation of high-molecular weight alkanes. Appl Microbial 28:1084–1084.
*Hatton RE. 1962. Water-base Fluids. In: Hydraulic Fluids. New York: Reinhold Publishing Corporation 131273–287.
*HazDat. 1996. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Healy CE, Beyrouty PC, Broxup BR. 1995. Acute and subchronic neurotoxicity studies with tri-n-butyl phosphate in adult Sprague-Dawley rats. Am Ind Hyg Assoc, 56:349–349.
*Healy CE, Nair RS, Lemen JK, . 1991. Subchronic and reproduction studies with dibutyl phenyl phosphate in Sprague-Dawley rats. Fundam Appl Toxicol 16: 117–127.2019337
*Healy CE, Nair RS, Ribelin WE, . 1992. Subchronic rat inhalation study with Skydrol500B-4 fire resistant hydraulic fluid. Am Ind Hyg Assoc J 53: 175–180.1642169
*Heitkamp MA, Freeman JP, Ceringlia CE. 1986. Biodegradation of tert-butylphenyl diphenyl phosphate. Appl Environ Microbial 51:316–316.
*Heitkamp MA, Huckins JN, Petty JD, . 1984. Fate and metabolism of isopropylphenyl diphenyl phosphate in freshwater sediments. Environmental Science and Technology 18:434–434.22247945
*Henrich RT. 1995. Toxicology profile for hydraulic fluids. Comments of Akzo Nobel Chemicals Inc. Akzo Nobel Chemical Inc. Dobbs Ferry, NY.
*Hesselberg RJ, Seelye JG. 1982. Identification of organic compounds in Great Lakes fishes by gas chromatography/mass spectrometry: 1977. Admen Report No. 82-1. Ann Arbor, MI: U.S. Fish and Wildlife Society Great Lakes Fishery Laboratory, 49.
*Hedge HC, Sterner JH. 1943. The skin absorption of triorthocresyl phosphate as shown by radioactive phosphorus. J Pharmacol Exp Ther 79:225–225.
*Hoffman RS, Henry GC, Howland MA, . 1992. Association between life-threatening cocaine toxicity and plasma cholinesterase activity. Ann Emerg Med 21:248–253
*Houghton. 1992. Material Safety Data Sheet: Houghton-Safe 5047-F. March 24, 1992
*Howard PH, Deo PG. 1979. Degradation of aryl phosphates in aquatic environments. Bull Environ Contam Toxicol 22:337–337.465801
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD. February 1995.
*Huckins JN, Fairchild JF, Boyle TP. 1991. Role of exposure mode in the bioavailability of triphenyl phosphate to aquatic organisms. Arch Environ Contam Toxicol 21:481–481.1759843
*Hutchinson TC, Hellebust JA, Tam D . 1980. The correlation of the toxicity to algae of hydrocarbons and halogenated hydrocarbons with their physical-chemical properties. In: Afghan BK, MacDay D, eds. Hydrocarbons and Halogenated Hydrocarbons in the Aquatic Environment. New York: Plenum Press 577–586.
*IARC. 1984. Carbon blacks, mineral oils, (lubricant base oils and derived products) and some nitroarenes. IARC Monogr Eval Carcinog Risk Chem Hum 33:86–86.
*Inui K, Mitsumori K, Harada T, . 1993. Quantitative analysis of neuronal damage induced by tri-ortho-cresyl phosphate in Wistar rats. Fundam Appl Toxicol 20: 111–119.8432421
*IRDC. 1981. Teratology study in rats. International Research and Development Corporation. Mattawan, Michigan U.S.A.
*Jarvholm B, Johansson B, Lavenius B, . 1986. Exposure to triarylphosphate and polyneuropathy: A case report. Am J Ind Med 9:561–561.3740073
*Johannsen FR, Wright PL, Gordon DE, . 1977. Evaluation of Delayed Neurotoxicity and Dose-Response Relationships of Phosphate Esters in the Adult Hen. Toxicol Appl Pharmacol, 41:291–291.898200
*Johnson MK. 1975. The delayed neuropathy caused by some organophosphorus esters: Mechanism and challenge. Crit Rev Toxicol 3:289–289.
*Johnson MK. 1982. The target for initiation of delayed neurotoxicity by organophosphorus esters: biochemical studies and toxicological applications. In: Hodgson E, Bend JR, Philpot, RM, eds. Reviews of biochemical toxicology Vo14. New York: Elsevier, 141–212.
*Johnson MK. 1990. Organophosphates and delayed neuropathy: Is NTE alive and well? Toxicol Appl Pharmacol 102:355–399:
*Johnson MK, Barnes JM. 1970. Age and the sensitivity of chicks to the delayed neurotoxic effects on some organophosphorus compounds. Biochem Pharmacol 19:3045–3045.5513043
*Julian RJ, Galt DE, Butler D. 1976. Diagnosis of triorthocresyl phosphate poisoning in cattle. Proceedings of the Annual Meeting of the American Association of Veterinary Laboratory Diagnostics 18:407–407.
*Karydis M. 1980 Uptake of hydrocarbons by the marine diatom Cyclotella cryptica. Microbiological Ecology 5:287–287.
*Kawamura K, Kaplan IR. 1983. Organic compounds in the rainwater of Los Angeles. Environ Sci Technol 17:497–497.22283170
*Keith LH, Garrison AW, Allen FR, . 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Keith LH, ed. Advances in identifying and analyzing organic pollution in water. Ann Arbor, MI: Ann Arbor Press, 329–373.
*Kinkead E, Kimmel E, Wall H, . 1990. Determination of the toxicity of cyclotriphosphazene hydraulic fluid by 21-day repeated inhalation and dermal exposure. Am Ind Hyg Assoc J 51:583–583.2085163
*Kinkead ER, Bashe WJ. 1987. Evaluation of the inhalation and skin absorption kinetics of a cyclotriphosphazene based hydraulic fluid. Report to Toxic Hazards Division of Aerospace Medical Research Laboratory, Wright-Patterson Air Force Base, OH. LR-86-03. February 1987.
*Kinkead ER, Bunger SK, Wolfe RE. 1992c. Acute toxicologic evaluation of a cyclotriphosphazene hydraulic fluid. Acute Toxicity Data 1:219.
*Kinkead ER, Bunger, SK Wolfe RE. 1992e. Irritation and sensitization evaluation of Fyrquel220 hydraulic fluid. 212–213. -.
*Kinkead ER, Culpepper BT, Henry SS. 1989~. Determination of the toxicity of cyclotriphosphazene hydraulic fluid by 21-day repeated dermal exposure. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-89-022,214–223
*Kinkead ER, Culpepper BT, Henry SS, . 1988. Evaluation of the acute toxicity of four water-in-oil emulsion hydraulic fluids. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-87-063, 1–42.
*Kinkead ER, Culpepper BT, Henry SS, . 1989a. Determination of the toxicity of cyclotriphosphazene hydraulic fluid by 21-day repeated inhalation exposure. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-89-022,224–230.
*Kinkead, ER, Culpepper BT, Pollard DL, . 1987a. The evaluation of the acute toxicity of four water-in-oil emulsions hydraulic fluids. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-87-020, 14–22.
*Kinkead ER, Henry SS, Culpepper BT, . 1989b. Evaluation of the acute delayed neurotoxicity of four shipboard hydraulic fluids. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-89-022,242–248.
*Kinkead ER, Henry SS, Leahy HF, . 198713. Evaluation of the acute toxicity of a synthetic polyalphaolefin-based hydraulic fluid. 23–32.
*Kinkead ER, Horton JR, Gaworski CL. 1985. Acute toxicity studies on two air force hydraulic fluids (ML0 82-233 and ML0 82-585). Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AAMRL-TR-85-070.
*Kinkead ER, Wolfe RE, Bunger SK, . 1991. Evaluation of the toxic effects of a 90-day continuous exposure of rats to water-in-oil hydraulic fluid emulstions. Harry G. Armstrong Aerospace Medical Research Laboratory Technical Report AL-Tr-1991-015 NMRI-91-90.
*Kinkead ER, Wolfe RE, Bunger SK. 1992a. Acute toxicologic evaluation of Fyrquel220 hydraulic fluid. Acute Toxicity Data 1:210.
*Kinkead ER, Wolfe RE, Bunger SK. 1992d. Irritation and sensitization evaluation of Durad MP280 hydraulic fluid. Acute Toxicity Data 1:211.
*Kinkead ER, Wolfe RE, Bunger SK, . 1992b. The acute toxicity evaluation of a low-temperature hydraulic fluid. J Am Ind Hyg Assoc 53:163–163.
*Klein BL, Simon JE. 1986. Hydrocarbon poisonings. Pediatr Clin North Am 33:411–411.2870464
*Konasewich D, Traversy W, Zar H. 1978. Status report on organic and heavy metal contaminants in the Lakes Erie, Michigan, Huron and Superior basins. Great Lakes Water Quality Board.
*Kurebayashi H, Tanaka A, Yamaha T. 1985. Metabolism and disposition of the flame retardant plasticizer, tri-p-cresyl phosphate, in the rat. Toxicol Appl Pharmacol 77: 395–404.3919466
*Labour Canada. 1990. Evaluation of health hazards associated with occupational exposure>? Skydrol hydraulic fluids with attachments, cover sheet, and letter dated 02/01/90. EPA/OTS Public files: 86-900000073. Monsanto Company, St. Louis, MO. NTIS OTS0522305.
*Laham S, Long G, Broxup B. 1984. Subacute oral toxicity of Tri-n-butyl Phosphate in the Sprague-Dawley rat. J Appl Toxicol 4(3): 150–154.6747197
*Laham S, Long G, Broxup B. 1985. Induction of urinary bladder hyperplasia in Sprague-Dawley rats orally administered Tri-n-butyl Phosphate. Archives of Environmental Health 302-301-306.
*Latendresse JR, Brooks CL, Capen CC. 1994. Pathologic effect of butylated triphenyl phosphate-based hydraulic fluid and tricresyl phosphate on the adrenal gland, ovary, and testis in the Fischer-344 Rat. Toxicol Path 22 (4):341–352.7817124
*Latendresse JR, Brooks CL, Flemming CD, . 1994. Reproductive toxicity of butylated triphenyl phosphate and tricresyl phosphate fluids in F344 Rats. Fundam Appl Toxicol 22:392–392.8050634
*LeBel GL, Williams DT. 1983. Determination of organic phosphate triesters in human adipose tissue. J Assoc Off Anal Chem 66:691–691.6863190
*LeBel GL, Williams DT. 1986. Levels of triaryl/alkyl phosphates in human adipose tissue from Eastern Ontario. Bull Environ Contam Toxicol 37:41–41.3719141
*LeBel GL, Williams DT, Benoit FM. 1981. Gas chromatographic determination of trialkyl/aryl phosphates in drinking water following isolation using macroreticular resin. J Assoc Off Anal Chem 64:991–991.
*Lide DR. 1994. Handbook of Chemistry and Physics. CRC Press Boca Raton London Tokyo. 3-398-3-399.
*Liu D. 1980. Fate of petroleum hydrocarbons in sewage sludge after land disposal. Bull Environ Contam Toxicol 25:616–616.7437565
*Lombardo P, Egry IJ. 1979. Identification and gas-liquid chromatographic determination of aryl phosphate residues in environmental samples. J Assoc Off Anal Chem 62:47–47.422504
*Lotti M, Becker CE, Aminoff MJ. 1984. Organophosphate polyneuropathy: Pathogenesis and’prevention. Neurology 34:658–658.6324035
*Lushbaugh CC, Green JW, Redemann CE. 1950. Effects of prolonged inhalation of oil fogs on experimental animals. Arch Ind Hyg Occup Med 1:237–237.15426340
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of Chemical Property Estimation Methods: Environmental behavior of organic compounds. New York: McGraw-Hill Book Company, l-1 to l-2.
*MacEwen JD, Vemot EH. 1983. Toxic Hazards Research Unit Annual Technical Report: 1983. Air Force Aerospace Medical Research Laboratory. AFAMRL-TR-83-64. NTIS AD-136170.
*MacEwen JD, Vemot EH. 1985. Toxic Hazards Research Unit Annual Report: 1985. Harry G. Armstrong Aerospace Medical Research Laboratory AAMRL-TR-85-058. NTIS AD-A161558, 144–158.
*Mandel JS, Berlinger NT, Kay N. 1989. Organophosphate exposure inhibits Non-Specific esterase staining in human blood monocytes. Amer J Industrial Med 15 :207–212.
*Marino MP. 1992. Phosphate Esters. In: Shubkin RL, ed. Synthetic Lubricants and High-Performance Functional Fluids. New York: Marcel Dekker Inc. 67–100.
*Marino MP, Placek DG. 1994. Phosphate Esters. In: CRC Handbook of Lubrication and Tribology; Volume III: Monitoring, Materials, Synthetic Lubricants, and Applications, ed. E. Richard Booser. Boca Raton: CRC Press, Inc. 269–286.
*Maroni M, Bleecker ML. 1986. Neuropathy target esterase in human lymphocytes and platelets. J Appl Toxicol 6: 1–7.3958422
*Matsumoto G. 1983. Changes in organic constituents in river water during incubation. Water Research 17:1803–1803.
*Mattie DR, Hoeflich TJ, Jones CE, . 1993. The Comparative Toxicity of Operational Air Force Hydraulic Fluids. Toxicol Ind Health 9(6):995–1016.8191505
*Mayer FL, Adams WJ, Finley MT, . 1981. Phosphate ester hydraulic fluids: An aquatic environmental assessment of Pydrauls 50E and 115E [Abstract]. American Society for Testing and Materials Special Technical Publication 838:103–123. CA/O96/137347V.
*Merck Index. 1989. Merck index: An Encyclopedia of Chemicals, Drugs, and Biologicals. 11th ed. Budavari S, ed. Rahway NJ: Merck & Co., Inc.
*Minton NA, Murray VSG. 1988. A review of organophosphate poisoning. Med Toxicol 3:350–350.
*Moller UJ. 1989. Hydraulic Fluids. In: Ullmann’s Encyclopedia of Industrial Chemistry, Vol Al 3,5th ed. 165–176.
*Monsanto. 1978. TSCA sect. 8(d) submission 40-7859047. A study of variables effecting the river die-away test. Special study 1978. Washington, D.C.: Office of Toxic Substances, U.S. Environmental Protection Agency. EPA Dot Control No. OTS 84003A
*Monsanto. 1979. Summaries of mutagenicity studies, neurotoxicity studies, teratology studies, long term feeding studies, and 90-day inhalation studies on aryl phosphate ester products.
*Monsanto. 1980. Evaluation of potential hazards by dermal contact. Test material: SH-79-007, Skydrol (R) 500B-4 Fire resistant hydraulic fluids.
*Monsanto. 1981. Stability study of natural sediments samples preserved by frozen storage with attachment. Monsanto Company, St. Louis, MO.
*Monsanto. 1983a. TSCA sect. 8(d) submission 8782 11865. Santicizer 154 river die-away biodegradation rate study [microfiche 2062271. Washington, D.C.: Office of Toxic Substances, U.S. Environmental Protection Agency.
*Monsanto. 1983b. TSCA sect. 8(d) submission 878211112. Santicizer 141 river die-away biodegradation rate study [microfiche 2062271. Washington, D.C. Office of Toxic Substances, U.S. Environmental Protection Agency. -.
*Monsanto. 1983~. TSCA sect. 8(d) submission 878211885. Biodegradability of t-butyl/phenyl phosphate mixtures [microfiche 2062271. Washington, D.C. Office of Toxic Substances, U.S. Environmental Protection Agency.
*Monsanto. 1986a. Material Safety Data Sheet: Pydraul29ELT. Monsanto Company, St. Louis, MO. April 18, 1986
*Monsanto. 1986b. Material Safety Data Sheet: Pydraul50E. Monsanto Company, St. Louis, MO. January 3, 1986.
*Monsanto. 1986~. Material Safety Data Sheet: Pydraul90E. Monsanto Company, St. Louis, MO April 18, 1986.
*Monsanto. 1987a. Three-month study of Skydrol500B-4 administered to male and female Sprague-Dawley rats by inhalation. Study No. 84049. Project No. ML-84-226.
*Monsanto. 1987b. Three-month inhalation toxicity study of Skydrol500B-4
*Monsanto. 1987~. In viva/in vitro neurotoxicity studies of Skydrol LD-4 in adult hens with mixtures of butyl diphenyl phosphate, dibutyl phenyl phosphate and tributyl phosphate.
*Monsanto. 1987d. In vivoh vitro neurotoxicity studies of Skydrol500B-4.
*Monsanto. 1988a. In vitro chromosome aberration with Skydrol500B-4 fire resistant hydraulic fluid study on butyldiphenylphosphate, dibutylphenylphosphate and tributylphosphate.
*Monsanto. 1988b. In vitro cytogenetics study of Skydrol LD4 fire resistant hydraulic fluid. Study No. 87066. Project No. 87-57.
*Monsanto. 1989. Three-month inhalation toxicity study of Skydrol500B-4.
*Monsanto. 1992a. Material safety data for Skydrol500B-4 fire resistant hydraulic fluid. 9/15/92. Monsanto Company, 800 North Lindbergh Boulevard, St. Louis, MO.
*Monsanto. 1992b. Material safety data for Skydrol LD-4 fire resistant hydraulic fluid. 9/15/92. Monsanto Company, 800 North Lindbergh Boulevard, St. Louis, MO.
*Mortensen A, Ladefoged O. 1992. Delayed neurotoxicity of trixylenyl phosphate and a trialkyl/aryl phosphate mixture, and the modulating effect of atropine on tri-ortho-tolyl phosphate-induced neurotoxicity. NeuroToxicology 13:347–347.1436754
*Muir DCG. 1984. Phosphate esters. In: The Handbook of Environmental Chemistry: Anthropogenic substances, Vol. 3. Germany: Springer-Verlag Berlin, 41–66.
*Muir DCG, Grift NP, Lockhart WL. 1982. Comparison of laboratory and field results for prediction of the environmental behavior of phosphate esters. Environmental Toxicology and Chemistry 1: 113–119.
*Muir DCG, Grift NP, Solomon J. 1981. Extraction and cleanup of fish, sediment, and water for determination of triaryl phosphates by gas-liquid chromatography. J Assoc Off Anal Chem 64:79–79.7204313
*Muir DCG, Lint D, Grift NP. 1985. Fate of three phosphate ester flame retardants in small ponds. Environmental Toxicology and Chemistry. 4:663–663.
*Muir DCG, Townsend BE, Lockhart WL. 1983b. Bioavailability of six organic chemicals to Chironomus tentans larvae in sediment and water. Environmental Toxicology and Chemistry 2:269–269.
*Muir DCG, Yarechewski AL, Grift NP. 1983a. Environmental dynamics of phosphate esters: III. Comparison of the bioconcentration of four triaryl phosphates by fish. Chemosphere 12:155–155.
*Murphy SD. 1986. Toxic effects of pesticides. In: Casarett and Doull’s toxicology, 3rd ed. 519–581.
*Mutch E, Blain PG, Williams FM. 1992. Interindividual variations in enzymes controlling organophosphate toxicity in man. Hum Exp Toxicol 11: 109–116.1349216
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*Newton J. 1989. A look at lubricating oils. Industrial Lubrication and Tribology 41:13–13.
*NFPA. 1991. Fire Protection Guide to Hazardous materials. 11th ed. One Battrymarch Park, Quincy, MA. 325–88.325–91.
*NIOSH. 1989a. NIOSH Manual of Analytical Methods. Occupational air method no. 7905. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1989b. NIOSH Manual of Analytical Methods. Occupational air method no. 7300. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1989~. NIOSH Manual of Analytical Methods. Occupational air method no. 5037. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. NTIS PB92-162536.
*Noda T, Mortia S, Ohgaki S. 1984. A Safety Evaluation of Chemicals Used in Household Products (V) Teratological Studies in 2-Ethylhexyl Diphenyl Phosphate in Rats. Annu Rep. Osaka City Inst. Public Health Environmental Science 46:82–82.
*Nolting F, Behnke W, Zetzsch C. 1988. A smog chamber for studies of the reactions of terpenes and alkanes with ozone and OH. Journal of Atmospheric Chemistry 6:47–47.
*Nomier AA, Abou-Donia MB. 1986. Studies on the metabolism of the neurotoxic tri-or&-cresyl phosphate: Synthesis and identification by infrared, proton nuclear magnetic resonance and mass spectrometry of five of its metabolites. Toxicology 38: 1–13.3942005
*NPRA. 1992. 1991 Report on U.S. lubricating oil sales. National Petroleum Refiners Association, Washington, DC.
*NTP. 1988. Unpublished report. (Cited in NTP 1994).
*NTP. 1994. National Toxicology Program Technical report series no. 433. Tricresyl phosphate (CAS No. 1330-78-5) in F344 rats and B6C3Fi mice (gavage and feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. NIH publication no. 84-2544.
*Ofstad EB, Sletten T. 1985. Composition and water solubility determination of a commercial tricresylphosphate. Science of the Total Environment 43:233–233.
*Oishi H, Oishi S, Hiraga K. 1982. Toxicity of Several Phosphoric Acid Esters in Rats. Toxicol Lett, 13:29–29.7179306
*OSHA. 1974. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 40 CFR 19 10.1000. Fed Regist 54:2948.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Padilla S, Veronesi B. 1985. The relationship between neurological damage and neurotoxic esterase inhibition in rats acutely exposed to tri-ortho-cresyl phosphate. Toxicol Appl Pharmacol 78:78–78.2994253
*Papay AG. 1989. Automatic-transmission fluids Dexron II and beyond. Lubrication Engineering 45:121–121.
*Papay AG. 1991. Formulating automatic-transmission fluids. Lubrication Engineering 47:271–271.
*Papay AG. 1993. Hydraulics. In: Shubkin RL, ed. Synthetic Lubricants and High-Performance functional fluids. New York: Marcel Dekker, Inc., 427–452.
*Peedicayil J, Ernest K, Thomas M, . 1991. The effect of organophosphorus compounds on serum pseudocholinesterase levels in a group of industrial workers. Hum Exp Toxicol 10:275–275.1679650
*Per1 CA, Hewitt TA, Vice DL, . 1985. Process and environmental considerations involved in the selection of hydraulic and lubrication fluids for a modem hot strip mill. Proceedings of the Industrial Waste Conference 40:121–121.
*Perrot LJ, Palmer H. 1992. Fatal hydrocarbon lipoid pneumonia and pneumonitis secondary to automatic transmission fluid ingestion. J Forensic Sci 37:1422–1422.1402767
*Peterman PH, Delfino JJ, Dube DJ, . 1980. Chloro-organic compounds in the lower FoxRiver, Wisconsin. In: Afghan BK, Mackay D, eds. Hydrocarbons and halogenated hydrocarbons in the aquatic environment. New York: Plenum Press. 145–160.
*Pickard MA, Whelihan JA, Westlake WS. 1975. Utilization of triaryl phosphates by a mixed bacterial population. Can J Microbial 24:140–140.
*MA, Whelihan JA, Westlake WS. 1974. Utilization of triaryl phosphates by a mixed bacterial population. Can J Microbial 24: 140–145.
*Quaker 1993. Material Safety Data Sheet: Quintolubric 95830W. June 1, 1993
*Reape JM. 1982. Neurologic health impact on workers with chronic low dose exposure to aryl phosphates. Thesis submitted to the faculty of the graduate school of the university of Minnesota.
*Richardson RJ, Moore TB, Kayyali US, . 1993. Chlorpyrifos: Assessment of potential for delayed neurotoxicity by repeated dosing in adult hens with monitoring of brain acetylcholinesterase, brain and lymphocyte neurotoxic esterase, and plasma butyrylcholinesterase activities. Fundam Appl Toxicol 21:89–89.
*Robinson EC, Hammond BG, Johannsen FR, . 1986. Teratogenicity studies of alkylaryl phosphate ester plasticizers in rats. Fundam Appl Toxicol 7:138–138.3732665
*RTECS. 1993. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH. May 1993.
*RTECS. 1996. Registry of Toxic Effects of Chemical Substances (RTECS). National Institute for Occupational Safety and Health (NIOSH). Computer database online.
*RTI. 1992. Research Triangle Institute. Two-generation reproductive toxicity study of tributyl phosphate administered in the feed to CD (Sprague-Dawley) rats. RTI Project No. 6OC-4652.
*Saeger VW, Hicks O, Kaley RG, . 1979. Environmental fate of selected phosphate esters. Environmental Science and Technology 13:840–840.
*Saliot A, Andril C, Ho R, . 1985. Hydrocarbons in the Mediterranean Sea: Their occurrence and fate in the sediment and in the water column, as dissolved and associated with small and large size particulates. Journal of Environmental Analytical Chemical 22:25–25.
*Sawhney BL. 1989. Movement of organic chemicals through landfill and hazardous waste disposal sites. In: Reactions and movement of organic chemicals in soils. SSSA Special Publication no. 22,447–474.
*Schwab BW, Richardson RJ. 1986. Lymphocyte and brain neurotoxic esterase: Dose and time dependence of inhibition in the hen examined with three organophosphorus esters. Toxicol Appl Pharmacol 83:1–1.3952739
*Senanayake N, Jeyaratnam J. 1981. Toxic Polyneuropathy due to Gingili Oil contaminated with tri-cresyl phosphate affecting adolescent girls in Sri Lanka. The Lancet, January 10, 1981.
*Serrazanetti GP, Conte LS, Carpene E, . 1991. Distribution of aliphatic hydrocarbons in plankton of Adriatic sea open waters. Chemosphere 23:925–925.
“Shanor SP, Van Hees GR, Bart N, . 1961. The influence of age and sex on human plasma and red cell cholinesterase. Am J Med Sci 242:357–357.
*Shaw DG, ed. 1989. Solubility data series. Volume 38: Hydrocarbons with water and seawater. Part II: Hydrocarbons C8 to C36. New York: Pergamon Press, 546–547.
*Sheaffer KK. 1977. Summary report: Toxicity of aryl phosphates, Kishacoquillas Creek, Standard Steel Works, Mifflin County. Memorandum to T.P. Clista, Division of Water Quality, Commonwealth of Pennsylvania.
*Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environmental Science and Technology 12:1188–1188.
*Sheldon LS, Hites RA. 1979. Sources and movement of organic chemicals in the Delaware River. Environmental Science and Technology 13574–579.
*Shubkin RL. 1993. Polyalphaolefins. In: Shubkin RL, ed. Synthetic lubricants and high-performance functional fluids. New York: Marcel Dekker, Inc., 1–40.
*Siegel J, Rudolph HS, Getzkin AJ, . 1965. Effects on experimental animals of long-term continuous inhalation of a triaryl phosphate hydraulic fluid. Toxicol Appl Pharmacol 7:543–543.4953874
*Siemiatycki J, Dewar R, Nadon L, . 1987. Associations between several sites of cancer and twelve petroleum-derived liquids. Stand J Work Environ Health 13:493–493.
*Singler RE, Bieberich MJ. 1993. Phosphazenes. In: Shubkin RL, ed. Synthetic lubricants and high-performance functional fluids. New York: Marcel Dekker, Inc., 215–228.
*Smith MI, Elvove E, Valaer PJ, . 1930. Pharmacological and chemical studies of the cause of so-called ginger paralysis. Public Health Rep 45:1703–1703.19315253
*Snyder Jr. CE, Gschwender LJ. 1993. Aerospace. In: Shubkin RL, ed. Synthetic lubricants and high-performance functional fluids. New York: Marcel Dekker, Inc., 525–532.
*Somkuti SG, Abou-Donia MB. 1990. Disposition, elimination, and metabolism of tri-ortho-cresyl phosphate following daily oral administration in Fischer 344 male rats. Arch Toxicol 64:572–572.2073130
*Sornkuti SG, Lapadula D, Chapin RM, . 1991. Light and electron microscopic evidence of tri-orthocresyl phosphate (TOCP)-mediated testicular toxicity in F344 rats. Toxicol Appl Pharmacol 107:35–35.1987658
*Somkuti SG, Lapadula DM, Chapin RE, . 1987a. Reproductive tract lesions resulting from subchronic administration (63 days) of tri-o-cresyl phosphate in male rats. Toxicol Appl Pharmacol 89:49–49.3590188
*Somkuti SG, Lapadula DM, Chapin RE, . 1987b. Time course of the tri-o-cresyl phosphate-induced testicular lesion in F-344 rats: Enzymatic, hormonal, and sperm parameter studies. Toxicol Appl Pharmacol 89:64–64.3590189
*Sprague GL, Castles TR, Bickford AA. 1984. Assessment of the delayed neurotoxic potential of isopropyl triphenylphosphate using a nontraditional testing strategy. Toxicol Environ Health 14:773–773.
*SRC. 1994a. Syracuse Research Corporation. HENRYWIN. Henry program for MS Windows 3.1. Syracuse Research Corporation, Merrill Lane Syracuse, NY.
*SRC. 1994b. Syracuse Research Corporation. HYDROWIN. Hydro program for MS Windows 3.1. Syracuse Research Corporation, Merrill Lane Syracuse, NY.
*SRC. 1995a. Syracuse Research Corporation. AOPWIN. Atmospheric Oxidation Program for Microsoft Windows 3.1. Syracuse Research Corporation, Merrill Lane Syracuse, NY.
*SRC. 1995b. Syracuse Research Corporation. KOWWIN. Log Kow program for MS Windows 3.1. Syracuse Research Corporation, Merrill Lane Syracuse, NY.
*Srivastava. 1990. An outbreak of tricresyl phosphate poisoning in Calcutta, India. Fd Chem Toxic 28(4):303–304.
*Stauffer Chemical Company. 1971. Neurotoxicity of Fyrquel 1.50. T-6422.
*Stauffer Chemical Company. 1980. Neurotoxicity evaluation of Fyrquel EHC. T-10264.
*Stauffer Chemical Company. 1981. Toxicology report on “effect of 3 doses of Fyrquel EHC on neurotoxic esterase”. T-10553.
*Stauffer Chemical Company. 1982. A teratology study in CD rats with Phosflex 51B.
*Strachan WMJ. 1974. Chloroform-extractable organic compounds in the international great lakes. In: Keith LH, ed. Identification and Analysis of Organic Pollutants in Water. Ann Arbor, MI: Ann Arbor Science, 479,487–488.
*Suffet IH, Brenner L, Radziul JV. 1980. GC/MS identification of trace organic compounds in Philadelphia waters during a 2-year period. Water Research 14:853–853.
*Sutton WL, Terhaar CJ, Miller FA, . 1960. Studies on the industrial hygiene and toxicology of triphenyl phosphate. Archives of Environmental Health 1:33–33.13835853
*Suwita E, Abou-Donia MB. 1990. Pharmacokinetics and metabolism of a single subneurotoxic oral dose of tri-o-cresyl phosphate in hens. Arch Toxicol 64:237–237.2372235
*Suzuki T, Sasaki K, Takeda M, . 1984a. Metabolism of tributyl phosphate in male rats. J Agric Food Chem 32:603–603.
*Suzuki T, Sasaki K, Takeda M, . 1984b. Some S-containing metabolites of tributyl phosphate in the rat. J Agric Food Chem 32:1278–1278.
*Taylor P, Li Y, Camp S, . 1993. Structure and regulation of expression of the acetylcholinesterase gene. Chem Biol Interactions 87: 199–207.
TR192. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Trundle D, Marcial G. 1988. Detection of cholinesterase inhibition: The significance of cholinesterase measurements. Ann Clin Lab Sci 18:345–345.3052242
*U.S. Air Force. 1989. Hydraulic fluids. In: The installation restoration program toxicology guide: Vol. 4. Prepared by Oak Ridge National Laboratory for Armstrong Aerospace Medical Research Laboratory, Wright-Patterson Air Force Base, OH, 68–1 to 68–40.
*USCG. 1994. U. S. Coast Guard. 46 CFR parts 30,50, 150,151, and 153. 59 FR 45150.
*USITC. 1993. Synthetic organic chemicals United States production and sales, 1991. USITC Publication 2607 U.S. International Trade Commissions, Washington, DC., 2–1 to 2–7.
*Veith GD, Delore DL, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. Journal of the Fish Research Board of Canada 36:1040–1040.
*Weber R, Ernst W. 1983. Occurrence and fluctuation of organic environmental chemicals in German estuaries. Vom Wasser 61:11–11.
*Weil ED. 1980. Flame retardants (phosphorus compounds). In: Grayson M, Eckroth D, eds. Kirk-Othmer’s encyclopedia of chemical technology Vol. 10, 3rd ed. New York: John Wiley & Sons, 348–349,396–411,416–419.
*Welsh JJ, Collins TFX, Whitby KE, . 1987. Teratogenic potential of triphenyl phosphate in Sprague-Dawley (Spartan) rats. Toxicol Ind Health 3:357–357.3686538
*Weschler CJ, Shields HC, Rainer D. 1990. Concentration of volatile organic compounds at a building with health and comfort complaints. J Am Ind Hyg Assoc 51:261–261.
*WHO. 1991. Environmental health criteria for tri-n-butyl phosphate. World Health Organization, Geneva, Switzerland.
*Williams DT, Nestmann ER. LeBel GL, . 1982. Determination of mutagenic potential and organic contaminants of Great Lakes drinking water. Chemosphere 11:263–263.
*Wills JG. 1980. Hydraulic fluids. In: Kirk-Othmer’s Encyclopedia of Chemical Technology, Vol. 12, 3rd ed. New York: John Wiley & Sons, 712–733.
*Wills JH. 1972. The measurement and significance of changes in the cholinesterase activities of erythrocytes and plasma in man and animals. CRC Crit Rev Toxicol (March): 153–202.
*Wolfe NL. 1980. Organophosphate and organophosphorothionate esters: Application of linear free energy relationships to estimate hydrolysis rate constants for use in environmental fate assessment. Chemosphere 9:571–571.
*Yang SM, Thieme RA, von Meyerinck L, . 1990. Identification of isopropylated phenyl phosphates in rabbit bile. Biomed Environ Mass Spectrom 19:573–573.2224186