# 7 REGULATIONS AND ADVISORIES

The national regulations and guidelines regarding hydraulic fluids in air, water, and other media are summarized in Table 7-1.

ATSDR has not derived any Minimal Risk Levels for hydraulic fluids.

Regulations found for mineral oils include the OSHA occupational exposure limit for mineral oil mists of 5 mg/m^3^ (OSHA 1974).

The only regulations found for organophosphate ester hydraulic fluids were for aryl phosphates. Two proposed rules for aryl phosphates address 1) exclusion from hazardous waste regulations and 2) additional testing, recordkeeping, and reporting under the Toxic Substances Control Act (TSCA).

Table 7-1 Regulations and Guidelines Applicable to Hydraulic Fluids

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
WHO | No information available
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | Mineral oil mists: TWA (8-hour) | 5 mg/m^3^ | 29 FR 1910.1000
OSHA | Petroleum distillates: TWA (8-hour) | 2,000 mg/m^3^ | OSHA 1974
Guidelines:
a. Air:
NIOSH | Mineral oil mists: TWA; STEL | 5 mg/m^3^; 10 mg/m^3^ | NIOSH 1992
NIOSH | Petroleum distillates: TWA; Ceiling, 15min | 350 mg/m^3^; 1,800 mg/m^3^ | NIOSH 1992
EPA | Designated conventional pollutant (oil and grease) | Yes | 40 CFR 401.16; EPA 1979b
b. Other:
EPA/OSW | Identification and Listing of Hazardous Waste-Excluded Wastes from Non-Specific sources (proposed) (tributyl phosphates) | Yes | 40 CFR 261, App. IX; 60 FR 6054; EPA 1995
EPA/OPPT | Test Rule Including Reporting and Recordkeeping (proposed) (aryl phosphates) | Yes | 40 CFR 704 and 799; 57 FR 2138; EPA 1992
USCG | Obsolete Bulk Hazardous Materials (advanced notice of proposed rule) (oil, mineral) | Yes | 46 CFR 150; 59 FR 45150; USCG 1994
[underlined: STATE]
Regulations and Guidelines:
a. Other:
California | Designated hazardous waste (eligible for recycling by reclaimer of petroleum products) | Yes | CELDS 1992

EPA = Environmental Protection Agency; NIOSH = National Institute for Occupational Safety and Health; OPPT = Office of Pollution Prevention and Toxics; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; STEL = Short Term Exposure Limit; TWA = Time-Weighted Average; USCG = U.S. Coast Guard