# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 Chemical Identity

Information regarding the chemical identity of hydraulic fluid products is located in Table 3-1. This table contains information representative of three types of hydraulic fluids: mineral oil, organophosphate ester, and polyalphaolefin.

Early fluid power systems used water as the hydraulic medium. Because of its corrosive effect on the metallic parts and lack of lubricity, water was replaced by petroleum-based oil. The petroleum-based fluids discussed in this profile are mineral oil and water-in-oil emulsion fluids. Water-in-oil emulsions consist of 35-40% water, ≤60% mineral oil, and emulsifiers and additives. The water is dispersed in fine droplets in the oil phase. However, these fluids containing oil are readily ignited (NFPA 1991). Some water-in-oil emulsion hydraulic fluids contain ethylene glycol; however, ethylene glycol represents ≤10% of the total volume of water-in-oil emulsion hydraulic fluids. The carbon number range in mineral oil hydraulic fluids will vary depending on the application, but probably is in the range of C_15_ to C_50_(IARC 1984). The hydrocarbon components of mineral oil (and ethylene glycol) are used in numerous other applications, so the presence of these components in the environment cannot be uniquely associated with mineral oil-based hydraulic fluid use.

Most mineral oil hydraulic fluids are made from dewaxed paraffin-based crude oils that are blended with additives to impart appropriate properties for the specific use (Newton 1989; Papay 1989, 1991; Wills 1980). The types of additives, which are summarized below, are quite numerous and in some cases (Mattie et al. 1993) may contain organophosphate esters. These additives include extreme pressure additives, which help prevent surface damage under severe loading (organic sulfur-, phosphorus-, and chlorine-containing compounds); anti-wear additives, which prevent wearing under light loads (fatty acids and derivatives, organophosphate esters); corrosion inhibitors, which prevent corrosion by oxygen and water (fatty acids, sulfonates, and salts of fatty acids); oxidation inhibitors, which inhibit oxidation of the hydraulic fluid (phenols, amines, and sulfides); defoamers, which prevent foam formation (silicone oils); viscosity index improvers, which reduce the dependence of viscosity on temperature (polyalphaolefins, polymethacrylates, and polyalkylstyrenes); pour point depressants, which lower the pour point temperature (polymethacrylates and condensation products); demulsifiers, which allow separation of oil and water (ionogenic and nonionogenic polar compounds); and dispersants, which prevent unwanted deposits (sulfonates and amides) (Moller 1989).

Table 3-1 Chemical Identity of Hydraulic Fluid Products

Characteristic | Houghto-Safe 5047F^a^ | Pyroguard A-433^b^ | Quintolubric 95830W^b^
Class | Water-in-oil | Water-in-oil | Water-in-oil
Product description | No data | No data | No data
Registered trade name(s) | Houghto-Safe 5047F | Pyroguard A-433 | Quintolubric 95830W
Components | Mineral oil (30-60%); ethylene glycol (1-10%); remainder water | Mineral oil (60%); water (40%) | Mineral oil (60%); water (40%)
Identification numbers:
CAS registry | No data | No data | No data
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Sunsafe F^a^ | Cellulube 220^c^ | Durad 110^d^
Class | Water-in-oil | Phosphate ester | Phosphate ester
Product description | No data | Triaryl phosphate | Isopropylated triphenyl phosphate mixture
Registered trade name(s) | Sunsafe F | Cellulube 220^*^ | Durad 110
Components | Mineral oil (60%); water (40%); <2% ethylene glycol | Triphenyl phosphate; tricresyl phosphates, trixylenyl phosphates; trialkyl phenyl phosphates | Isopropylated triphenyl phosphate; triphenyl phosphate
Identification numbers:
CAS registry | No data | No data | No data
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | Not applicable
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Durad 125^e^ (additive) | Durad 220^f^ (additive) | Durad 220B^g^
Class | Phosphate ester | Phosphate ester | Phosphate ester
Product description | Tricresyl phosphate | Isopropylphenyl phosphate | t-Butylphenyl diphenyl phosphate
Registered trade name(s) | Durad 125 | Durad 220 | mixtureDurad 220B; MIL-H-19457C^x^
Components | Tricresyl phosphates; currently less than 1 % total ortho isomer, no detectable tri-ortho-cresyl phosphate | Isopropylphenyl phosphate blend | t-Butylphenyl phenyl phosphate; triphenyl phosphate
Identification numbers:
CAS registry | No data | No data | 28777-70-0^w^
NIOSH RTECS | No data | No data | TC8625000^x^
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | Not applicable
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Durad 300^h^ | Durad 550B^i^ | Durad MP280B^j^ (hydraulic fluid) (now known as Reolube_R_)
Class | Phosphate ester | Phosphate ester | Phosphate ester
Product description | Isopropylated triphenyl phosphate mixture | t-Butylated triphenyl phosphate mixture | Mixed triaryl phosphate
Registered trade name(s) | Durad 300 | Durad 550B | Durad MP280B (Reolube_R_)
Components | Isopropylated triphenyl phosphate; triphenyl phosphate (15%) | Not specified | t-butylphenyl phenyl phosphate, triphenyl phosphate; additives
Identification numbers:
CAS registry | No data | No data | 68937-40-6
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | Not applicable | Not applicable | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Fyrquel 150^k^ | Fyrquel 220^l^ | Fyrquel EHC^m^
Class | Phosphate ester mixture | Phosphate ester mixture | Phosphate ester mixture
Product description | Butylated triphenyl phosphate | Mixed triaryl phosphate | Mixed triaryl phosphate
Registered trade name(s) | Fyrquel 150 | Fyrquel 220 | Fyrquel EHC
Components | Butylated triphenyl phosphate ≈ 100%; triphenyl phosphate 15–20% | t-Butylphenyl diphenyl phosphate 35–40%; di(t-butylphenyl) phenyl phosphate 25–30%; triphenyl phosphate 15–20%; tri (p-t-butylphenyl) phosphate 6–10%; butylated triphenyl phosphate 6–10% | Mixed triaryl phosphate ≈50%; mixed xylenyl phosphate ≈ 50%; triphenyl phosphate ≈7–10%
Identification numbers:
CAS registry | No data | 55957-10-3^w^ | No data
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Hyjet IV^n^ | Pydraul 29ELT^o^ | Pydraul 50E^o^
Class | Organophosphate | Phosphate ester | Phosphate ester
Product description | Trialkyl phosphate | Mixed triaryl phosphate | Phosphate ester mixture
Registered trade name(s) | Hyjet IV | Pydraul 29ELT | Pydraul 50E
Components | Tributyl phosphate (79%); cycloaliphatic epoxide (2.0%) additives, including a triaryl phophate (21.0%) | Mixture of 2-ethylhexyl diphenyl blend; p-t-butyl phenyl blend; triphenyl phosphate; di_(7-9-11)_phthalate blend; di-2-ethylhexyl phenyl phosphate | Nonylphenyl diphenyl phosphate (≈41%); cumylphenyl diphenyl phosphate (≈23%); triphenyl phosphate (≈36%)^w^
Identification numbers:
CAS registry | No data | No data | 66594-31-8^w^
NIOSH RTECS | No data | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | UN3082 | No data | Not applicable
HSDB | No data | No data | No data
NCI | No data | No data | No data
Characteristic | Pydraul 90E^o^ | Reofos 50^p^ | Reofos 65^q^ | Reolube HYD46^r^
Class | Phosphate ester | Phosphate ester | Phosphate ester | Phosphate ester blend
Product description | Mixed triaryl phosphate | Isopropylated triphenyl phosphate mixture | Isopropylated triphenyl phosphate mixture | Isopropylated triphenyl phosphate blend
Registered trade name(s) | Pydraul 90E | Reofos 50 | Reofos 65 | Reolube HYD46
Components | Mixture of nonylphenyl diphenyl phosphate; cumylphenyl phosphate; cumylphenyl diphenyl phosphate; triphenyl phosphate; performance additives—phosphate ester blends including CAS# 6630-28-3 | Not specified | Mixture of triphenyl phosphate; o-isopropylphenyl diphenyl phosphate; bis(o-isopropylphenyl)phenyl phosphate; tris(o-isopropylphenyl)phosphate | Not specified
Identification numbers:
CAS registry | No data | 63848-94-2^w^ | No data | 107028-44-4^w^
NIOSH RTECS | No data | No data | No data | No data
EPA hazardous waste | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | No data | No data | No data | No data
NCI | No data | No data | No data | No data
Class | Phosphate ester mixture^s^ | Phosphate ester mixture^t^ | Phosphazene ester^u^ | Polyalphaolefin
Class | Phosphate ester mixture | Phosphate ester mixture | Phosphazene ester | Polyalphaolefin
Product description | | | Cyclotriphosphazene | Hydrogenated oligomers of alphaolefins
Registered trade name(s) | Skydrol 500B, Skydrol 500B-4 | Skydrol LD-4 | | See Table 3-2
Components | Skydrol 500B: tri-n-butyl-phosphate (65-75%); di-n-butyl phenyl phosphate (10-15%); n-butyl diphenyl phosphate (10-15%); Skydrol 500B-4^y^: tributyl phosphate; dibutyl phenyl phosphate; butyl diphenyl phosphate | Skydrol LD: tri-n-butyl-phosphate^y^ Skydrol LD-4: tributyl phosphate; dibutyl phenyl phosphate; 2,5-di-tert-butyl-p-cresol (minor component); butyl diphenyl phosphate | Dimers, trimers and tetramers of cyclotriphosphazene ester and 0.1% tolyltriazole; (P_3_N_3_)_n_ | Mixture of oligomers of linear alphaolefins having 6 or more carbon atoms^v^; (C=C-C-C-C-C-)_n_
Identification numbers:
CAS registry | 50815-84-4^w^ | 55962-27-1^w^ | 291-37-2 | See Table 3-2
NIOSH RTECS | VX5500000^x^ | No data | No data
EPA hazardous waste | No data | No data | No data
OHM/TADSDOT/UN/NA/IMCO shipping | No applicable | No applicable | No data
HSDB | No data | No data | No data
NCI | No data | No data | No data

a Houghton 1992

b Kinkead et al. 1992a

c Carpenter et al. 1956, 1959*

d FMC 1991d

e FMC 1992f

f FMC 1994

g FMC 1992e

h FMC 1991c

i FMC 1992c

j FMC 1992d

k Akzo 1989

l Akzo 1992

m Akzo 1991

n Chevron 1994

o Monsanto 1992b

p FMC 1995

q Mortensen and Ladefoged 1992

r FMC 1990, 1995

s Monsanto 1992a

t Monsanto 1992b

u Kinkead et al. 1992a

v Shubkin 1993

w CAS 1995a

x RTECS 1996

y Monsanto 1990

* A fluid designated “TAP-1” described by Siegel et al. (1965) appears to be very similar if not identical to Cellulube 220.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMO = Dept, of Transportation/United Nations/North America/International Maritime Dangerous Goods Code;EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

The exact nature of each of these additives appears to be trade secret information since none of the Material Safety Data Sheets describing the hydraulic fluids presented in this profile identify these materials. In addition, no information concerning the exact production methods used in manufacturing these hydraulic fluids was located in the available literature. Nonetheless, they are probably manufactured in batch processes and then tested to insure that they conform to the specifications for which they are sold. The number, nature, and amount of each additive used in a batch may depend on availability, cost, or performance.

The carbon number range (hence, viscosity) in mineral oil hydraulic fluids will vary depending on the application of the fluid (IARC 1984; Papay 1989, 1991, 1993; Wills 1980), but probably are in the range of C_15_ to C_50_. The higher the carbon number, the higher the viscosity; viscosity is a major factor in determining the base stock of a hydraulic fluid (Moller 1989; Papay 1989, 1991, 1993; Shubkin 1993; Wills 1980). A more highly refined mineral oil will have better viscosity properties (i.e., high viscosity index or low dependence of viscosity on temperature) (Moller 1989; Shubkin 1993).

In the past, hydraulic fluids using mineral oils sometimes included such additives as PCBs to improve the thermal resistance or other properties of the resulting fluids. While such uses of PCBs have been discontinued, PCBs at NPL sites may be encountered as a component where hydraulic fluids are a site contaminant (ATSDR 1993b).

Synthetic fire-resistant fluids have been developed to replace petroleum-based fluids for many applications. Although there are several types of these less hazardous fluids, the only synthetic fluids discussed in this profile are phosphate esters and polyalphaolefins. The phosphate esters are tertiary esters of orthophosphoric acid, O=P(OH)_3_, and may be triaryl, trialkyl, and alkyl/aryl. The polyalphaolefins are usually based on 2-decene and contain a mixture of oligomers (dimers, trimers, etc.).

The first commercial trialkyl phosphate esters (TAP) were tricresyl phosphate (TCP) and trixylenyl phosphate (TXP), referred to as “natural” phosphate esters because the cresols and xylenols used as raw materials are derived from petroleum oil or coal tar (Marino and Placek 1994). These products are not commercially significant at present; however, at waste disposal sites, contaminants from older product formulations may be encountered, particularly those containing the neurotoxic tri-ortho-cresyl phosphate isomer. “Synthetic” phosphate esters are derived from synthetic feedstocks. Specific synthetic reactions have been developed to produce triaryl, trialkyl, and alkyl\aryl esters. The triaryl phosphates are currently the most significant commercial products (Marino 1992). All three organic groups can be the same, such as tricresyl or trixylenyl phosphate, or they may be different, as iso-propylphenyl diphenyl phosphate or cresyl diphenyl phosphate. Of the trialkyl phosphate esters, tributyl phosphate is the most important of the synthetic base stocks. Most are used in aircraft hydraulic fluids (Marino 1992). Dibutyl phenyl phosphate, also used as an aircraft hydraulic fluid, is the most important of the alkyl/aryl phosphate esters (Marino 1992).

Products may be either mixtures of phosphate ester compounds resulting directly from the manufacturing process or mixtures resulting from post-blending or compounding with additives.

One of the main human health concerns about organophosphate esters is the potential for neurotoxicity reactions, in particular a condition known as organophosphate-induced delayed neurotoxicity (OPIDN). Tri-ortho- cresyl phosphate (TOCP) has been identified as one of the more potent OPIDN neurotoxins in humans, and was formerly a constituent in some organophosphate ester hydraulic fluid products (Marino 1992; Marino and Placek 1994). Production processes now routinely remove virtually all the TOCP. For instance, tricresyl phosphate (TCP) products now typically are manufactured to contain over 98% meta and para isomers and virtually no TOCP (Marino and Placek 1994). Products containing these compounds associated with OPIDN have now entirely disappeared from commercial use, and the vast majority of the industrial organophosphate esters are based on triaryl phosphates with no halogenated components (Marino 1992). At waste disposal sites, however, site contaminants from older product formulations containing the ortho form may be encountered.

In addition, organophosphate esters also are used as antiwear additives in hydraulic fluids and other lubricants; of the organophosphate esters discussed in this profile, Durad 110, 125, 220B, and 300 are categorized by their manufacturers as antiwear additives and not as hydraulic fluids (FMC 1991c, 1991d, 1992a, 1992b; Marino and Placek 1994).

Before the 1960s products were introduced based on alkyl aryl phosphates that could contain chlorinated aromatic hydrocarbons. Such products have now entirely disappeared from commercial use, and the vast majority of the industrial organophosphate esters are based on triaryl phosphates with no halogenated components (Marino 1992). However, at older waste disposal sites, hydraulic fluid site contaminants could contain chlorinated hydrocarbons. As with the PCBs formerly included as additives in other forms of hydraulic fluids, these additives may present more toxicity risks than the primary ingredients of the hydraulic fluids.

A typical polyalphaolefin oil prepared from 1-decene and BF _3_· n-C_4_H_9_OH catalyst at 30 °C contains predominantly trimer (C_30_hydrocarbons) with much smaller amounts of dimer, tetramer, pentamer, and hexamer. While 1-decene is the most common starting material, other alphaolefins can be used, depending on the needs of the product oil.

The final oil contains a large number of isomers (e.g., the trimer of 1-decene contains many C_30_ isomers, the tetramer contains many C_40_ isomers) which result from skeletal branching during the oligomerization (Shubkin 1993). Polyalphaolefin oils are many times classified by their kinematic viscosity at 100 °C; the higher the viscosity, the longer the average chain length of the polyalphaolefin. The isomer distribution of a polyalphaolefin oil used in a particular hydraulic fluid will depend on the application. A polyalphaolefin oil contains a narrower range of molecular weights than a comparable mineral oil (Chrisope and Landry 1993; Shubkin 1993).

Most hydraulic fluids contain additives that impart needed properties (Papay 1989, 1991; Wills 1980). The exact composition and proportion of these additives in a certain type of fluid depends on the intended use. Hydraulic fluids are compounded to conform to performance-based standards such as Military or ASTM (American Society for Testing and Materials) specifications. Some examples of Military specifications are shown in Table 3-2. Many different formulations can be compounded to conform to one performance standard. It should be noted that the variability among these products or even within products with the same trade names may confuse efforts to determine environmental and health effects of hydraulic fluids at hazardous waste landfills since hydraulic fluids that are currently used may or may not contain the same components present in old products of the same name.

Table 3-3 contains information regarding the chemical identity of principal components of hydraulic fluids. Trade names are included when the component constitutes 100% (or nearly 100%) of the product. Information has also been included for several representative types of mineral oil. It should be noted, however, that the term “mineral oil” encompasses a wide variety of petroleum-based products. Several phosphate esters used as hydraulic fluid additives are also included in Table 3-3.

Some of the products listed in the tables in Chapter 3 are not currently on the market. Information has been included for these products since components may be present at older waste disposal sites. For example, Cellulube 200 has not been a commercial product for over 20 years, Pydraul products are no longer sold commercially, and MIL-H- 19457B has been obsolete since 1981 (FMC 1995). In addition, some product names and designations have changed. For example, Durad MP 280B is now known as a Reolube (effective January 1995) (FMC 1995).

Table 3-2 Examples of Military Standards for Hydraulic Fluids

Property | MIL-H-5606^a^ | MIL-H-5606F^b^ | MIL-H-19457B^c^ | MIL-H-19457C^c^ | MIL-H-83282^b,^ ^d^ | MIL-H-83306^e^
Class | Petroleum base | Petroleum base | Phosphate ester | Phosphate ester | Hydrogenated polyalphaolefin | Phosphate ester
Product description | No data | No data | No data | Butylated triphenyl phosphate mixture | No data | No data
Synonyms | MLO 82-585 | No data | No data | MIL-H-19457D | MIL-H-83282C | No data
Major components^f^ | Napthenictype petroleum oil | Petroleum products with additives | Trixylyl phosphate | Triphenyl phosphate; t-butyl phenyl diphenyl phosphate; di-t-butylphenyl phenyl phosphate; little to no tri-(t-butylphenyl) phosphate | Trimers of polyalphaolefin^e^ | Tributyl-phosphate and dibutyl phenyl phosphate base stock
Operational temperature range | No data | −54-135 °C | No data | No data | −40-205 °C | No data
NATO Code | No data | H515 | No data | No data | H-537 | No data
Other | No data | No data | Obsolete since 1981 | No data | No data | No data

a Kinkead et al. 1985

b Department of Defense 1993

c FMC 1995

d MIL-H-83282 LT is a candidate low-temperature hydraulic fluid

e Mattie et al. 1993

f Numerous chemicals may be added to the hydraulic fluid base stocks to improve fluid characteristics. Tricresyl or triphenyl phosphate may be added as antiwear additives (Department of Defense 1993). The amount of the ortho isomer of tricresyl phosphate may not exceed 1% of total tricresyl phosphate (Mattieet al. 1993).

Table 3-3 Chemical Identity of Hydraulic Fluid Components^a^

Characteristic | Tricresyl phosphate | Trixylyl phosphate | Cresyl diphenyl phosphate | Triphenyl phosphate
Type | Organophosphate ester | Organophosphate ester | Organophosphate ester | Organophosphate ester
Synonym(s) | TCP; tritolyl phosphate | Xylyl phosphate; TXP; trixylenyl phosphate | Diphenyl tolyl phosphate | TPP
Registered trade name(s) | Durad 125^b^ | Durad 220X^c^; Kronitex TXP^d^; Reofos 95; Fyrquel 220^d^ | Phosflex 112; Santicizer 140 | Celluflex TPP; Disflamoll TP; Phosflex TPP
Major components | Mixture of isomers, predominantly m, p, little o | Mixture of isomers | Mixture of isomers | Triphenyl phosphate
Chemical formula | C_2_H_21_O_4_P | C_24_H_27_O_4_P | C_19_H_17_O_4_P | C_18_H_15_O_4_P
Chemical structure | (RO)(RO)(RO)P=O | (RO)(RO)(RO)P=O | (RO)(R′O)(R′O)P=O | (RO)(RO)(RO)P=O
Identification numbers:
CAS registry | 1330-78-5 | 25155-23-1 | 26444-49-5 | 115-86-6
NIOSH RTECS | 68952-35-2^b^ | No data | TC5520000 | TC8400000
EPA hazardous waste | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | 6774 | 6094 | 6096 | 2536
NCI | No data | No data | No data | No data
Characteristic | Isopropyl phenyl diphenyl ester | t-Butylphenyl diphenyl phosphate | Dibutyl phenyl phosphate | Nonylphenyl diphenyl phosphate
Type | Organophosphate ester | Organophosphate ester | Organophosphate ester | Organophosphateester
Synonym (s) | No data | | DBPP | No data
Registered trade name(s) | Phosflex 41P; Kronitex 100 | Fyrquel GT; Saniticizer 100B; Santicizer 154 | No data | No data
Major components | Mixture of isomers | | Dibutyl phenyl phosphate | Nonylphenyl diphenyl phosphate
Chemical formula | C_21_H_21_O_4_P | C_22_H_23_O_4_P | C_14_H_23_O_4_P | C_27_H_33_O_4_P
Chemical structure | (RO)(RO′)(RO′)P=O | (RO)(R′O)(R′O)P=O | (RO)(RO)(R′O)P=O | (RO)(R′O)(R′O)P=O
Identification numbers:
CAS registry | 28108-99-8 | 56803-37-3 | 2528-36-1 | 38638-05-0
NIOSH RTECS | No data | No data | TB9626600 | No data
EPA hazardous waste | No data | No data | No data | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | 6795 | 6102 | 2604 | No data
NCI | No data | No data | No data | No data
Characteristic | 2-Ethylhexyl diphenyl phosphate | Isodecyl diphenyl phosphate | Tri-n-butyl phosphate | Tris-isopropyl phenyl phosphate
Type | Organophosphate ester | Organophosphate ester | Organophosphate ester | Organophosphate ester
Synonym (s) | Diphenyl-2-ethylhexyl phosphate | Isodecyldiphenylphosphate | Tributyl phosphate; TBP; butyl phosphate; TNBP | No data
Registered trade name(s) | Saniticizer 141; Octicizer | Saniticizer 148^b^ | Skydrol LD^d^; Celluphos 4 | Durad 110, Durad 300
Major components | 2-Ethylhexyl diphenyl phosphate | Isodecyl diphenyl phosphate | Tri-n-butyl phosphate | Isopropylphenyl phosphate
Chemical formula | C_2_H_27_O_4_P | C_22_H_31_O_4_P | C_12_H_27_O_4_P | C_27_H_33_O_4_P
Chemical structure Identification numbers: | (RO)(R′O)(R′O)P=O | (RO)(R′O)(R′O)P=O | (RO)(RO)(RO)P = O | (RO)(RO)(RO)P = O
CAS registry | 1241-94-7 | 29761-21-5 | 126-73-8 | 26967-76-0
NIOSH RTECS | TC6125000 | No data | (55962-27-1 Skydrol LD)^b^ | No data
EPA hazardous waste | No data | No data | TC7700000 | No data
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | No data | No data
HSDB | 370 | 6797 | 1678 | 6797
NCI | No data | No data | No data | No data
Characteristic | Tri-o-cresyl phosphate | Mineral Oil^e^ | Mineral Oil^e^
Type | Organophosphate ester | Mineral oil | Mineral oil
Synonym (s) | o-Tolyl phosphate; TOCP; TOTP | Petroleum distillates; solvent-refined light paraffinic | Petroleum distillates, straight-run middle
Registered trade name(s) | Past contaminant of tricresyl phosphate | No data | No data
Major components | Tri-o-cresyl phosphate | Predominantly saturated hydrocarbons predominantly in the range C15 through C30 | Hydrocarbons predominantly in the range C11 through C200
Chemical formula | C_21_H_21_O_4_P
Chemical structure | (RO)(RO)(RO)P=O
Identification numbers:
CAS registry | 78-30-8 | 64741-89-5 | 64741-44-2
NIOSH RTECS | TD0350000 | PY8041500 | LX329600
EPA hazardous waste | No data | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | UN 2574; IMO 6.1 | No data | No data
HSDB | 4084 | No data | No data
NCI | No data | No data | No data

a All information from HSDB 1995 unless otherwise noted.

b FMC 1994

c Muir 1984

d Nobile et al. 1980

e RTECS 1996

CAS = Chemical Abstracts Service; DOT/UN/NA/IMO = Dept, of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH =National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS =Registry of Toxic Effects of Chemical Substances

## 3.2 Physical and Chemical Properties

Information regarding the physical and chemical properties of selected hydraulic fluid products is shown in Table 3-4. Physical and chemical properties of selected hydraulic fluid components are shown in Table 3-5.

The physical properties important for the projected use of hydraulic fluids are viscosity, density, foaming behavior, and fire resistance. There is no generally recognized test method for measuring flammability of hydraulic fluids, although various test methods may be utilized (Moller 1989).

Physical data important for describing environmental behavior (K_OC_, K_OW_, vapor pressure, water solubility, and Henry’s law constant) are incomplete. In general, hydraulic fluids have relatively low water solubilities.

A summary of the hydraulic fluids discussed in this profile is found in Table 3-6. Data on some of the components of hydraulic fluids are shown in Tables 3-7 through 3-9.

Table 3-4 Physical and Chemical Properties of Hydraulic Fluid Products

Property | Houghto-Safe 5047F^a^ | Pyroguard A-433^b^ | Quintolubric 95830W^b^ | Sunsafe F^b^
Molecular weight | Not applicable | Not applicable | Not applicable | Not applicable
Color | Opaque white | Milky white | Milky white | Milky white
Physical state | Liquid | Liquid | Liquid | Liquid
Melting point | No data | No data | No data | No data
Boiling point | 102 °C | 100 °C | 100 °C | 100 °C
Density | 0.927 g/mL | 0.92 g/mL | 0.96 g/mL | 0.92 g/mL
Odor | Bland | No data | No data | No data
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | Emulsion | No data | No data | No data
Organic solvents | No data | No data | No data | No data
Partition coefficients: | No data | No data | No data | No data
Log K_ow_
Log K_oc_
Vapor pressure | No data | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data
Property | Cellulube 220 | Durad 110^c^ | Durad 125^d^ | Durad 220
Molecular weight | No data | No data | 368.36^e^ | No data
Color | No data | Clear | Practically colorless | No data
Physical state | No data | Liquid | Liquid | No data
Melting point | No data | No data | No data | No data
Boiling point | No data | 220-270 °C at 4 mm Hg | 420 °C | No data
Density | No data | 1.1-1.17 g/mL at 20 °C | 1.162 at 25 °C | No data
Odor | No data | Odorless | Odorless | No data
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | No data | No data | 0.36 mg/L at 25 °C; insoluble (<0.002% at 85 °C)^e^ | No data
Organic solvents | No data | No data | Miscible with common solvents and thinners, vegetable oils^e^ | No data
Partition coefficients:
Log K_ow_ | No data | No data | 5.11; 6.34 (est.)^f^ | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | 0.026 mm Hg at 150 °C | 1×10^−7^ at 10 °C | No data
Henry’s law constant | No data | No data | 5.35×10^−8^ atm-m^3^/mol (est.) | No data
Autoignition temperature | No data | 551 °C | 420 °C | No data
Flashpoint | No data | 199 °C (closed cup) | 427 °C (760 mm Hg)^g^ | No data
Flammability limits | No data | No data | 225-235 °C (Pensky-Martin closed cup)^g^ | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No explosion hazard | No data | No data
Property | Durad 220B^h^ | Durad 300^i^ | Durad 550B^j^ | Durad MP280B^j^
Molecular weight | No data | No data | No data | No data
Color | Clear blue | Clear | Clear | Clear blue
Physical state | Liquid | Liquid | Liquid | Liquid
Melting point | −20 °C | No data | No data | No data
Boiling point | 416 °C | 220-270 °C at 4 mm Hg | No data | No data
Density | 1.145-1.165 g/mL at 20 °C | 1.15-1.17 g/mL at 20 °C | 1.124 g/mL at 20 °C | 1.145-1.165 g/mL at 20 °C
Odor | Odorless | Odorless | Odorless | No data
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | Insoluble | Insoluble | Insoluble | Insoluble
Organic solvents | No data | No data | No data | No data
Partition coefficients: | No data | No data | No data | No data
Log K_ow_ | No data | No data | No data
Log K_oc_ | | No data | No data
Vapor pressure | 0.033 mm Hg at 22 °C | 0.026 mm Hg at 150 °C | <0.033 mm Hg at 150 °C | 0.033 mm Hg at 150 °C
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | 535 °C | 551 °C | 480 °C | No data
Flashpoint | 243 °C (closed cup) | 199 °C (closed cup) | 254 °C (open cup) | 243 °C (closed cup)
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data
Property | Fyrquel 150^k^ | Fyrquel 220^l^ | Fyrquel EHC^m^ | Hyiet IV^h^
Molecular weight | −400 formula weight | No data | No data | 265 (average)
Color | Clear | Clear | Clear | Clear purple
Physical state | Liquid | Liquid | Liquid | Liquid
Melting point | No data | No data | No data | No data
Boiling point | decomp. >352 °C | decomp. >352 °C | No data | 288 °C
Density | No data | No data | No data | 0.997 g/mL
Odor | Essentially none | Essentially none | Essentially none | Sweet
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | Miscibility <0.1 mL | <1000 ppm | <1000 ppm | Insoluble
Organic solvents | No data | No data | No data | Soluble in hydrocarbon solvents
Partition coefficients: | No data | No data | No data | No data
Log K_ow_
Log K_oc_
Vapor pressure | <0.1 mm Hg at 37.8 °C | <0.1 mm Hg at 37.8 °C | <0.1 mm Hg at 37.8 °C | 0.5 mm Hg at 93 °C
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | 518 °C
Flashpoint | 246 °C (closed cup) | 246 °C (closed cup) | >235 °C (open cup) | 182 °C (open cup)
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data
Property | Pydraul 29ELT^n^ | Pydraul 50E^n^ | Pydraul 90E^o^ | Reofos 50^p^
Molecular weight | No data | No data | No data | No data
Color | Clear to slightly hazy blue | Blue to blue-green | Green to blue | No data
Physical state | Liquid | Liquid | Liquid | No data
Melting point | No data | No data | No data | No data
Boiling point | No data | 399 °C | No data | No data
Density | 1.09-1.10 at 25 °C | 1.145-1.165 g/mL at 25 °C | 1.147-1.167 g/mL at 25 °C | No data
Odor | No data | No data | No data | No data
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | Practically insoluble | 160 mg/L | Practically insoluble | No data
Organic solvents | No data | No data | No data | No data
Partition coefficients: | No data | No data | No data | No data
Log K_ow_
Log K_oc_
Vapor pressure | 0.002 mm Hg at 93 °C | 0.002 mm Hg at 93 °C | 0.001 mm Hg at 93 °C | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | 465 °C | No data | No data
Flashpoint | No data | 241 °C (open cup) | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data
Property | Reofos 65 | Reolube HYD46^q^ | Skydrol 500B-4^r^
Molecular weight | No data | No data | No data
Color | No data | Slightly hazy | Clear purple
Physical state | No data | Liquid | Liquid
Melting point | No data | No data | No data
Boiling point | No data | >400 °C (est.) | 125 °C at 267 mm Hg (est.)
Density | No data | 1.121 g/mL at 20 °C | 1.052-1.060 g/mL at 25°C
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Water
Air
Solubility: | No data | No data | No data
Water
Organic solvents
Partition coefficients: | No data | No data | No data
Log K_ow_
Log K_oc_
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | 545 °C | 399 °C
Flashpoint | No data | 245 °C (open cup) | 160 °C (open cup)
Flammability limits in air | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Skydrol LD-4^s^ | Cyclotriphosphazene^t^ | Polyalphaolefin
Molecular weight | No data | No data | No data
Color | Clear purple | No data | No data
Physical state | Liquid | Liquid | No data
Melting point | No data | No data | No data
Boiling point | 125 °C at 380 mm Hg (est.) | No data | No data
Density | 1.004-1.014 g/mL at 25 °C | 1.445 g/mL | No data
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Water
Air
Solubility: | No data | No data | No data
Water at 25 °C
Organic solvents
Partition coefficients: | No data | No data | No data
Log K_ow_
Log K_oc_
Vapor pressure | No data | 0.48 mm Hg at 65 °C | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | 399 °C | No data | No data
Flashpoint | 160 °C (open cup) | No data | No data
Flammability limits in air | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a Houghton 1992

b Kinkead et al. 1987a, 1988

c FMC 1992e

d All information from HSDB 1995, except where noted

e Mayer et al. 1981

f SRC 1995

g FMC, Marino and Placek 1994

h Chevron 1994

l FMC 1991c

j FMC 1992c

k Akzo 1992

l Akzo 1991

m Akzo 1989

n Monsanto 1986b

O Monsanto 1986c

p FMC 1991d

q FMC 1995

r Monsanto 1992a

s Monsanto 1992b

t Kinkead et al. 1990

Table 3-5 Physical and Chemical Properties of Selected Hydraulic Fluid Components^a^

Property | Tricresyl phosphate | Trixylyl phosphate | Cresyl diphenyl phosphate | Triphenyl phosphate
Molecular weight | 368.36^m^ | 410.45 | 340.33 | 326.29^g^
Color | Practically colorless | No data | Clear | Colorless; white
Physical state | Liquid | Liquid | Liquid | Crystals^g^
Melting point, °C | No data | | −38 | 50-51^g^
Boiling point, °C | 420 °C | 243-265 °C | 390 | 245 (11 mm Hg)^g^
Density, g/cm^3^ | 1.162 at 25 °C | 1.155 | 1.208 | 1.2055 g/mL at 30 °C^g^
Odor | Odorless | | Very slight odor | Characteristic, resembling phenol
Odor threshold: | No data | No data | No data | No data
Water
Air
Solubility:
Water | 0.36 mg/L at 25 °C; insoluble (<0.002% 85 °C)^b^ | 0.002% at 85 °C; 0.89 mg/mL | Insoluble | Insoluble^b^; 0.002% at 54 °C
Organic solvent(s) | Miscible with common solvents and thinners, vegetable oils^b^ | No data | Soluble in most organic solvents except glycerol | Soluble in benzene, CHCI_3_, ether, acetone^b^
Partition coefficients:
Log K_ow_ | 5.11; 6.34 (est.)^c^ | 5.63^i^; 7.98 (est.)^c^ | No data | 4.7 (est.)^c^
Log K_oc_ | No data | 3.67-4.44 (est.) | No data | 4.26 (est.)
Vapor pressure, mm Hg | 1.1 × 10^−7^ at 10 °C | 5.15×10^−8^ (30 °C) | No data | 1 mm Hg at 193.5 °C
Henry’s law constant | 5.35×10^−8^ atm-m^3^/mol (est.)^d^ | 7.19×10^−8^ atm-m^3^/mol (est.)^d^ | No data | <9.87×10^−8^ atm-m^3^/mol^i^; 3.98×10^−8^ atm-m^3^/mol (est.)^d^
Autoignition temperature | 410 °C 427 °C (760 mm Hg)^e^ | 535-545 °C^e^ | No data | No data
Flashpoint, °C | 225-235 °C (Pensky-Martin closed cup)^e^ | 245-255 °C (Pensky-Martin closed cup)^e^ | 232 °C (closed cup)^f^ | 220 °C (closed cup)
Flammability limits | No data | No data | No data | Noncombustible
Conversion factors | No data | No data | 1 ppm = 13.89 mg/m^3^ | 1 ppm = 13.32 mg/m^3^
Explosive limits | No data | No data | No data | No data
Property | Isopropyl phenyl diphenyl ester | t-Butylphenyl diphenyl phosphate | Dibutyl phenyl phosphate
Molecular weight | 368 | 382.40 | 286.34
Color | No data | No data | Clear, slightly yellow
Physical state | No data | No data | Liquid
Melting point, °C | No data | No data | No data
Boiling point, °C | No data | No data | 131-132 °C
Density, g/cm^3^ | No data | No data | 1.0691 at 25 °C
Odor | No data | No data | Butanolic
Odor threshold: | No data | No data | No data
Water
Air
Solubility:
Water | 2.2 mg/mL | No data | Very low; 96 ppm
Organic solvent(s) | No data | No data | No data
Partition coefficients:
Log K_ow_ | 6.16 (est.)^c^; 5.31 (est.) | 6.61(est.)^c^ | 4.27
Log K_oc_ | No data | No data | 3.23
Vapor pressure, mm Hg | 3.515×10^−7^ (25 °C, est.) | No data | 2.3×10^−4^ mm Hg 25 °C (est.)
Henry’s law constant | 7.74×10^−8^ atm-m^3^/mol (est.)^d^ | 2.15×10^−5^ atm-m^3^/mol at 25 °C^i^; 1.03×10^−7^ atm-m^3^/mol^d^ | 5.04×10^−7^ atm-m^3^/mol
Autoignition temperature | No data | No data | 129 °C (closed cup)
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Nonylphenyl diphenyl phosphate | 2-Ethylhexyl diphenyl phosphate | Isodecyl diphenyl phosphate
Molecular weight | 452 | 362.41 | 390
Color | No data | No data | No data
Physical state | Liquid | Liquid | No data
Melting point, °C | No data | −30 °C | No data
Boiling point, °C | 471 | 375 °C | 249 at 1.33 kPa
Density, g/cm^3^ | No data | No data | 1.070 g/mL
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Water
Air
Solubility:
Water | 0.77 ng/L^b^ | 1.9 mg/L at 25 °C | 0.75 mg/L at 25 °C
Organic solvent(s) | No data | No data | No data
Partition coefficients:
Log k_ow_ | 5.93^m^; 9.2^c^ | 5.73 | 5.44
Log K_oc_ | 3.69^h^ | No data | 4.34 (est.)
Vapor pressure, mm Hg | 1.9×10^−8h^ | 6.29 × 10^−5^ at 30 °C (est.) | 1.6×10^−5^ at 25 °C (est.)
Henry’s law constant | 4.24×10^−7^ atm-m^3^/mol (est.)^d^; 1.4×10^−8^ atm-m^3^/mol^h^ | 5.42×10^−5^ atm-m^3^/mol at 25 °C^i^ | 4.36×10^−7^ atm-m^3^/mol (est.)^d^
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Tri-n-butyl phosphate | Tris(isopropylphenyi)phosphate | Tri-o-cresyl phosphate
Molecular weight | 266.32 | 452 | 368.37^g^
Color | Colorless | No data | Colorless or pale yellow^b^
Physical state | Liquid | Liquid | Liquid^b^
Melting point, °C | <−80 °C^g^ | −25 | 11 °C^g^
Boiling point, °C | 289 °C^g^ | 220-270 (0.53 kPa) | −410 °C^g^
Density | 0.976 g/mL at 25 °C^g^ | 1.159 g/mL at 25 °C | 1.1955 g/mL at 25 °C^g^
Odor | Odorless^n^ | No data | Practically odorless
Odor threshold: | No data | No data | No data
Water
Air
Solubility:
Water | 1 mL dissolves in about 165 mL water^g^ | No data | Sparingly soluble^b^
Organic solvent(s) | Soluble in ether, benzene carbon disulfide, alcohol^b^ | No data | Soluble in alcohol, benzene, ether^b^; soluble in acetic acid^g^
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure, mm Hg | 127 mm Hg at 177 °C | No data | 10 mm Hg at 265 °C
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | 385 °C^f^
Flashpoint | 146 °C^g^ | No data | 225 °C (closed cup)^f^
Flammability limits | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a All information from HSDB, except where noted

b Mayer et al. 1981

c SRC 1995b KOWWIN

d SRC 1994a HENRYWIN

e FMC, Marino and Placek 1994

f NFPA 1991

g Merck 1989

h Boethling and Cooper 1985

i Muir et al. 1985

EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; CHCI_3_ = chloroform; est. = estimated; kPa = kilopascal

Table 3-6 Summary of Chemical Information for Selected Hydraulic Fluids

Name | Source | Identity/Composition | Physical and Chemical Properties
[underlined: Mineral oil based fluids]
MIL-H-5606 | Various^a^ | Table 3-2 | Meets specifications^b^
Houghto-Safe 5047F | Houghton | Table 3-1 | Table 3-4
Sunsafe F | Sun | Table 3-1 | Table 3-4
Pyroguard A-443 | Mobil | Table 3-1 | Table 3-4
Quintolubric 958 30W | Quaker | Table 3-1 | Table 3-4
[underlined: Oraanophosohate esters]
Fyrquel 150 | Akzo | Table 3-1 | Table 3-4
Fyrquel 220 | Akzo | Table 3-1 | Table 3-4
Fyrquel EHC | Akzo | Table 3-1 | Table 3-4
Durad 110 | FMC | Table 3-1 | Table 3-4
Durad 125 | FMC | Table 3-1 | Table 3-5 (tricresyl phosphate)
Durad 220B | FMC | Table 3-1 | Table 3-4
Durad 300 | FMC | Table 3-1 | Table 3-4
Durad 550B | FMC | Table 3-1 | Table 3-4
Durad MP 280B^d^ | FMC | Table 3-1 | Table 3-4
Skydrol 500B | Monsanto | Table 3-1 | Table 3-4
Skydrol 500B-4 | Monsanto | Table 3-1 | Table 3-4
Skydrol LD | Monsanto | Table 3-1 | Table 3-4
Skydrol LD-4 | Monsanto | Table 3-1 | Table 3-4
Pydraul 29E LT^c,h^ | Monsanto | Table 3-1 | Table 3-4
Pydraul 50E^c,f^ | Monsanto | Table 3-1 | Table 3-4
Pydraul 90E^c,g^ | Monsanto | Table 3-1 | Table 3-4
Reofos 50^c^ | FMC | Table 3-1 | Table 3-4
Reofos 65^c^ | FMC | Table 3-1 | No data
Reolube HYD46 | FMC | Table 3-1 | Table 3-4
Cellulube 220^c^ | FMC | Table 3-1 | No data
Santicizer 141 | Monsanto | 2-Ethylhexyl diphenyl phosphate | Table 3-5 (2-Ethylhexyl diphenyl phosphate)
Santicizer 148 | Monsanto | Isodecyl diphenyl phosphate^j^ | Table 3-5 (isodecyl diphenyl phosphate)
MIL-H-19457B | Various^a^ | Table 3-2 | Meets specifications^b^
MIL-H-19457C | Various^a^ | Table 3-2 | Meets specifications^b^
MIL-H-83306 | Various^a^ | Table 3-2 | Meets specifications^b^
Hyjet IV | Chevron | Table 3-1 | Table 3-4
[underlined: Polvabhaolefins]
MIL-H-83282 | Various^a^ | Table 3-2 | Meets specifications^b^
MIL-H-83282LT | Various^a^ | Low temperature version of MIL-H-83282. Dimer (49%)/-trimer (16.5%) blend ofpolyalphaolefin^e^ | Meets specifications^b^
[underlined: Other]
Cyclotriphosphazine | Not reported | Dimers, trimers and tetramers of cyclotriphosphazene^i^ | Table 3-4

a Products from various producers may meet the specifications.

b Specifications have been established for properties such as viscosity, flammability, and shear stability. The range of physical properties of the available hydraulic fluids is not available.

c Discontinued product

d Reolube MP 280B effective January 1995

e Mattie et al. 1993

f Pydraul 50E is Fyrquel 220 (Akzo 1993)

g Pydraul 90E is Fyrquel 450 (Akzo 1993)

h Pydraul 20E LT is Fyrquel LT (Akzo 1993)

i Kinkead et al. 1990

j FMC 1994

Table 3-7 Water Solubility of Hydrocarbon Components of Mineral Oil Hydraulic Fluids

Hydrocarbon | Distilled water solubility (ppm) | Salt water solubility (ppm)
Tetradecane (C_14_) | 2.2 | 1.7
Hexadecane (C_16_) | 0.9 | 0.4
Octadecane (C_18_) | 2.1 | 0.8
Eicosane (C_20_) | 1.9 | 0.8
Hexaeicosane (C_26_) | 1.7 | 0.1
Hexatricontane (C_36_) | 1.7^a^

a Shaw 1989

Source: Sutton and Calder 1974, except where noted

Table 3-8 Log K_ow_ Values for Organophosphate Ester Hydraulic Fluid Components

Chemical name | Log Ko_W_
Triphenyl phosphate | 4.63
Tricresyl phosphate, mixed isomers | 5.11
Trixylenyl phosphate, mixed isomers | 5.63
Isopropylphenyl diphenyl phosphate, mixed isomers | 5.31
2-Isopropylphenyl diphenyl phosphate | 5.65
2,4-Diisopropylphenyl diphenyl phosphate | 6.52
2,4,6-Triisopropylphenyl diphenyl phosphate | ≈6.70
Nonylphenyl diphenyl phosphate, mixed isomers | 5.93
Cumylylphenyl diphenyl phosphate, mixed isomers | 6.08
t-Butylphenyl diphenyl phosphate, mixed isomers | 5.12
2-Ethylhexyl diphenyl phosphate | 5.73
Tributyl phosphate | 4.00
Dibutyl phenyl phosphate | 4.27

Sources: Ciba-Geigy 1986; Mayer et al. 1981; Saeger et al. 1979

Table 3-9 Water Solubilities for Organophosphate Ester Hydraulic Fluid Components

Chemical name | Water solubility (mg/L)
Triphenyl phosphate | 1.9
Tricresyl phosphate, mixed isomers | 0.36
Trixylenyl phosphate, mixed isomers | 0.89^a^
Isopropylphenyl diphenyl phosphate, mixed isomers | 2.2
Nonylphenyl diphenyl phosphate, mixed isomers | 0.77
Cumylphenyl diphenyl phosphate, mixed isomers | 0.063
t-Butylphenyl diphenyl phosphate, mixed isomers | 3.2
2-Ethylhexyl diphenyl phosphate | 1.9
Tributyl phosphate | 280.0
Dibutyl phenyl phosphate | 280.0

a Ofstad and Sletten (1985) reported a water solubility of 0.11 mg/L for trixylenyl phosphate, which is significantly lower than the one reported by Saeger et al. (1979).

Source: Mayer et al. 1981; Saeger et al. 1979