# 8 REFERENCES

* Cited in text

Anonymous. 1986. TNT, RDX, HMX, and 2,4-DNT in waste water and groundwater liquid chromatographic method first action. In: Changes in methods. J Assoc Off Anal Chem 69:366–367.
*AOAC. 1990. TNT, RDX, HMX, and 2,4-DNT in waste water and groundwater. Liquid chromatographic method - 986.22. AO AC Official Methods of Analysis. 15th Ed. Arlington, VA: Association of Official Analytical Chemists.
*Army. 1974. The toxicology of cyclotrimethylenetrinitramine (RDX) and cyclotetramethylenetetranitramine (HMX) solutions in dimethylsulfoxide (DMSO), cyclohexanone, and acetone. Aberdeen Proving Ground, MD: Edgewood Arsenal. AD-780 010. (authored by McNamara et al.)
*Army. 1977a. Final report on toxicological investigations of pilot treatment plant waste waters at Holston Army Ammunition Plant. Washington, DC: U.S. Army Medical Research and Development Command. Columbus, OH: Battelle Columbus Laboratories, (authored by Stilwell et al.)
Army. 1977b. Munitions environmental quality standards research status report. Washington, DC: U.S. Army Medical Research and Development Command. AD-A956 091. (authored by Glennon et al.)
*Army. 1977c. Mutagenicity of some munitions waste water chemicals and chlorine test kit reagents. Final Report. Menlo Park, CA: SRI International, (authored by Simmon et al.)
Army. 1979. Mammalian toxicity of munitions compounds identification of waste products from RDX and HMX manufacture. Kansas City, MO: Midwest Research Institute, U.S. Army Medical Bioengineering Research and Development Laboratory AD-A074505. (authored by Helton et al.)
Army. 1982a. Environmental fate studies of HMX screening studies. Final Report, Phase I. Menlo Park, CA: SRI International. AD-Al48 978. (authored by Spanggord et al.)
*Army. 1982b. Migration of explosives in soil. Silver Springs, MD: Naval Surface Weapons Center, NSWC TR 82-566. (authored by Kayser EG, Burlinson NE).
*Army. 1983. Environmental fate studies of HMX Phase II-detailed studies. Final Report. Menlo Park, CA: SRI International. AD-A145 122. (authored by Spanggord et al.)
*Army. 1984a. Database assessment of the health and environmental effects of munitions production waste products. Oak Ridge, TN: Oak Ridge National Laboratory, Chemical Effects Information Center, ORNL-6018. AD-A145 417 (authored by Ryon et al.)
*Army. 1984b. Degradation of pink water compounds in soil - TNT, RDX, HMX. Natick, MA: United States Army Natick Research and Development Center, Science and Advanced Technology Laboratory. Technical Report NATICWTR-85/046. (authored by Greene et al.)
*Army. 1984~. Reverse phase HPLC method of analysis of TNT, RDX, HMX and 2,4-DNT in munitions waste water. Hanover, NH: U.S. Army Cold Regions Research and Engineering Laboratory, CRREL Report 84-29. AD-A155-983 (authored by Jenkins et al.)
*Army. 1984d. The anaerobic biotransformation of RDX, HMX, and their acetylated derivatives. Natick, MA: U.S. Army Natick Research and Development Center, NaticWTR-85/007. (authored by McCormick et al.)
*Army. 1985a. Determination of the acute and subchronic mammalian toxicity of HMX. Frederick, MD: U.S. Army Medical Research and Development Command. AD-Al73 743. (authored by Wilson AB)
*Army. 1985b. HMX: 13 week toxicity study in mice by dietary administration. Ft. Detrick, MD: U.S. Army Medical Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory, (authored by Everett DJ and Maddock SM)
*Army. 1985c. HMX: 13 week toxicity study in rats by dietary administration. Ft. Detrick, MD: U.S. Army Medical Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory. (authored by Everett et al.)
*Army. 1985d. HMX: 14-day toxicity study in mice by dietary administration. Ft. Detrick, MD: Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory. (authored by Greenough RJ, McDonald P).
*Army. 1985e. HMX: 14-day toxicity study in rats by dietary administration. Ft. Detrick, MD: Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory. AD-A171 597 (authored by Greenough RJ, McDonald P).
Army. 1985f. HMX: analysis of dosing formulation used in acute, sub-acute and sub-chronic toxicity studies. Frederick, MD: U.S. Army Medical Research and Development Command. AD-A171 595. (authored by Henderson MS)
*Army. 1985g. HMX: analysis in plasma obtained after 90 day toxicity studies with rats and mice. Frederick, MD: U.S. Army Medical Research and Development Command. AD-Al71 603. (authored by Henderson MS)
*Army. 1985h. HMX: Acute toxicity tests in laboratory animals. Ft. Detrick, MD: US. Army Medical Research and Development Command. Report No. 2051. (authored by Cuthbert et al.)
*Army. 1985i. TNT, RDX, and HMX explosives in soils and sediments. Hanover, NH: US. Army Cold Regions Research and Engineering Laboratory. CRREL Report 85-15. (authored by Cragin et al.)
*Army. 1986. HMX: toxicokinetics of 14C-HMX following oral administration to the rat and mouse and intravenous administration to the rat. Frederick, MD: U.S. Army Medical Bioengineering Research and Development Laboratory. IRI Report No. 2588. AD-A171 600. (authored by Cameron BD)
*Army. 1989. Organic explosives and related compounds: environmental and health considerations. Frederick, MD: U.S. Army Medical Research & Development Command. Technical Report 8901. (authored by Burrows et al.)
Army. 1990. Environmental transformation products of nitroaromatics and nitramines. Literature review and recommendations for analytical method development. Hanover, NH: U.S. Army Cold Regions Research and Engineering Laboratory. CETHA-TE-CR-89205. (authored by Walsh ME)
Army. 1991a. Optimization of cornposting for explosives contaminated soil. West Chester, PA: Roy F. Weston, Inc. U.S. Army Toxic and Hazardous Materials Agency, CETHA-TS-CR-91053. (authored by Williams and Marks)
*Army. 1991b. Stability of explosives in environmental water and soil samples. Oak Ridge, TN: Oak Ridge National Laboratory, ORNL/TM--11770. (authored by Maskarinec et al.)
*Army. 1991c. Improved salting out extraction-preconcentration method for the determination of nitroaromatics and nitramines in water. Hanover, NH: U.S. Army Cold Regions Research and Engineering Laboratory, CRRELA Special Report 91-18, AD-A245-491 (authored by Miyares PH, Jenkins TF).
*ASTM. 1991. Methods for analysis of nitroaromatics and nitroamine explosives in soil by high performance liquid chromatography. American Society for Testing and Materials. Method D5143-90.
ATF. 1993. Bureau of Alcohol, Tobacco and Firearms. Federal Register 58:4736–4738.
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Part V. Federal Register 54:37619–37633.
*ATSDR. 1993. Agency for Toxic Substances and Disease Registry. Toxicological profile for hydrazines (Draft). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Bauer CF, Grant CL, Jenkins TF. 1986. Interlaboratory evaluation of high-performance liquid chromatographic determination of nitroorganics in munitions plant waste water. Anal Chem 58:176–182.
*Bauer CF, Koza SM, Jenkins TF. 1990. Liquid chromatographic method for determination of explosives residues in soil: collaborative study. J Assoc Off Anal Chem 73:541–552.
*Berberich DW, Yost RA, Fetterolf DD. 1988. Analysis of explosives by liquid chromatography/thermospray/mass spectrometry. J Forensic Sci 946–959.
*Bongiovanni R, Podolak GE, Clark LD, 1984. Analysis of trace amounts of six selected polynitro compounds in soils. Am Ind Hyg Assoc J 45:222–226.
*Checkai R, Major M, Nwanguma R, 1993. Transport and fate of nitroaromatic and nitramine explosives in soils from open burning/open detonation operations: Milan Army Ammunition Plant. Aberdeen, MD: Edgewood Research, Development, and Engineering Center. AD-A279 145.
*Department of State. 1992. Federal Register 57:15227–15237.
DOT. 1990. Department of Transportation. Part II. Federal Register 55:18438–18442, 18449, 18479.
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 82, 850.
*EPA. 1986. U.S. Environmental Protection Agency. Federal Register 51:35372–35376.
*EPA. 1988. Health advisory for octahydro-1,3,5,7-tetranitro 1,3,5,7-tetrazocine (HMX). Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. (authored by McLellan et al.)
*EPA. 1990. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22537, 22593,22712.
*EPA. 1992. SW 846 Method 8330: Nitroaromatics and nitramines by high performance liquid chromatography (HPLC). Washington, DC: Environmental Protection Agency 8330:1–21
*EPA. 1994. EPA Superfund Record of Decision (EPA Region 4): Milan Army Ammunition Plant, Operable Unit 3, Milan, TN. Office of Emergency Medical Response. EPA/ROD/R04-94/199.
*EPA. 1995. Drinking water regulations and health advisories. Washington, DC: US Environmental Protection Agency, Office of Water.
Farber M. 1992. Mass-spectrometric investigations of the thermal-decomposition of 1,3,5,7-tetranitro-1,3,5,7-tetraazacyclooctane (HMX) and 1,3,5-trinitro-1,3,5-triazacyclohexane (RDX). Mass Spectrometry Reviews 11:137–152.
*FEDRIP. 1995. Federal Research In Progress. Dialog. Information Services, Inc. March 1995.
Fernando T, Aust S. 1991. Biological decontamination of water contaminated with explosives by Phanerochaete chrysosporium. Gas, Oil, Coal, Environmental Biotechnology 3:193–206.
*Fine DH, Yu WC, Goff EU, 1984. Picogram analyses of explosive residues using the thermal energy analyzer (TEA^®^). J Forensic Sci 732–746.
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee. Report 7, p. 17.
*Glover DJ, Hoffsommer JC. 1973. Thin-layer chromatographic analysis of HMX in water. Bull Environ Contam Toxicol 10:302–304.4766133
*Grant CL, Jenkins TF, Golden SM. 1993a. Evaluation of pre-extraction holding times for nitroaromatic and nitramine explosives in water. Hanover, NH: USA Cold Regions Research and Engineering Laboratory. CRREL Special Report 93-24, AD-A271 547.
*Grant CL, Jenkins TF, Golden SM. 1993b. Experimantal assessment of analytical holding times for nitroaromatic and nitramine explosives in soil. Hanover, NH: USA Cold Regions Research and Engineering Laboratory. CRREL Special Report 93-11, AD-A269 721.
*Hable M, Stem C, Asowata C, 1991. The determination of nitroaromatics and nitramines in ground and drinking water by wide-bore capillary gas chromatography. J Chromatogr Sci 29: 131–135.1874908
*Hathaway JA, Buck CR. 1977. Absence of health hazards associated with RDX manufacture and use. J Occup Med 19:269–272.323432
*HazDat. 1995. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*HSDB. 1995. Hazardous substances data bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. March 8, 1995
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC. March 8, 1995.
*Jenkins T, Miyares P, Myers K, 1992. Comparison of cartridge and membrane solid-phase extraction with salting-out solvent extraction for preconcentration of nitroaromatic and r&amine explosives from water. Hanover, NH: USA Cold Regions Research and Engineering Laboratory. ADA260 177.
*Jenkins TF, Leggett DC, Grant CL, 1986. Reversed-phase high-performance liquid chromatographic determination of nitroorganics in munitions waste water. Anal Chem 58:170–175.
*Jenkins TF, Walsh ME, Schumacher PW, 1989. Liquid chromatographic method for determination of extractable nitroaromatic and nitramine residues in soil. J Assoc Off Anal Chem 72:890–899.
Kotiaho T, Lauritsen FR, Choudhoury TK, 1991. Membrane introduction mass spectrometry. Anal Chem 63:875–833.
Lloyd JB. 1983. High-performance liquid chromatography of organic explosives components with electrochemical detection at a pendant mercury drop electrode. J Chromatogr 257:227–236.
*Major MA, Checkai RT, Phillips CT, 1992. Method for screening and analysis of residues common to munition open burning/open detonation (OB/OD) sites. Int J Environ Anal Chem 48:217–227.
*Maskarinec MP, Manning DL, Harvey RW, 1984. Determination of munitions components in water by resin adsorption and high-performance liquid chromatography-electrochemical detection. J Chromatogr 302:51–63.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*OSHA. 1987. HMX Analytical Method. Salt Lake City, UT: Pesticides and Carcinogen Branch, OSHA Analytical Laboratory.
*Phillips C, Checkai R, Chester N, 1994. Toxicity testing of soil samples from Joliet Army Ammunition Plant, IL. Aberdeen, MD: Edgewood Research, Development, and Engineering Center. AD-A279 091.
*Phillips C, Checkai R, Wentsel R. 1993. Toxicity of selected munitions and munition-contaminated soil on the earthworm (Eiseniafoetidu). Aberdeen, MD: Edgewood Research, Development, and Engineering Center. AD-A264 408.
Sax NI, Lewis RJ Sr. 1989. Dangerous properties of industrial materials. 7th ed. Vol. II. New York, NY: Van Nostrand Reinhold Company 1015.
*Sieber W, Sundin D, Frazier T, 1991. Development, use and availability of a job exposure matrix based on national occupational hazard survey data. Am J Ind Med 20:163:174.
*Tan EL, Ho CH, Griest WH. 1992. Mutagenicity of trinitrotoluene and its metabolites formed during composting. J Toxicol Environ Health 36: 165 175.1629932
*Thorne P. 1994. Evaluation of the use of supercritical fluids for the extraction of explosives and their degradation products from soil. Hanover, NH: USA Cold Regions Research and Engineering Laboratory. CRREL Special Report 94-9. AD-A282 338.
*Whong WZ, Speciner ND, Edwards GS. 1980. Mutagenic activity of tetryl, a nitroaromatic explosive, in three microbial test systems. Toxicol Lett 5:11–17.6445609
Williams RT, Ziegenfuss PS, Sisk WE. 1992. Composting of explosives and propellant contaminated soils under thermophilic and mesophilic conditions. J Ind Microbial 9:137–144.