# PEER REVIEW

A peer review panel was assembled for HMX. The panel consisted of the following members:

1. Dr. Tim Borges, Technical Information Analyst, Clinton, Tennessee
2. Mr. Bruce Jacobs, Director, General Physics Corporation, Edgewood, Maryland
3. Dr. Ronald Spanggord, Director of Bio-Analytical Chemistry, SRI International, Menlo Park, California

These experts collectively have knowledge of HMX’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(i)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.