# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for HMX.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical and chemical properties of HMX.

TABLE 3-1 Chemical Identity of HMX

Characteristic | Information | Reference
Chemical name | HMX
Synonym(s) | Tetranitro-1,3,5,7,-tetraazocyclooctane; cyclotetramethylenetetranitramine; tetramethylenetetranitramine; octahydro-1,3,5,7-tetranitro-tetrazocine; octogen; and others | HSDB 1995; IRIS 1995
Registered trade name(s) | No data
Chemical formula | C_4_H_8_N_g_O_g_ | HSDB 1995
Chemical structure | [image] | Bongiovanni et al. 1984
Identification numbers: | [image] | Bongiovanni et al. 1984
CAS registry | 2691-41-0 | HSDB 1995
NIOSH RTECS | XF 7450000 | HSDB 1995
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | UN0226 | HSDB 1995
HSDB | 5893 | HSDB 1995
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of HMX

Property | Information | Reference
Molecular weight | 296.20 | HSDB 1995
Color | Colorless | EPA 1988
Physical State | Solid | EPA 1988
Melting point | 276–286°C | Army 1989; EPA 1988
Boiling point | No data
Density:
at 25°C | 1.90 g/cm^3^ | Army 1989
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20° C | 6.63 mg/L | EPA 1988
Water at 25°C | 5 mg/L | Army 1989
Water at 83°C | 140 mg/L | EPA 1988
Organic solvent(s) | Soluble in dimethyl sulfoxide, acetone, cyclohexanone, acetic anhydride | EPA 1988
Partition coefficients:
Log K_ow_ | 0.26; 0.06 | Army 1989
Log K_oc_ | 0.54 | Army 1989
Vapor pressure at 25 °C | 3.33×l0^−14^ mmHg | Army 1989
at 100°C | 3×10^−9^ mmHg | EPA 1988
Henry’s law constant:
at 25°C | 2.60×10^15^ atm-m^3^/mol | Army 1989
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors | No data
Explosive limits | Decomposes violently at 279°C | Sax and Lewis 1989