# APPENDIX A MINIMAL RISK LEVEL WORKSHEETS

## HMX Acute Oral

Chemical Name: HMX
CAS Number: 2691-41-0
Date: June 6, 1997
Profile Status: Final (Post-Public Comment)
Route: [ ] Inhalation [x] Oral
Duration: [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: 13
Species: Mouse

[underlined: Minimal Risk Level:]

0.1 [X] mg/kg/day [ ] ppm

[underlined: Reference:]

Army. 1985d. HMX: 14-day toxicity study in mice by dietary administration. Ft. Detrick, MD: Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory. AD-A171 597 (authored by Greenough RJ, McDonald P).

Experimental design:

Groups of 6 male and 6 female B6C3Fl mice were administered HMX in the feed for 14 days at the following doses: 0, 100, 300, 900, and 2700 mg/kg/day for males; and 0, 320, 800, 2000, and 5000 mg/kg/day for females.

[underlined: Effects noted in study and corresponding doses]:

HMX-treated animals exhibited hyperkinesia when aroused at doses of 100 mg/kg/day. Convulsions were observed in two males exposed to 300 mg/kg/day. Other effects including piloerection, hunched posture, and increased sensitivity to auditory stimuli were also noted in animals exposed to this dose. No mention was made by the authors whether or not convulsions were observed in animals given higher doses. Necropsy of the brain did not reveal any abnormalities.

[underlined: Dose and end point used for MRL derivation]: 100 mg/kg/day hyperkinesia

- [ ] NOAEL [x] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

- [XI 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion used from npm in food or water to a mg/body weight dose? If so explain]:

NA

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

NA

[underlined: MRL Calculation]:

LOAEL: 100 mg/kg/day

MRL = LOAEL/UF = 100/1000 = 0.1 mg/kg/day

## HMX Intermediate Oral

Chemical Name: HMX
CAS Number: 2691-41-0
Date: June 6, 1997
Profile Status: Final (Post-Public Comment)
Route: [ ] Inhalation [X] Oral
Duration: [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: 16
Species: Rat

[underlined: Minimal Risk Level]:

0.05 [X] mg/kg/day [ ] ppm

Reference:

Army. 1985c. HMX: 13 week toxicity study in rats by dietary administration. Ft. Detrick, MD: US. Army Medical Research and Development Command, U.S. Army Medical Bioengineering Research and Development Laboratory, (authored by Everett et al.)

[underlined: Experimental design:]

Groups of 20 male and 20 female Fischer rats were administered HMX in the feed for 13 weeks at the following doses: 0, 50, 150, 450, 1,350, and 4,000 mg/kg/day for males; 0, 50, 115, 270, 620, and 1,500 mg/kg/day for females.

[underlined: Effects noted in study and corresponding doses:]

A NOAEL was established for hepatic effects at 50 mg/kg/day. Hepatic effects including enlarged centrilobular cells with pale nuclei and dark cytoplasm were observed in males exposed to 150 mglkgiday or more. In females administered 270 mg/kg/day or more, focal atrophy of the kidney tubules and dilatation was observed. Only high-dose animals (1,500 mg/kg/day for females, 4,000 mg/kg/day for males) were evaluated for serum chemistry parameters. Decreases in hemoglobin, packed cell volume, and blood urea nitrogen, and an increase in methemoglobin were observed in both males and females, although the elevation in methemoglobin levels was significant in males only. In addition, urinary pH was decreased while urinary volume was increased in females administered the highest dose. Crystals were observed in the urine of males administered the highest dose. Significant body weights were decreased in a dose-dependent manner, and many organ weights (adrenal, brain, heart, kidney, spleen, liver, lungs, and ovaries) were affected in a dose-dependent manner, however, the dose at which these changes became significant could not be determined. Histological effects were seen only in the liver and the kidneys. The results of this study indicate the liver and the kidneys as target organs. Ophthalmoscopic examination did not reveal any significant effects on the eyes that could be attributed to HMX treatment. Food intake did not show a consistent dose-related trend, but was reduced in treated animals as compared to controls.

[underlined: Dose and end point used for MRL derivation: 50 mg/kg/day- Hepatic]

- [Xl NOAEL [ ] LOAEL

[underlined: Uncertainy factors used in MRL derivation:]

- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying factors used in MRL derivation:]

- [X] 10 for use of a “limited database” and of data indicating that mice may be more sensitive than rats

[underlined: Supporting studies:]

Hepatocyte hyperplasia and cytoplasmic eosinophilia were noted in rats and mice exposed to 1,280 and 300 mg/kg/day HMX, respectively, for 14 days (Army 1985d, 1985e). No hepatic effects were observed in mice exposed to 90 mg/kg/day HMX (Army 1985b).

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose? If so explain:]

NA

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

NA

[underlined: MRL Calculation]:

NOAEL: 50 mg/kg/day

MRL = (NOAEL/UF)/ MF = (50/100)/10 = 0.05 mg/kg/day