# CHAPTER 8 REFERENCES

+ Cited in supplemental document

+Abdel-Rahman MS, Saladin JJ, Bohman CE. 1978. The effect of 2-hexanone and 2-hexanone metabolites on pupillomotor activity and growth. Am Ind Hyg Assoc J 39:94–99.637027
Abdo KM, Graham DG, Timmons PR, . 1982. Neurotoxicity of continuous (90 days) inhalation of technical grade methyl butyl ketone in hens. J Toxicol Environ Health 9:199–215.7077682
Abou-Donia MB, Makkawy HM, Graham DG. 1982. The relative neurotoxicities of n-hexane, methyl n-butyl ketone, 2,5-hexanediol, and 2,5-hexanedione following oral or intraperitoneal administration in hens. Toxicol Appl Pharmacol 62:369–389.7071856
Abou-Donia MB, Makkawy HM, Campbell GM. 1985b. Pattern of neurotoxicity of n-hexane, methyl n-butyl ketone, 2,5-hexanediol, and 2,5-hexanedione alone and in combination with o-ethylo-4-nitrophenyl phenylphosphonothioate in hens. J Toxicol Environ Health 16(1):85–100.4068058
Abou-Donia MB, Lapadula DM, Campbell G, . 1985a. The joint neurotoxic action of inhaled methyl butyl ketone vapor and dermally applied O-ethyl O-4nitrophenyl phenylphosphonothioate in hens: Potentiating effect. Toxicol Appl Pharmacol 79(1):69–82.4049408
Abou-Donia MB, Hu ZH, Lapadula DM, . 1991. Mechanisms of joint neurotoxicity of n-hexane, methyl isobutyl ketone and O-ethyl O-4-nitrophenyl phenylphosphonothioate in hens. J Pharmacol Exp Ther 257(1):282–289.2019992
ACGIH. 1986. Methyl-n-butyl ketone. In: Documentation of the threshold limit values and biological indices. 5th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, Inc., 378–379.
ACGIH. 2001. Methyl n-butyl ketone. In: Documentation of the threshold limit values and biological exposure indices. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 1–6.
ACGIH. 2003. Methyl n-butyl ketone. In: Documentation of the biological exposure indices. 7th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 1–3.
ACGIH. 2015. Methyl n-butyl ketone. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
+Allen N, Mendell JR, Billmaier DJ, . 1975. Toxic polyneuropathy due to methyl-n-butyl ketone: An industrial outbreak. Arch Neurol 32:209–218.164846
Ambrose D, Ellender JH, Lees EB, . 1975. Thermodynamic properties of organic oxygen compounds. XXXVIII. Vapour pressures of some aliphatic ketones. J Chem Thermodyn 7:453–472.
Anderson ME, Harland WA. 1980. The analysis of volatiles in blood from fire fatalities. In: Proceedings of the Forensic Toxicology European Meeting. Glasgow, Scotland: International Association of Toxicology, 279–292.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data Monograph 1. http://www.nist.gov/data/PDFfiles/jpcrdM1.pdf. April 19, 2016.
Atkinson R, Carter WP, Aschmann SM, . 1985. Atmospheric fates of organic chemicals: Prediction of ozone and hydroxyl radical reaction rates and mechanisms. Research Triangle Park: U.S. Environmental Protection Agency, 1–4, 60.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1999. Toxicological profile for n-hexane. Agency for Toxic Substances & Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/tp113.pdf. August 4, 2017.
ATSDR. 2008. Health consultation. Garfield county public health implications of ambient air exposure to volatile organic compounds as measured in rural, urban, and oil & gas development areas. Garfield County, Colorado. Agency for Toxic Substances and Disease Registry. https://www.colorado.gov/pacific/sites/default/files/HHW_CSA_Ambient-Air-in-Garfield-County-HC-3.13.2008.pdf. August 4, 2017.
ATSDR. 2017. 2-Hexanone. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
Babeu L, Vaishnav DD. 1987. Prediction of biodegradability for selected organic chemicals. J Ind Microbiol 2:107–115.
Badings HT, de Jong C, Dooper RPM. 1985. Automatic system for rapid analysis of volatile compounds by purge-and-cold-trapping/capillary gas chromatography. J High Resolut Chromatogr 8(11):755–763. 10.1002/jhrc.1240081111.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bavazzano P, Apostoli P, Balducci C, . 1998. Determination of urinary 2,5-hexanedione in the general Italian population. Int Arch Occup Environ Health 71(4):284–288.9638486
Bierbaum PJ, Marceleno T. 1973. Survey of Brammer Manufacturing Company, Davenport, Iowa. Cincinnati, OH: National Institute of Occupational Safety and Health. PB81231318.
Billmaier D, Yee HT, Allen N, . 1974. Peripheral neuropathy in a coated fabrics plant. J Occup Med 16:665–671.4375708
+Branchflower RV, Pohl LR. 1981. Investigation of the mechanism of the potentiation of chloroform-induced hepatotoxicity and nephrotoxicity by methyl n-butyl ketone. Toxicol Appl Pharmacol 61:407–413.7330881
+Branchflower RV, Schulick RD, George JW, . 1983. Comparison of the effects of methyl-n-butyl ketone and phenobarbital on rat liver cytochromes P-450 and the metabolism of chloroform to phosgene. Toxicol Appl Pharmacol 71(3):414–421. 10.1016/0041-008x(83)90029-7.6658790
+Brown EM, Hewitt WR. 1984. Dose-response relationships in ketone-induced potentiation of chloroform hepato- and nephrotoxicity. Toxicol Appl Pharmacol 76:437–453.6506071
Brown KW, Donnelly KC. 1988. An estimation of risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30.
Bryant BH, Yamasaki H, Sandrof MA, . 2008. Spermatid head retention as a marker of 2,5-hexanedione-induced testicular toxicity in the rat. Toxicol Pathol 36:552–559.18467684
Buttery RG, Stern DJ, Ling LC. 1994. Studies on flavor volatiles of some sweet corn products. J Agric Food Chem 42:791–795. 10.1021/jf00039a038.
Calvert JG, Pitts JN. 1966. Photochemistry of the polyatomic molecules. In: Photochemistry. New York, NY: John Wiley & Sons, Inc., 204.
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46:35–57. 10.1080/00207239408710909.
Chou CHSJ, Holler J, De Rosa CT. 1998. Minimal risk levels (MRLs) for hazardous substances. J Clean Technol Environ Toxicol Occup Med 7(1):1–24.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CLPSD. 1986. 2-Hexanone. Percentage occurrence by site in NPL sites. Contract Laboratory Program Statistical Database. Alexandria, VA: Viar and Company, Management Services Division.
+Couri D, Hetland LB, Abdel-Rahman MS, . 1977. The influence of inhaled ketone solvent vapors on hepatic microsomal biotransformation activities. Toxicol Appl Pharmacol 41:285–289.898199
+Cowlen MS, Hewitt WR, Schroeder F. 1984a. 2-Hexanone potentiation of (14C)chloroform hepatotoxicity: covalent interaction of a reactive intermediate with rat liver phospholipid. Toxicol Appl Pharmacol 73(3):478–491.6719463
+Cowlen MS, Hewitt WR, Schroeder F. 1984b. Mechanisms in 2-hexanone potentiation of chloroform hepatotoxicity. Toxicol Lett 22(3):293–299.6091297
+Davenport JG, Farrell CMDF, Sumi SM. 1976. “Giant axonal neuropathy” caused by industrial chemicals: Neurofilamentous axonal masses in man. Neurology 26:919–923.183168
Day EA, Anderson DF. 1965. Cheese flavor, gas chromatographic and mass spectral identification of neutral components of aroma faction and blue cheese. J Agric Food Chem 13:2–4.
DiVincenzo GD, Kaplan CJ, Dedinas J. 1976. Characterization of the metabolites of methyl n-butyl ketone, methyliso-butyl ketone, and methyl ethyl ketone in guinea pig serum and their clearance. Toxicol Appl Pharmacol 36:511–522.941151
DiVincenzo GD, Hamilton ML, Kaplan CJ, . 1977. Metabolic fate and disposition of 14C-labeled methyl n-butyl ketone in the rat. Toxicol Appl Pharmacol 41:547–560.918987
DiVincenzo GD, Hamilton ML, Kaplan CJ, . 1978. Studies on the respiratory uptake and excretion and the skin absorption of methyl n-butyl ketone in humans and dog. Toxicol Appl Pharmacol 44:593–604.567391
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
+Duckett S, Streletz IJ, Chambers RA, . 1979. 50 ppm MnBK subclinical neuropathy in rats. Experientia 35:1365–1367.499425
Duguay AB, Plaa GL. 1995. Tissue concentrations of methyl isobutyl ketone, methyl n-butyl ketone and their metabolites after oral or inhalation exposure. Toxicol Lett 75(1–3):51–58.7863537
Dumont JP, Adda J. 1978. Occurrence of sesquiterpenes in mountain cheese volatiles. J Agric Food Chem 26:364–367.
+Eben A, Flucke W, Mihail F, . 1979. Toxicological and metabolic studies of methyl n-butylketone, 2,5-hexanedione, and 2,5-hexanediole in male rats. Ecotoxicol Environ Saf 3:204–217.540560
+Egan G, Spencer P, Schaumburg H, . 1980. n-Hexane-"free" hexane mixture fails to produce nervous system damage. Neurotoxicology 1:515–524.
EIA. 2016. Energy in brief. Shale in the United States. U.S. Energy Information Administration. https://www.eia.gov/energy_in_brief/article/shale_in_the_united_states.cfm. November 02, 2016.
Eitzer BD. 1995. Emissions of volatile organic chemicals from municipal solid waste composting facilities. Environ Sci Technol 29:896–902. 10.1021/es00004a009.22176396
EPA. 1981. Chemical hazard information profile. Draft report methyl-n-butyl ketone. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1986. Gas chromatography/mass spectrometry for volatile organics. Method 8240. Test methods for evaluation solid waste. Washington, DC: U.S. Environmental Protection Agency. SW-846.
EPA. 1987. IV. Discussion of the chemical substance. U.S. Environmental Protection Agency. Fed Regist 52:11823–11826.
EPA. 1988. Superfund record of decision. Forest waste disposal. Otisville, Michigan. Second remedial action. Washington, DC: U.S. Environmental Protection Agency. EPARODR0588062. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91001K2I.txt. April 21, 2016.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009a. Toxicological review of 2-hexanone (CAS No. 591-78-6). U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1019tr.pdf. January 22, 2016.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2012a. 2-Hexanone. EPI Suite^TM^-Estimation program interface. U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. June 14, 2016.
EPA. 2012b. Benchmark dose technical guidance. Washington, DC: U.S. Environmental Protection Agency. EPA100R12001.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
FDA. 2019. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. June 5, 2019.
Fedtke N, Bolt HM. 1986. Methodological investigations on the determination of n-hexane metabolites in urine. Int Arch of Occup Environ Health 57:149–158.3949399
Girolami RL, Knight SG. 1955. Fatty acid oxidation by Penicillium roqueforti. Appl Microbiol 3(5):264–267.13249382
Granvil CP, Sharkawi M, Plaa GL. 1994. Metabolic fate of methyl n-butyl ketone, methyl isobutyl ketone and their metabolites in mice. Toxicol Lett 70(3):263–267.8284793
Grey TTC, Shrimpton DH. 1967. Volatile components of raw chicken breast muscle. Br Poult Sci 8:23–33.
Grinberg A. 2014. In the pits. Oil and gas wastewater disposal into open unlined pits and the threat to California’s water and air. Clean Water Action, Clean Water Fund. http://www.cleanwateraction.org/sites/default/files/docs/publications/In%20the%20Pits.pdf. November 7, 2017.
Hansch C, Leo A, Hoekman D. 1995. 2-Hexanone. In: Exploring QSAR. Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 24.
+Hansen LF, Nielsen GD. 1994. Sensory irritation and pulmonary irritation of n-methyl ketones: Receptor activation mechanisms and relationships with threshold limit values. Arch Toxicol 68(3):193–202.8024467
Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18(6):483–490. 10.1021/es00124a016.22247953
Hayes T. 2009. Sampling and analysis of water streams associated with the development of Marcellus shale gas. Final report. Marcellus Shale Coalition. http://energyindepth.org/wp-content/uploads/marcellus/2012/11/MSCommission-Report.pdf. August 17, 2017.
Helmig D, Arey J. 1992. Organic chemicals in the air at Whitaker’s forest Sierra Nevada Mountains, California. Sci Total Environ 112(2–3):233–250. 10.1016/0048-9697(92)90190-4 1566045
+Hewitt WR, Brown EM, Plaa GL. 1983. Relationship between the carbon skeleton length of ketonic solvents and potentiation of chloroform-induced hepatotoxicity in rats. Toxicol Lett 16(3–4):297–304.6857725
+Hewitt LA, Ayotte P, Plaa GL. 1986. Modifications in rat hepatobiliary function following treatment with acetone, 2-butanone, 2-hexanone, mirex, or chlordecone and subsequently exposed to chloroform. Toxicol Appl Pharmacol 83(3):465–473. 10.1016/0041-008x(86)90229-2.2422788
+Hewitt WR, Miyajima H, Cote MG, . 1980. Acute alteration of chloroform-induced hepato- and nephrotoxicity by n-hexane, methyl n-butyl ketone, and 2,5-hexanedione. Toxicol Appl Pharmacol 53:230–248.7394766
HHS. 2017. Household products database. Health & safety information on household products. Rockville Place, MD: U.S. Department of Health and Human Services. https://householdproducts.nlm.nih.gov/. October 3, 2019.
HSDB. 2009. 2-Hexanone. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 19, 2016.
IARC. 2019. Agents classified by the IARC monographs. Volumes 1–123. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. May 29, 2019.
IRIS. 2009. 2-Hexanone. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/1019_summary.pdf. June 5, 2019.
+Johnson BL, Setzer JV, Lewis TR, . 1977. Effects of methyl n-butyl ketone on behavior and the nervous system. Am Ind Hyg Assoc J 38:567–579.412406
+Kanada M, Miyagawa M, Sato M, . 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats: 1. Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32(3):145–164.7698903
+Katz G, O’Donoghue JL, DiVincenzo GD, . 1980. Comparative neurotoxicity and metabolism of ethyl n-butyl ketone and methyl n-butyl ketone in rats. Toxicol Appl Pharmacol 52:153–158.7361307
Kinlin T, Muralidhara R, Pittet A, . 1972. Volatile components of roasted filberts. J Agric Food Chem 20:1021–1028.
+Krasavage WJ, O’Donoghue JL. 1977. Chronic inhalation exposure of rats to methyl n-butyl ketone (MnBK). Eastman Kodak Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0555051. EPA Document No. 88930008233.
+Krasavage WJ, O’Donoghue JL, Di VGD, . 1980. The relative neurotoxicity of methyl-n-butyl ketone, n-hexane and their metabolites. Toxicol Appl Pharmacol 52:433–441.7368216
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kumar A, Alaimo CP, Horowitz R, . 2011. Volatile organic compound emissions from green waste composting: Characterization and ozone formation. Atmos Environ 45:1841–1848.
Laity JL, Burstain IG, Appel BR. 1973. Photochemical smog and the atmospheric reactions of solvents. Adv Chem Ser 124:95–112.
Lande SS, Durkin PR, Christopher DE, . 1976. Investigation of selected potential environmental contaminants: Ketonic solvents. Washington, DC: U.S. Environmental Protection Agency. EPA560276003. NTIS No. TR 76-500.
Lapadula DM, Habig C, Gupta RP, . 1991. Induction of cytochrome P450 isozymes by simultaneous inhalation exposure of hens to n-hexane and methyl iso-butyl ketone (MiBK). Biochem Pharmacol 6(7):877–883.
LoPachin RM, DeCaprio AP. 2004. gamma-Diketone neuropathy: Axon atrophy and the role of cytoskeletal protein adduction. Toxicol Appl Pharmacol 199(1):20–34. 10.1016/j.taap.2004.03.008.15289087
Lopachin RM, DeCaprio AP. 2005. Protein adduct formation as a molecular mechanism in neurotoxicity. Toxicol Sci 86(2):214–225.15901921
LoPachin RM, Gavin T. 2015. Toxic neuropathies: Mechanistic insights based on a chemical perspective. Neurosci Lett 596:78–83. 10.1016/j.neulet.2014.08.054.25218479
LoPachin RM, Lehning EJ, Opanashuk LA, . 2000. Rate of neurotoxicant exposure determines morphologic manifestations of distal axonopathy. Toxicol Appl Pharmacol 167(2):75–86. 10.1006/taap.2000.8984.10964758
Lowery CE, Foster JW, Jurtshuk P. 1968. The growth of various filamentous fungi and yeasts on n-alkanes and ketones. Arch Mikrobiol 60:246–254.5750910
Lucas SV. 1984. GC/MS analysis of organics in drinking water concentrates and advanced waste treatment concentrates. Volume 1. Research Triangle Park, NC: U.S. Environmental Protection Agency. 189, 247. EPA600184020a.
Lukins HB, Foster JW. 1963. Methyl ketone metabolism in hydrocarbon utilizing mycobacteria. J Bacteriol 85:1074–1087.14043998
Luster MI, Munson AE, Thomas PT, . 1988. Development of a testing battery to assess chemical-induced immunotoxicity: National Toxicology Program’s guidelines for immunotoxicity evaluation in mice. Fundam Appl Toxicol 10:2–19 3280374
MacLeod H, Jourdain JL, Poulet G, . 1984. Kinetic study of reactions of some organic sulfur compounds with OH radicals. Atmos Environ 18(12):2621–2626.
Mallov JS. 1976. MBK neuropathy among spray painters. J Am Med Assoc 235:1455–1457.
Marceleno T, Bierbaum PJ, Malloy JS. 1974. Survey of Premium Finishes, Incorporated. Cincinnati, OH: National Institute for Occupational Safety and Health. PB81242729.
McCormick RL, Ratcliff MA, Christensen E, . 2015. Properties of oxygenates found in upgraded biomass pyrolysis oil as components of spark and compression ignition engine fuels. Energy Fuels 29(4):2453–2461. 10.1021/ef502893g.
+Mendell JR, Sahenk Z, Saida K, . 1977. Alterations of fast axoplasmic transport in experimental methyl n-butyl ketone neuropathy. Brain Res 133(1):107–118. 10.1016/0006-8993(77)90052-x.71185
+Mendell JR, Saida K, Ganansia MF, . 1974. Toxic polyneuropathy produced by methyl n-butyl ketone. Science 185:787–789.4367263
Myers VB. 1983. Remedial activities at the Miami Drum site, Florida. National Conference of Management of Uncontrolled Hazardous Waste Sites. In: Hazardous Materials Control Research Institute, 354–357.
Nakajima D, Ishii R, Kageyama S, . 2006. Genotoxicity of microbial volatile organic compounds. J Health Sci 52:148–153.
+Narotsky MG, Pegram RA, Kavlock RJ. 1997. Effect of dosing vehicle on the developmental toxicity of bromodichloromethane and carbon tetrachloride in rats. Fundam Appl Toxicol 40(1):30–36.9398485
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NIOSH. 1978. Criteria for a recommended standard: Occupational exposures in coal classification plants. Cincinnati, OH: National Institute for Occupational Safety and Health. DHEW (NIOSH) Pub No. 78191.
NIOSH. 1984. Ketones I Method 1300. NIOSH manual of analytical methods. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1994. 2-Hexanone. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/591786.html. June 5, 2019.
NIOSH. 2018. 2-Hexanone. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0325.html. June 5, 2019.
Nomeir AA, Abou-Donia MB. 1985. Analysis of n-hexane, 2-hexanone, 2,5-hexanedione, and related chemicals by capillary gas chromatography and high-performance liquid chromatography. Anal Biochem 151:381–388.4096376
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
O’Donoghue JL. 1985. Alkanes, alcohols, ketones, and ethylene oxide. In: Neurotoxicity of industrial and commercial chemicals. Boca Raton, FL: CRC Press Inc., 61–97.
+O’Donoghue JL, Krasavage WJ. 1979. Chronic inhalation exposure of cats to methyl n-butyl ketone (MnBK). Eastman Kodak Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0555051. EPA Document No. 88920008233.
+O’Donoghue JL, Krasavage WJ, Terhaar CJ. 1978. A comparative chronic toxicity study of methyl n-propyl ketone, methyl n-butyl ketone, and hexane by ingestion. Eastman Kodak Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA Document No. 88920008233. OTS0555051.
OSHA. 1995. 2-Hexanone. Method number OV2013. Occupational Safety & Health Administration. https://www.osha.gov/dts/sltc/methods/partial/pv2031/2031.html. April 18, 2016.
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 28, 2018.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
PA DEP. 2011. Northern Pennsylvania Marcellus shale short-term ambient air sampling report. Pennsylvania Department of Environmental Protection. http://www.dep.state.pa.us/dep/deputate/airwaste/aq/aqm/docs/Marcellus_NE_01-12-11.pdf. August 17, 2017.
Pellizzari ED, Castillo NP, Willis S, . 1979. Identification of organic components in aqueous effluents from energy-related processes. In: Measurement of organic pollutants in water and wastewater. Vol. 686. Philadelphia, PA: American Society for Testing and Materials, 256–274.
Perry JJ. 1968. Substrate specificity in hydrocarbon utilizing microorganisms. Antonie Van Leeuwenhoek 34:27–36.5300487
Perry DL, Chuang CC, Jungclaus GA, . 1979. Identification of organic compounds in industrial effluent discharges. Athens, GA: U.S. Environmental Protection Agency.
+Peters MA, Hudson PM, Dixon RL. 1981. The effect totigestational exposure to methyl n-butyl ketone has on postnatal development and behavior. Ecotoxicol Environ Saf 5:291–306.7297468
Plumb RHJ. 1992. The importance of volatile organic compounds as a disposal site monitoring parameter. In: Lesage S, Jackson RE, eds. Environmental science pollution control series 4, groundwater contamination and analysis at hazardous waste sites. New York, NY: Mercel Dekker, Inc., 173–197.
Ramarathnam N, Rubin LJ, Diosady LL. 1991. Studies on meat flavor. 2. A quantitative investigation of the volatile carbonyls and hydrocarbons in uncured and cured beef and chicken. J Agric Food Chem 39:1839–1847.
RePORTER. 2019. 2-Hexanone. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. February 28, 2017.
Richardson SD, Thruston ADJ, Caughran TV, . 1999. Identification of new ozone disinfection byproducts in drinking water. Environ Sci Technol 33:3368–3377. 10.1021/es981218c.
RPSEA. 2012. Barnett and Appalachian shale water management and reuse technologies. Research Partnership to Secure Energy for America. Report No. 08122-05. https://www.netl.doe.gov/File%20Library/Research/Oil-Gas/Natural%20Gas/shale%20gas/08122-05-final-report.pdf. August 11, 2017.
RTECS. 2009. 2-Hexanone. Registry of Toxic Effects of Chemical Substances. http://www.cdc.gov/niosh-rtecs/MP155CC0.html. March 7, 2016.
+Saida K, Mendell JR, Weiss HS. 1976. Peripheral nerve changes induced by methyl n-butyl ketone and potentiation by methyl ethyl ketone. J Neuropathol Exp Neurol 35(3):207–225.178832
Sato A, Nakajima T. 1979. Partition coefficients of some aromatic hydrocarbons and ketones in water, blood and oil. Br J Ind Med 36(3):231–234. 10.1136/oem.36.3.231.500783
+Schrenk HH, Yant WP, Patty FA. 1936. Acute response of guinea pigs to vapors of some new commercial organic compounds: X. Hexanone (methyl butyl ketone). Public Health Rep 51(20):624–631. 10.2307/4581834.
Shackelford WM, Keith LH. 1976. Frequency of organic compounds identified in water. Athens, GA: Environmental Research Laboratory. EPA600476062. PB165470.
+Smyth HF, Carpenter CP, Weil CS, . 1954. Range-finding toxicity data, List V. AMA Arch Ind Health 10:61–68.
+Spencer PS, Schaumburg HH, Raleigh RL, . 1975. Nervous system degeneration produced by the industrial solvent methyl n-butyl ketone. Arch Neurol 32:219–221.1124984
Takeoka GR, Flath RA, Guntert M, . 1988. Nectarine volatiles: Vacuum steam distillation versus headspace sampling. J Agric Food Chem 36:553–560.
TCEQ. 2011. Superfund site discovery and assessment program. Removal action report. Dona Park residential removal site. Corpus Christi, Nueces County, TX. Houston, TX: Texas Commission on Environmental Quality. https://www.tceq.texas.gov/assets/public/remediation/variousremediationsites/donapark/dona_park_rar_final.pdf. August 10, 2016.
Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15-11–15-34.
Topping DC, Morgott DA, O’Donoghue JL. 2001. Ketones of six to thirteen carbons. In: Bingham E, Cohrssen B, Powell CH, eds. Patty’s toxicology. Vol. 6. 5th ed. New York, NY: John Willey & Sons, Inc., 195–363.
+Union Carbide. 1977. Comparative toxicity to rats of methoxyacetone and five other aliphatic ketones in their drinking water with cover letter. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206068. EPA Document No. 8DS878212140.
White EL, Bus JS, Heck HA. 1979. Simultaneous determination of n-hexane, 2-hexanone and2,5-hexanedione in biological tissues by gas chromatography mass spectrometry. Biomed Mass Spectrom 6(4):169–172.385075
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Yalkowsky SH, He Y. 2003. 2-Hexanone. In: Handbook of aqueous solubility data. Boca Raton, FL: CRC Press, 301.
Yu RC, Hattis D, Landaw EM, . 2002. Toxicokinetic interaction of 2,5-hexanedione and methyl ethyl ketone. Arch Toxicol 75:643–652.11876497