# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Nickolette Roney, M.P.H. (Lead)
  Carolyn Harper, Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Fernando Llados, Ph.D.
  Julie M. Klotzbach, Ph.D.
  Courtney Hard, B.A.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.

## PEER REVIEWERS

1. James Blando, Ph.D., School of Community & Environmental Health, Old Dominion University, Norfolk, Virginia;
2. Richard M. LoPachin, Ph.D., Montefiore Medical Center, Bronx, New York;
3. Michael Aschner, Ph.D., Department of Molecular Pharmacology, Albert Einstein College of Medicine, Bronx, New York.

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.