# VERSION HISTORY

Date | Description
February 2020 | Final toxicological profile released
April 2018 | Draft for public comment toxicological profile released
September 1992 | Final toxicological profile released