# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 2-hexanone in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 2-hexanone.

Table 7-1 Regulations and Guidelines Applicable to 2-Hexanone

Agency | Description | Information | Reference
Air
EPA | RfC | 3x10^-2^ mg/m^3a^ | IRIS 2009
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009b
EPA | RfD | 5x10^-3^ mg/kg-day^b^ | IRIS 2009
WHO | Drinking water quality guidelines | Not listed | WHO 2017
FDA | Substances Added to Food | Not listed^c^ | FDA 2019
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | Inadequate information to assess carcinogenic potential | IRIS 2009
IARC | Carcinogenicity classification | Not listed | IARC 2019
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 100 ppm (410 mg/m^3^) | OSHA 2018a, 2018b, 2018c
NIOSH | REL (up to 10-hour TWA) | 1 ppm (4 mg/m^3^) | NIOSH 2018
NIOSH | IDLH | 1,600 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^d^ | 10 ppm | DOE 2018a
DOE | PAC-2^d^ | 830 ppm | DOE 2018a
DOE | PAC-3^d^ | 5,000 ppm | DOE 2018a

a The RfC is based on a BMCL_05(HEC)_ of 90 mg/m^3^ for reduced motor conduction velocity of the sciatic-tibial nerve in monkeys in a subchronic inhalation study.

b The RfD is based on a BMDL_10_ of 5 mg/kg-day for axonal swelling of the peripheral nerve in rats in a chronic drinking water study.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; BMCL = 95% lower confidence limit on the benchmark concentration; BMDL = 95% lower confidence limit on the benchmark dose; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HEC = human equivalent concentration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization