# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for 2-hexanone. Note that the purity of commercial-grade 2-hexanone ranges from 70 to 96%; contaminants may include methyl isobutyl ketone (MiBK) (Topping et al. 2001).

Table 4-1 Chemical Identity of 2-Hexanone^a^

Characteristic | Information
Chemical name | 2-Hexanone
Synonym(s) and registered trade name(s) | Methyl n-butyl ketone; MBK; 2-oxohexane; n-butyl methyl ketone, propylacetone; MnBK
Chemical formula | C_6_H_12_O
Chemical structure | [image]
CAS Registry Number | 591-78-6

a All information obtained from HSDB (2009), unless otherwise noted.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 4-2 lists important physical and chemical properties of 2-hexanone.

Table 4-2 Physical and Chemical Properties of 2-Hexanone

Property | Information
Molecular weight | 100.16
Color | Colorless
Physical state | Liquid
Melting point | -55.5°C
Boiling point | 127.2°C
Density at 20°C | 0.83
Odor | Similar to acetone, but more pungent
Odor threshold:
Water | 0.25 mg/L
Air | 0.076 ppm (0.31 mg/m^3^)
Solubility:
Water at 20°C | 1.72x10^4^ mg/L
Organic solvents | Soluble in acetone; miscible in ethanol and ether
Partition coefficients:
Log K_ow_ | 1.38
Log K_oc_ | No data
Vapor pressure at 25°C | 11.6 mm Hg
Henry’s law constant | 9.32x10^-5^ atm-m^3^/mol at 25°C (estimated)
Autoignition temperature | 795°F (423°C)
Flashpoint | 95°F (35°C) (open cup); 77°F (25°C) (closed cup)
Flammability limits | 1.2–8%
Conversion factors at 25°C, 760 mm Hg | 1 ppm=4.10 mg/m^3^; 1 mg/L=244 ppm
Explosive limits | 1.22–8%

Source: HSDB 2009