# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR 2-HEXANONE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 2-hexanone.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for 2-hexanone. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of 2-hexanone have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of 2-hexanone are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer
- Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for 2-hexanone released for public comment in April 2018. The following main databases were searched in March 2019:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for 2-hexanone. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to 2-hexanone were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
03/2019 | ((591-78-6[rn] OR “Methyl n-Butyl Ketone”[mh] OR “2-Hexanone”[tw] OR “2-Oxohexane”[tw] OR “Butyl methyl ketone”[tw] OR “Butylmethyl Ketone”[tw] OR “Hexan-2-one”[tw] OR “Hexanone-2”[tw] OR (“MBK”[tw] AND (ketone OR hexanone)) OR “Methyl butyl ketone”[tw] OR “Methyl n-butyl ketone”[tw] OR “n-Butyl methyl ketone”[tw] OR “Propylacetone”[tw]) AND (2014/12/01 : 3000[dp] OR 2015/12/01 : 3000[mhda] OR 2015/12/01 : 3000[crdat] OR 2015/12/01 : 3000[edat])) OR (“2-HEXANON”[tw] OR “Hexan-2-on”[tw] OR “hexan-2-ona”[tw] OR “hexane-2-one”[tw] OR “Ketone, butyl methyl”[tw] OR “MnBK”[tw])
Toxline
03/2019 | Year of Publication 2014 through 2019; (591-78-6[rn] OR “2-Hexanone” OR “2-Oxohexane” OR “Butyl methyl ketone” OR “Butylmethyl Ketone” OR “Hexan-2-one” OR “Hexanone-2” OR “Methyl butyl ketone” OR “Methyl n-butyl ketone” OR “n-Butyl methyl ketone” OR “Propylacetone” OR “2-HEXANON” OR “Hexan-2-on” OR “hexan-2-ona” OR “hexane-2-one” OR “Ketone, butyl methyl”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; Year of Publication 2014 through 2019; (“MBK” AND (ketone OR hexanone)) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; (“2-HEXANON” OR “Hexan-2-on” OR “hexan-2-ona” OR “hexane-2-one” OR “Ketone, butyl methyl” OR “MnBK”) AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
03/2019 | L1 1426 SEA FILE=TOXCENTER 591-78-6; L2 1286 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 1253 SEA FILE=TOXCENTER L2 NOT TSCATS/FS; L4 82 SEA FILE=TOXCENTER L3 AND ED>=20151201; L5 116 SEA FILE=TOXCENTER L3 AND PY>2014; L6 116 SEA FILE=TOXCENTER L4 OR L5; ANSWERS ‘1-115’ FROM FILE TOXCENTER ACT TOXQUERY/Q; -------; L11 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L12 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); L13 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L14 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L15 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L16 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L17 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L18 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L19 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L20 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); L21 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L22 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L23 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L24 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L25 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L26 QUE (ENDOCRIN? AND DISRUPT?); L27 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L28 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L29 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L30 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L31 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L32 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L33 QUE (NEPHROTOX? OR HEPATOTOX?); L34 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L35 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L36 QUE L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34 OR L35; L37 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L38 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L39 QUE L36 OR L37 OR L38; L40 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L41 QUE L39 OR L40; -------; L42 47 SEA FILE=TOXCENTER L6 AND L41; L43 46 DUP REM L42 (1 DUPLICATE REMOVED); ANSWERS ‘1-46’ FROM FILE TOXCENTER D SCAN L43

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
03/2019 | Compounds searched: 591-78-6
NTP
03/2019 | “591-78-6” “2-Hexanone”; “Butylmethyl Ketone” “Methyl butyl ketone” “Methyl n-butyl ketone” “n-Butyl methyl ketone”; “Hexan-2-one” “Hexanone-2” “Butyl methyl ketone” “2-Oxohexane”; “Propylacetone” “Ketone, butyl methyl” “MBK” “mnbk”; “2-HEXANON” “Hexan-2-on” “hexan-2-ona” “hexane-2-one”
DTIC
05/2019 | Synonyms in all fields search box; “591-78-6” OR “2-Hexanone” OR “2-Oxohexane” OR “Butyl methyl ketone” OR “Hexanone-2” OR “Methyl butyl ketone” OR “Methyl n-butyl ketone” OR “Propylacetone” OR “n-Butyl methyl ketone” OR “Butylmethyl Ketone” OR “Hexan-2-one” OR “2-Hexanone Methyl n-butyl ketone” OR “2-hexanon” OR “hexan-2-on” OR “hexan-2-ona” OR “hexane-2-one” OR “ketone, butyl methyl” OR “MnBK” OR (“MBK” AND (“ketone” OR “hexanone”)); Keywords in citation terms box; “toxicity” OR “toxicology” OR “poisoning” OR “cancer” OR “carcinogens” OR “carcinogen” OR “neoplasms” OR “neoplasm” OR “oncogenesis” OR “teratogenic compounds” OR “lethality” OR “death” OR “body weight” OR “immunology” OR “genotoxicity” OR “mutagenicity” OR “mutagens” OR “mutations” OR “oral” OR “gavage” OR “inhalation” OR “dermal” OR “metabolism” OR “pharmacokinetics” OR “pharmacokinetic” OR “PBPK” OR “pharmacology” OR “organs” OR “skin” OR “tissues” OR “body fluids” OR “toxic agents” OR “rats” OR “mice” OR “mouse” OR “rat”
NIH RePORTER
09/2019 | “2-Hexanone” OR “2-Oxohexane” OR “Butyl methyl ketone” OR “Butylmethyl Ketone” OR “Hexan-2-one” OR “Hexanone-2” OR (“MBK” AND (ketone OR hexanone)) OR “Methyl butyl ketone” OR “Methyl n-butyl ketone” OR “n-Butyl methyl ketone” OR “Propylacetone” OR “2-HEXANON” OR “Hexan-2-on” OR “hexan-2-ona” OR “hexane-2-one” OR “Ketone, butyl methyl” OR “MnBK” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

The 2019 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 86
- Number of records identified from other strategies: 23
- Total number of records to undergo literature screening: 109

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on 2-hexanone:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 112
- Number of studies considered relevant and moved to the next step: 32

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 32
- Number of studies cited in the pre-public draft of the toxicological profile: 129
- Total number of studies cited in the profile: 148

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 March 2019 Literature Search Results and Screen for 2-Hexanone

Figure B-1 Description