# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## 2-Hexanone Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Numbers: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: An acute-duration inhalation MRL for 2-hexanone was not derived due to lack of appropriate studies in humans or in animals. The only information located regarding effects in humans is that men (unknown number) exposed to ≥2,300 ppm vapors of a commercial-grade 2-hexanone for brief periods of time (25–60 seconds) found the atmospheres extremely disagreeable due to a strong odor and had irritation of the eyes and nasal passages (Schrenk et al. 1936). The same group of investigators reported that an unspecified number of guinea pigs exposed to 2,300 ppm 2-hexanone showed signs of eye and nose irritation after 1 minute of exposure and lacrimation after 10 minutes of exposure; no such signs were reported in guinea pigs exposed to 1,000 ppm 2-hexanone. Exposure of guinea pigs to 6,500 ppm for 540 minutes caused lethality.

Agency Contacts (Chemical Managers): Nickolette Roney

## 2-Hexanone Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Numbers: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: An intermediate-duration inhalation MRL for 2-hexanone was not derived because the lowest dose tested in an animal study induced serious neurological effects; ATSDR does not derive MRLs based on serious LOAELs. The lowest LOAEL reported was 50 ppm for sciatic nerve demyelination (a serious effect) in rats exposed for 8 hours/day, 5 days/week for 6 months (Duckett et al. 1979). Other intermediate-duration inhalation studies reported neurological effects (decreased nerve conduction velocity, neuropathy, and histopathological changes to central and peripheral nerves) occurring at higher exposure levels (≥100–1,000 ppm) (Duckett et al. 1979; Egan et al. 1980; Johnson et al. 1977; Katz et al. 1980; Mendell et al. 1974; Saida et al. 1976; Spencer et al. 1975). Other adverse effects included decreased body weight and decreased white blood cell count (Johnson et al. 1977; Katz et al. 1980); however, these effects were observed at exposure levels of 700–1,000 ppm.

Agency Contacts (Chemical Managers): Nickolette Roney

## 2-Hexanone Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Numbers: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: A chronic-duration inhalation MRL for 2-hexanone was not derived due to lack of adequate data. Peripheral neuropathy, rated as moderate to severe, was observed in workers exposed to 2-hexanone (Allen et al. 1975; Billmaier et al. 1974). Workers were also exposed to methyl ethyl ketone, which has been shown to potentiate the effects induced by 2,5-hexanedione, the toxic metabolite of 2-hexanone (Saida et al. 1976; Yu et al. 2002). Therefore, these data are not suitable for derivation of the chronic-duration inhalation MRL. Two chronic-duration inhalation studies have been conducted in animals, one in rats exposed intermittently to 2-hexanone for 72 weeks (Krasavage and O’Donoghue 1977) and one in cats similarly exposed for 2 years (O’Donoghue and Krasavage 1979). In both studies, the lowest LOAEL reported was 330 ppm for serious neurological effects (peripheral neuropathy and axonal degeneration of central and peripheral nerves), with a NOAEL of 100 ppm. However, because a serious LOAEL of 50 ppm for sciatic nerve demyelination was observed in an intermediate-duration study in rats (Duckett et al. 1979), a chronic-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Nickolette Roney

## 2-Hexanone Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Numbers: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: An acute-duration oral MRL was not derived for 2-hexanone because of insufficient database. There are no human data, and the database in animals consists of a report of an oral LD_50_ in rats (Smyth et al. 1954) and a study of the potentiation action of 2-hexanone on liver and kidney toxicity caused by chloroform (Brown and Hewitt 1984). In that study, a single high dose of 1,500 mg/kg alone (only dose tested) did not induce morphological alterations in the liver, but produced epithelial degeneration in proximal tubules of the kidneys. However, the Brown and Hewitt (1984) study did not assess neurological effects, the most sensitive effect of 2-hexanone for both inhalation and oral exposure. Therefore, an acute-duration oral MRL was not derived.

Agency Contacts (Chemical Managers): Nickolette Roney

## 2-Hexanone Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Numbers: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: An intermediate-duration oral MRL for 2-hexanone was not derived because the lowest dose tested in an animal study induced serious neurological effects; a serious LOAEL is not considered a suitable basis for an MRL. The lowest LOAEL reported was 310 mg/kg/day for an approximately 40% reduction in locomotor activity in guinea pigs exposed to 2-hexanone in drinking water for 24 weeks; this effect was classified as a serious LOAEL. Pupillary responses to light stimuli were also significantly reduced at this dose level. Other intermediate-duration oral studies reported adverse neurological effects at higher daily doses. These effects include peripheral neuropathy in rats administered ≥480 mg/kg/day (Union Carbide 1977); hindlimb weakness in rats administered 400 mg/kg/day (Eben et al. (1979), and paralysis in rats exposed to 660 mg/kg/day (Krasavage et al. 1980).

Agency Contacts (Chemical Managers): Nickolette Roney

## 2-Hexanone Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Hexanone
CAS Number: | 591-78-6
Date: | February 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.05 mg/kg/day
Critical Effect: | Axonal swelling in peripheral nerve and spinal cord
Reference: | O’Donoghue et al. 1978
Point of Departure: | LOAEL of 143 mg/kg/day
Uncertainty Factor: | 1,000
Modifying factor: | 3
LSE Graph Key: | 7
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.05 mg/kg/day was derived for 2-hexanone based on axonal swelling in peripheral nerve in rats administered via drinking water for 13 months (O’Donoghue et al. 1978). The MRL is based on a LOAEL of 143 mg/kg/day and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, 10 for human variability) and a modifying factor of 3 for a high response at the lowest dose tested.

Selection of the Critical Effect: One chronic-duration oral study evaluated the toxicity of 2-hexanone (O’Donoghue et al. 1978). The lowest LOAEL reported was 143 mg/kg/day for neurotoxicity. The study also reported reduced body weight at 266 mg/kg/day and skeletal muscle myofiber atrophy at 560 mg/kg/day. Neurotoxicity also has been observed in intermediate-duration oral studies and in animals and humans exposed to 2-hexanone via inhalation; see discussion below (Other Additional Studies or Pertinent Information that Lend Support to this MRL).

Selection of the Principal Study: One chronic-duration oral exposure study was identified (O’Donoghue et al. 1978). This is a well-conducted study that conducted neurological examinations and microscopic examinations of numerous tissues.

Summary of the Principal Study:

O’Donoghue JL, Krasavage WJ, Terhaar CJ. 1978. A comparative chronic toxicity study of methyl n-propyl ketone, methyl n-butyl ketone, and hexane by ingestion. Eastman Kodak Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. EPA Document No. 88920008233. OTS0555051.

Groups of male Sprague-Dawley rats (10/group) were exposed to drinking water containing 0, 0.25, 0.5, or 1.0% 2-hexanone (96.1% purity) for 13 months. Based on water consumption and body weight data, the investigators calculated daily doses of 2-hexanone of 0, 143, 266, or 560 mg/kg/day. There were two control groups, each with 10 rats. Rats were observed daily for clinical signs; body weight measurements and neurological examinations were performed weekly. At termination of exposure, the hindlimb sciatic-plantar nerve, multiple levels of the spinal cord, medulla, and cerebellum from five rats per group were embedded in plastic for microscopic examination. Most tissues and organs from the highest dose group and target organs from lower dose groups were embedded in paraffin for light microscopy examination.

Clinical signs were restricted to neurological effects and reduced body weight. Final body weights were reduced approximately 6, 14, and 30% in the 143, 266, and 560 mg/kg/day dose groups, respectively. No information was provided regarding food consumption. Clinical neurological signs were seen in the 266 and 560 mg/kg/day groups. Signs first appeared on day 42 in the 560 mg/kg/day group and on day 77 in the 266 mg/kg/day group. All rats in the 560 mg/kg/day group showed severe deficits. Signs included decreased extension of hindlimbs, hindlimb weakness, waddling gait, dragging of hind paws, and loss of tone in hindlimb musculature with grossly observable atrophy of hindlimb musculature and axial muscles of the lumbar area. Weakness of the forelimbs was seen in three out of nine rats in the 560 mg/kg/day group by the end of the study. No clinical progression was apparent in the 266 mg/kg/day group. Histological examination showed that rats from all treated groups had “giant” axonal neuropathy. Axonal swelling and giant axonopathy were common in peripheral nerves and spinal cord from 560 mg/kg/day rats, less common in dorsal root ganglia, and rare in the brain. Sections embedded in plastic showed clumping of axonal organelles. Myelin alterations were also seen in peripheral nerves. Neurogenic skeletal muscle atrophy occurred in proximal and distal hindlimb musculature. Alterations in the 266 mg/kg/day group were similar but less severe. Less severe changes were seen in peripheral nerves from 143 mg/kg/day rats; fewer giant axons were evident, but myelin changes were more common. Spinal lesions and neurogenic muscle atrophy were minimal. Relevant incidence data are shown in Table A-1. No treatment-related gross or microscopic alterations were reported in tissues other than the nervous system and skeletal muscle.

Table A-1 Incidence Data for Neuropathological Lesions in Rats exposed to 2-Hexanone for 13 Months

Dose (mg/kg/day) | Brain | Axonal swelling | | Peripheral nerve | Myofibrillar atrophy
Dose (mg/kg/day) | Brain | Spinal cord | Dorsal root ganglia | Peripheral nerve | Quadriceps muscle | Calf muscle
0 | 0/10 | 0/5 | 0/5 | 0/10 | 0/10 | 0/10
143 | 2/10 | 7/10^a^ | 0/7 | 8/10^a^ | 1/10 | 2/10
266 | 4/10^a^ | 5/5^a^ | 0/5 | 10/10^a^ | 5/10^a^ | 6/10^a^
560 | 8/10^a^ | 5/5^a^ | 3/5 | 10/10^a^ | 10/10^a^ | 10/10^a^

a p<0.05 per Fisher Exact Test conducted by SRC, Inc.

Source: O’Donoghue et al. 1978

Selection of the Point of Departure for the MRL: Benchmark dose (BMD) modelling of the incidence data for axonal swelling in peripheral nerve of rats in the O’Donoghue et al. (1978) study was considered and rejected because a nearly maximum response level (80%) was reached with the lowest dose tested. In such cases, there is great uncertainty because the BMD may be just below the first dose or orders of magnitude lower (EPA 2012b). Therefore, the NOAEL/LOAEL approach was used to derive a chronic-duration oral MRL for 2-hexanone.

Calculations: Conversion of drinking water concentrations to daily doses (mg/kg/day) was done by the investigators.

Uncertainty Factor (UF) and Modifying Factor (MF):

- 10 UF for use of a LOAEL
- 10 UF for extrapolation from animals to humans
- 10 UF for human variability
- 3 MF to account for an 80% response rate at the lowest dose

- MRL = LOAEL ÷ (UFs × MF)
- 0.05 mg/kg/day = 143 mg/kg/day ÷ (1,000 × 3)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: 2-Hexanone is well-known as a neurotoxic chemical that has been tested in a variety of animal species. Neurotoxicity, including hind limb weakness, paralysis, decreased locomotor activity, and peripheral neuropathy, was observed in intermediate-duration oral exposure studies reported in rats and guinea pigs (Abdel-Rahman et al. 1978; Eben et al. 1979; Krasavage et al. 1980; Union Carbide 1977). Although no studies examining oral exposure of 2-hexanone in humans were identified, case reports and studies in workers also provide evidence that 2-hexanone produces neurotoxicity in humans following inhalation exposure (Allen et al. 1975; Billmaier et al. 1974; Davenport et al. 1976; Mallov 1976). Inhalation studies in animals also demonstrate that 2-hexanone is neurotoxic, with adverse neurological effects following acute exposure of guinea pigs (Schrenk et al. 1936), intermediate exposure of monkeys, rats, and cats (Duckett et al. 1979; Egan et al. 1980; Johnson et al. 1977; Katz et al. 1980; Mendell et al. 1974; Saida et al. 1976; Spencer et al. 1975), and chronic exposure of rats and cats (Krasavage and O’ Donoghue 1977, 1979). Because the toxic chemical form of 2-hexanone is the metabolite, 2,5-hexanedione, and 2,5-hexanedione is also a metabolite of n-hexane, additional relevant information can be found in documents on n-hexane (i.e., ATSDR 1999).

Agency Contacts (Chemical Managers): Nickolette Roney