# 8 REFERENCES

* Cited in text

*ACGIH. 1994. Documentation of threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Adams WG. 1975. Long-term effects on the health of men engaged in the manufacture of toluene diisocyanate. Br J Ind Med 32(1):72–78.164881
*Akbar-Khanzadeh F, Rivas RD. 1996. Exposure to isocyanates and organic solvents, and pulmonary-function changes in workers in a polyurethane molding process. JOEM 38(12): 1205–1212.8978511
*Alexandersson R, Hedenstierna G, Randma E, 1985. Symptoms and lung function in low-exposure to TDI by polyurethane foam manufacturing. Int Arch Occup Environ Health 55(2):149–157.2985507
*Alexandersson R, Hedenstierna G, Plato N, 1987. Exposure, lung function, and symptoms in car painters exposed to hexamethylene diisocyanate and biuret modified hexamethylendiisocyanate. Arch Environ Health 42(6):367–373.3439815
*Andersen M, Binderup ML, Kiel P, 1980. Mutagenic action of isocyanates used in the production of polyurethanes. Stand J Work Environ Health 6(3):221–226.
*Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87: 185–205.3824380
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. Current concepts and approaches on animal test alternatives. Salem H., ed. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andersson K, Gudehn A, Hallgren C, 1983. Monitoring 1,6-hexamethylene diisocyanate in air by chemosorption sampling. Stand J Work Environ Health 9(6):497–503.
*ASTER. 1995. Assessment Tools for the Evaluation of Risk ecotoxicity profile: On hexane 1,6-diisocyanate. U.S. Environmental Protection Agency, Environmental Research Laboratory, Duluth, MN. February 17, 1995.
*Atkinson R. 1988. Estimation of gas-phase hydroxyl radical rate constants for organic chemicals. Environ Toxicol Chem 7:435–442.
*Atkinson RJ. 1987. The structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Inter Chem Kinet 19:799–828.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Axford AT, McKerrow CB, Jones AP, 1976. Accidental exposure to isocyauate fumes in a group of firemen. Br J Ind Med 33:65–71.179561
*Bagon DA, Warwick CJ, Brown RH. 1984. Evaluation Of Total Isocyanate-In-Air Method Using. Am Ind Hyg Assoc J 45(1):39–43.6702596
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Bascom R, Kennedy TP, Levitz D, 1985. Specific bronchoalveolar lavage IgG antibody in hypersensitivity pneumonitis from diphenylmethane diisocyanate. Am Rev Respir Dis 131(3):463–465.3977184
*Bauer X, Dewair M, Fruhmamr G. 1984. Detection of immunologically sensitized isocyanate workers by RAST and intracutaneous skin tests. J Allergy Clin Immuuol 73(5 Pt 1):610–618.
*Beard RR, Noe JT. 1981. Aliphatic and alicyclic amiues. In: Patty’s Industrial Hygiene and Toxicology. Third Edition, Vol 28. 3144, 3149, 3150.
*Belin L, Hjortsberg Ulf, Wass U. 1981. Life threatening pulmonary reaction to car paint containing a prepolymerized isocyanate. Stand J Work Environ Health 7:310–311.
*Berode M, Testa B, Savolainen H. 1991. Bicarbonate-catalyzed hydrolysis of hexamethylene diisocyanate to. Toxicol Lett 56(1–2):173–178.2017775
*Bidleman TE. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22: 361–367.
*Boeniger MF. 1991. Air concentrations of TDI and total reactive isocyanate group in three flexible polyurethane manufacturing facilities. Applied Occupational and Environmental Hygiene 6(10):53–63.
*Bridie AL, Wolff CJ M, Winter M. 1979. BOD and COD of some petrochemicals. Water Res 13:627–630.
“Brochhagen FK, Grieveson BM. 1984. Environmental aspects of isocyanates in water and soil. Cellular Polymers 3:11–17.
*Brorson T, Skarping G, Sandstrom JF, 1990a. Biological monitoring of isocyanates and related amines. I. Determination of 1,6-hexamethylene diamine (HDA) iu hydrolysed human urine after oral administration of HDA. Int Arch Occup Environ Health 62:79–84.2295527
*Brorson T, Skarpiug G, Nielsen J. 1990b. Biological monitoring of isocyanates and related amines. II. Test chamber exposure of humans to 1,6-hexamethylene diisocyanate (HDI). Int Arch Occup Environ Health 62(5):385–389.2228259
*Brorson T, Skarping G, Remnan L, 1989. Test atmospheres of diisocyanates with special reference to controlled exposure of humans. Int Arch Occup Environ Health 61(8):495–501.2553615
*Brown WE, Green AH, Karol MH, 1982. Inhibition of cholinesterase activity by Isocyanates. Toxicol Appl Pharmacol 63:45–52.6280343
*Brown WE, Shamoo AY, Hill BL, 1984. Immobilized cholinesterase to detect airborne concentrations of hexamethylene diisocyanate (HDI). Toxicol Appl Pharmacol 73(1):105–109.6710507
*Butcher BT, Mapp CE, Fabbri LM. 1993. Polyisocyanates and Their Prepolymers. In: Bernstein IL, Chan-Yeung M, Malo JL, , eds. Asthma in the Workplace. Marcel Dekker, Inc. New York, NY. 415–437.
*CAA. 1990. Clean Air Act amendments, Title 3, Section 112(b). List of hazardous air pollutants.
*CCOHS. 1998. Canadian Centre for Occupational Health and Safety. ChemInfo database.
*Chadwick DH, Cleveland TH. 1981. Kirk-Othmer Encyclopedia of Chemistry and Technology, 3rd ed. John Wiley and Sons, New York, NY. 13:789–818.
*Cibulas W Jr., Brooks SM, Murlas CG, 1988. Toluene diisocyanate-induced airway hyperreactivity in guinea pigs depleted of granulocytes. J Appl Physiol 64(5):1773–1778.2839448
*Clewell HJ III, Andersen M. 1985. Risk assessment extrapolations using physiologically-based pharmacokinetic modeling. Toxicol Ind Health 1:111– 131.3843496
*CMA Personal Communication. 1997. Chemical Manufactures Association Hexamethylene Diisocyanate panel comments on Draft ATSDR HDI Profile.
*Cockcroft SW, Mink JY. 1979. Isocyanate-induced asthma in an automobile spray painter. J Can Med Assoc 121:602–604.
*Codd LW, Dijkhoff K, Fearson JH. 1972. Chemical technology and encyclopedia treatment. Barnes & Noble 4:542–544.
*Corbini G, Corti P, Dreassi E, 1991. Determination of diisocyanate monomers in air by differential-pulse polarography. Analyst 116(7):731–734.
*Corley RA, Medrala AL, Smith FA, 1990. Development of a physiologically based pharmacokinetic model for chloroform. Tox Appl Pharmacol 103:512–527.
*Cvitanovic S, Zekan LJ, Marusic M. 1989. Occurrence and specificity of IgE antibodies to isocyanates in occupationally exposed workers. Int Arch Occup Environ Health 61(7):483–486.2777392
*Dahl AR, Hadley WM. 1991. Nasal cavity enzymes involved in xenobiotic metabolism: Effects on the toxicity of inhalants. Crit Rev Toxicol 21(5):345–372.1741949
*Dahl AR, Lewis JL. 1993. Respiratory tract uptake of inhalants and metabolism of xenobiotics. Ann Rev Pharmacol Toxicol 33:383–407.8494345
*Dahl AR, Schlesinger RB, Heck HD, 1991. Comparative dosimetry of inhaled materials: Difference among animal species and extrapolation to man. Fund Appl Toxicol 16(1):1–13.
*Dahl AR, Snipes MB, Gerde P. 1991. Sites for uptake of inhaled vapors in beagle dogs. Toxicol Appl Pharmacol 109(2):276–288.2068727
*Dalene M, Skarping G, Brorson T. 1990. Chromatographic determination of amines in biological fluids with special reference to the biological monitoring of isocyanates and amines. IV. Determination of 1,6-Hexamethylenediamine in human urine using capillary gas chromatography. J Chromatogr 516(2):405–413.2079495
*Dalene M, Skarping G, Tinnerberg H. 1994a. Biological monitoring of hexamethylene diisocyanate by determination of 1,6-hexamethylene diamine as the trifluorethyl chlorformate derivative using capillary gas chromatography with thermoionic and selective-ion monitoring. J Chromatogr B Biomed Appl 656(2):319–328.7987483
*Dalene M, Skarping G, Tinnerberg H. 1994b. Thermospray mass spectrometry of aliphatic diamines derivatized with trifluoroethyl chloroformate, with special reference to the biological monitoring of hexamethylenediisocyanate (HDI) and isophoronediisocyanate (IPDI). Chromatographia 38(11–12):776–780.
*Daniels WJ, Singal M, Donohue M. 1985. Health Hazard Evaluation Report No. HETA-84–2 13–39 1– 16 19, Duluth Community Action Program, Duluth, Minnesota. Hazard Evaluations and Technical Assistance Branch, National Institute of Occupational Safety and Health, U.S. Department of Health and Human Services.
*Dasheill OL, Kennedy GL. 1984. The effects of fasting on the acute oral toxicity of nine chemicals in the rat. J Appl Toxicol (4):320–325.6520321
*Dewair M, Baur X, Mauermayer R. 1983. Inhibition of acetylcholinesterase by diisocyanates and its spontaneous reactivation. Int Arch Occup Environ Health 52:257–261.6313528
*DeWilde A, Hathaway JA. 1994. Follow-up evaluation of pulmonary function of tolonates workers at Freeport, Texas Plant.
*Dharmarajan V. 1978. Occupational Exposures to Methylene Bisphenylisocyanate (MDI): Gaseous or Aerosol? J Environ Path01 Toxicol 2:1–8.
*Dharmarajan V, Rando RJ. 1980. Dynamic calibration of a continuous organo-isocyanate monitor for hexamethylene diisocyanate. Am Ind Hyg Assoc J 41(6):437–441.6249110
*Dharmarajan V, Weil H, Self CW. 1978. Environmental characterization of toluene diisocyanate (TDI) in a manufacturing plant. J Am Ind Hyg Assoc 39:414–418.
*Diem JE, Jones RN, Hendrick DJ, 1982. 5 Year longitudinal study of workers employed in a new toluene diisocyanate manufacturing plant. Am Rev Respir Dis 126(3):420–428.6289703
Diller WF, NieBen J, Klebert W. 1985. Spirometric field study of workers at a 1,6-Hexamethylene Diisocyanate manufacturing plant. Zbl Arbeitsmed 35:85–87.
*DOT. 1976. Hazardous materials and special provisions. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101.
*DOW Chemical. 1964. Study in rats methyl isocyanate and hexamethylene diisocyanate. International Research Development Corporation. EPA/OTS #86-870002225.
*Duff PB. 1983. The fate of TDI in the environment. In: Polyurethane-New Paths to Progress Marketing Technology. Proceedings of the SPI 6th International Tech/Market Conference. 408–412.
Duff PB. 1985. Fate of toluene diisocyanate in air. Phase II study. In: Proceedings of the SPI 6th International Tech/Market Conference. 29:9–14.
*Duncan B, Scheel LD, Fairchild EJ, 1962. Toluene diisocyanate inhalation toxicity: pathology and mortality. Am Ind Hyg Assoc J 23:447–456.
*Dunlap KL, Sandridge RL, Keller J. 1976. Determination of isocyanates in working atmospheres by high speed liquid chromatography. Analytical Chemistry 48(3):497–499.
*E. I. DuPont de Nemours. 1977a. Special primary skin irritation and sensitization on guinea pigs. EPA/OTS dot #86-870001005.
*E. I. DuPont de Nemours. 1977b. Primary skin irritation and sensitization testing on guinea pigs. EPA/OTS dot #86-870001118.
*E.I. DuPont de Nemours. 1978. Mouse sensory irritation study. EPA/OTS dot #86-870001046.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
*Ellwood PA, Hardy HL, Walker RF. 1981. Aliphatic and aromatic isocyanates and their oligomers were determined in air by high-performance thin-layer chromatography. Analyst(London) 106(1258):85–93.
*EPA. 1989. Protection of environment. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR. 268.42.
*EPA. 1990. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/S-90/066A.
*EPA. 1994a. Addition of certain chemicals; toxic chemical release reporting; community right-to-know. U. S. Environmental Protection Agency. 59 Federal Register 1788. Code of Federal Regulations. 40 CFR. 372.65.
*EPA. 1994b. Methods for derivation of inhalation reference concentrations and applications of inhalation dosimetry. U.S. Environmental Protection Agency, Office of Research and Development. Washington D.C. EPA/600/8–90/066F.
*EPA. 1995. Office of Pollution prevention and toxics, U. S. Environmental Protection Agency. EPA 745-k-95–05 1.
*EPA. 1995a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63, Subpart JJ. National Emission Standards for wood furniture manufacturing operations.
*EPA. 1995b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. List of Hazardous Substance and Reportable Quantities. Federal Register 60 FR 30926. Final Rule.
*EPA. 1997. Testing Consent order for 1,6,-Hexamethylene Diisocyanate (HDI). U. S. Environmental Protection Agency. Notice of Consent Agreement. 62 FR 5 1107.
“FEDRIP. 1997. Federal Research In Progress. Dialog Information Service, Inc.
*Ferguson JS, Schaper M, Alarie Y. 1987. Pulmonary Effects of a Polyisocyanate Aerosol: Hexamethylene Diisocyanate Trimer (HDlt) or Desmodur-N (DES-N). Toxicol Appl Pharmacol 89(3):332–346.3603565
*Foureman GL, Greenberg MM, Sangha GK, 1994. Evaluation of nasal tract lesions in derivation of the inhalation reference concentration for hexamethylene diisocyanate. Inhalation Toxicology 6:341–355.
*Gerde P, Dahl AR. 1991. A model for the uptake of inhaled vapors in the nose of the dog during cyclic breathing. Toxicol Appl Pharmacol. 109(2):276–288.2068727
*Gilbert DS. 1988. Fate of TDI and MDI in air, soil, and water. J Cellular Plastics 24:178–192.
*Goldberg PA, Walker RF, Ellwood PA, 1981. Determination of trace atmospheric isocyanate concentrations by reversed-phase high-performance liquid chromatography using. J Chromatogr 212(1):93–104.
*Gordon T, Thompson JE, Sheppard D. 1988. Arachidonic acid metabolites do not mediate toluene diisocyanate-induced airway hyperresponsiveness in guinea pigs. Prostaglandins 35(5):699–706.2840688
*Graham JD. 1980. Simplified sample handling procedure for monitoring industrial isocyanates in air. J Chromatogr Sci 18(8):384–387.
*Grammer LC, Eggum P, Silverstein M, 1988. Prospective immunologic and clinical study of a population exposed to hexamethylene diisocyanate. J Allergy Clin Immunol 82(4):627–633.3171003
*Grammer LC, Harris KE, Malo JL, 1990. The use of an immunoassay index for antibodies against isocyanate human protein conjugates and application to human isocyanate disease. J Allergy Clin Immunol 86(1)94–98.2164544
*Gudehn A. 1984. Improved chromatographic procedure for determination of 9-n methylaminomethylanthracene isocyanate derivatives by high-performance liquid chromatography. J Chromatogr 301(2):481–484.6501502
*Hagmar L, Stromberg U, Welinder H, 1993. Incidence of cancer and exposure to toluene diisocyanate and methylene diphenyldiisocyanate: a cohort based case-referent study in the polyurethane foam manufacturing industry. Br J Ind Med 50( 11): 1003– 1007.8280625
*Hagmar L, Welinder H, Mikoczy Z. 1993. Cancer incidence and mortality in the Swedish polyurethane foam manufacturing industry. Br J Ind Med 50(6):537–543.8392362
*Hakes DC, Johnson GD, Marhevka JS. 1986. An improved high pressure liquid chromatographic method for the determination of isocyanates using nitro reagent. Am Ind Hyg Assoc J 47(3):181–184.3706145
*Harris JC. 1990. Rate of hydrolysis. In: Lyman WJ, Rheehl WF, Rosenblatt DH, eds. Handbook of Chemical Property Estimation Methods. American Chemical Society, Washington, DC. 74.
*Haschek WM, Wits&i HR. 1991. Respiratory System. In: Haschek WM, Rousseaux CG, eds. Handbook of Toxicologic Pathology. Harcourt Brace Jovanovich, Publishers. San Diego, New York, Boston, London, Sydney, Tokyo, Toronto, Academic Press. 761–771.
*Haskell Laboratory. 1946. Summary of acute toxicity studies on diisocyanates. EPA/OTS Dot #86-870000995.
*Haskell Laboratory. 1961. Evaluation of the toxicity of hexamethylene diisocyanate relative to that of toluene-2,4-diisocyanate. EPA/OTS Dot #86-870001008.
*HazDat. 1997. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Holdren W, Spicer CW, Riggin RM. 1984. Gas phase reaction of toluene diisocyanate with water vapor. Am Ind Hyg Assoc J 45:626–633.
*Howard PH. 1993. Handbook of Environmental Fate and Exposure Data for Organic Chemicals. Lewis Publishers, Inc., Chelsea, MI. 48–52,280–287.
*Howard PH, Boethling RS, Jarvis WM, 1991. Handbook of Environmental Degradation Rates. Lewis Publishers, Inc., Chelsea, MI. 430–431.
*HSDB. 1995. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Program (via TOXNET), Bethesda, MD. January 26, 1995.
*Huang J, Wang XP, Chen BM, 1991a. Immunological effects of toluene diisocyanate exposure on painters. Arch Environ Contam Toxicol 21(4):607–611.1662030
*Huang J, Wang XI’, Ueda A, 1991b. Allergologic evaluation for workers exposed to toluene diisocyanate. Ind Health 29(3):85–92.1662672
*Hulse PM. 1984. An evaluation of HDI in polyurethane spray paint aerosols. NTIS# AD-Al51 606.
*Huynh CK, Vu-Due T, Savolainen H. 1992. Design and evaluation of a solid sampler for the monitoring of airborne two-component spray painting. Am Ind Hyg Assoc J 53(3):157–162.1642167
*International Isocyanate Institute. 1981. Accumulation and toxicity of isocyanates and theirwater reaction products in fish with attachments and cover letter. EPA/OTS dot #86-870000616.
*International Isocyanate Institute. 1983. Biodegradability and toxicity bioassays of isocyanates and amines. EPA/OTS dot #86-87000652.
*International Isocyanates Institute. 1987a. Isocyanate inhalation tests - diisocyanate induced asthma. EPA/OTS dot #86-870000661.
*International Isocyanate Institute. 1987b. Reactions of OH radicals with toluene diisocyanate, toluene diamine, and methylene dianiline under simulated atmosphere. EPA/OTS dot #86-870000666.
*International Isocyanate Institute. 1990. Biodegradation of toluene diisocyanate and diphenyl methane diisocyanate. EPA/OTS dot #86-870000646.
*IRIS. 1997. Integrated Risk Information System (IRIS) risk estimate for 1,6-hexamethylene diisocyanate. Environmental Protection Agency, Office of Health and Environmental Assessment. Cincinnati, OH.
*Janko M, McCarthy K, Fajer M, 1992. Occupational exposure to 1,6-hexamethylene diisocyanate-based polyisocyanates in the state of Oregon, 1980–1990. Am Ind Hyg Assoc J 53(5):331–338.1609744
*Jones RN, Rando RJ, Glindmeyer HW, 1992. Abnormal lung function in polyurethane foam producers. Weak relationship to toluene diisocyanate exposures. Am Rev Respir Dis 146(4):871–877.1329591
*Karol MH. 1981. Survey of industrial workers for antibodies to toluene di-isocyanate. J Occup Med 23(11):741–747.6275057
*Karol MH. 1986. Respiratory effects of inhaled isocyanates. Crit Rev Toxicol 16(4):349–379.3519088
*Karol MH, Hansen GA, Brown WE. 1984. Effects of inhaled hexamethylene diisocyanate (HDI) on guinea pig cholinesterases. Fund Appl Toxicol 4(2 Pt 1):284–287.
*Karol MH, Hauth BA. 1982. Use of hexyl isocyanate antigen to detect antibodies to hexamethylene diisocyanate (HDI) in sensitized guinea pigs and in a sensitized worker. Fund Appl Toxicol 2(3):108-l 13.
*Karol MH, Hauth BA, Riley EJ, 1981. Dermal contact with toluene diisocyanate (TDI) produces respiratory tract hypersensitivity in guinea pigs. Toxicol Appl Pharmacol 58(2):221–230.6264649
*Karol MH, Kramarik JA. 1996. Phenyl isocyanate is a potent chemical sensitizer. Toxicology Letters 89: 139–146.8960156
*Kawazoe Y, Kato MZ, Takahashi K. 1981. Studies on chemical carcinogens. XX. Inhibitory effect of alkyl isocyanates and isothicyanates on mutagenesis in E. coli by ultraviolet radiation. Chem Pharm Bull 29:2631–2638.
*Kazuyuki 0, Higashi T, Nakadate T, 1992. Four year follow-up of effects toluene diisocyanate exposure on the respiratory system in polyurethane foam manufacturing worker. Int Arch Occup Environ Health 63:565–569.1316880
*Keller J, Sandridge RL. 1979. Sampling of isocyanates in air. Anal Chem 5 l(11): 1868–1870.
*Kennedy AL, Brown WE. 1992. Isocyanates and lung disease experimental approaches to molecular mechanisms. Occupational Medicine: State of the Art Reviews 7(2):301–329.
*Kennedy GL Jr., Graepel GJ. 1991. Acute toxicity in the rat following either oral or inhalation exposure. Toxicol Lett (Amsterdam) 56(3):317–326.
*Key-Schwartz R. 1992. Analytical problems in the determination of 1,6-hexamethylene diisocyanate using NIOSH Method 5521. Appl Occup Environ Hyg 7(10):643–644.
*Key-Schwartz RJ. 1995. Analytical problems encountered with NIOSH method 5521 for total isocyanates. Amer Ind Hyg Assoc J 56(5):474–479.7754977
*Kimmerle G, Bayer AG. 1976. Acute inhalation toxicity of diisocyanates polymer isocyanates and coating systems on rats. Institute for Toxicology Report No. 6200.
*Kormos LH, Sandridge RL, Keller J. 1981. Determination of isocyanates in air by liquid chromatography with fluorescence detection. Anal them 53(7):1122–1125.
*Koschier FJ, Burden EJ, Brunkhorst CS, 1983. Concentration dependent elicitation of dermal sensitization in guinea-pigs treated with 2,4-toluene diisocyanate. Toxicol Appl Pharmacol 67(3):401–407.6302947
*Krishnan K, Andersen M. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Wallace Hayes, ed. Principles and methods of toxicology. 3rd edition, Raven Press, Ltd. New York, NY.
*Krishnan K, Andersen M, Clewell HJ II I, 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RS A, ed. Toxicology of chemical mixtures, Academic Press, New York, NY.
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. General and applied toxicology. Vol. I. Ballantine B, Marro T, Turner T, eds. Stockton Press, New York, NY. 153–164.
*Levine SP, Hoggatt JH, Chladek E, 1979. Determination of aliphatic isocyanates iu air by a liquid chromatographic-fluorescence technique. Anal Chem 5 l(8): 1106-l 109.
*Lewis JL, Rhoades CE, Bite DE, 1992. Interspecies comparison of cellular localization of the cyanide metabolizing enzyme rhodanese within olfactory mucosa. Anat Ret 232(4):620–627.
*Lewis RJ. 1992. Sax’s dangerous properties of industrial materials. Eight edition. Vol II. Van Nostrand Reinhold.
*Lewis RJ Sr. 1993. Hawley’s Chemical Dictionary. 12th ed., Van Nostrand Reinhold Co., New York, NY. 489.
*Luckenbach M, Kielar R. 1980. Toxic comeal epithelial edema from exposure to high atmospheric concentration of toluene diisocyanates. Am J Ophthahnol 90(5):682–686.
*Maitre A, Berode M, Perdrix A, 1993. Biological monitoring of occupational exposure to toluene diisocyanate. Int Arch Occup Environ Health 65(2):97–100.8253517
*Main-e A, Leplay A, Perdrix A, 1996. Comparison between solid sampler impinger for evaluation of occupational exposure to 1,6-hexamethylene diisocyanate polyisocyanates during spray painting. Am Indust Hygiene Assoc J 57:153–160
*Malo JL, Ouimet G, Cartier A, 1983. Combined alveolitis and asthma due to hexamethylene diisocyanate, with demonstration of crossed respiratory and immunologic reactivities to diphenylmethane diisocyanate. J Allergy Clin Immunol 72(4):413–419.6619454
*Manno M, Lotti M. 1976. Cholinesterases in human toluene diisocyanate exposure. Int Arch Occup Environ Health 38(1):55–60.185156
*Mazur G, Pethran A. 1993. Detection of specific IgE in isocyanate and phthalic anhydride exposed workers: comparison of RAST RIA, Immuno CAP System FEIA, and Magic Lite SQ. Allergy 48(8):627–630.8116862
*Mobay Corporation. 1966. Toxicological investigation of Mondur HX- Monsanto sample number 128. Hexamethylene diisocyanate. EPA/OTS dot #86-870001292. (microfiche)
*Mobay Corporation. 1980. Aqueous surfactant solutions for treatment of isocyanate spills. EPA/OTS dot #86-870001235. (microfiche)
*Mobay Corporation. 1981a. The evaluation of hexamethylene-1,6-diisocyanate for mucous membrane irritation in rabbits with cover letter dated 07/29/87. Epa./ots dot #86-87000 1243.
*Mobay Corporation. 1981b. The evaluation of hexamethylene- 1,6-diisocyanate for primary skin irritation in rabbits. EPA/OTS dot #86-870001242.
*Mobay Corporation. 1981c. Comparison of some mono- and diisocyanates as sensory irritants. Toxicol Appl Pharmacol 57:241–246.7222041
*Mobay Corporation. 1982. Sensory irritation study with HDI in rats with cover letter dated 07/29/87. EPA/OTS Dot #86-870001268. (microfiche)
*Mobay Corporation. 1984. 2 1 -Day inhalation toxicity study with hexamethylene diisocyanate (HDI) in rats. EPA/OTS dot #86-870001230. (microfiche)
*Mobay Corporation. 1986. Sampling for hexamethylene diisocyanate and methyl ethyl ketoxime in curing oven exhaust. EPA/OTS dot #86-870001276. (microfiche)
*Mobay Corporation. 1988. 90-day inhalation toxicity study with 1,6-hexamethylene diisocyanate in rats with attached appendices and cover letter. EPA/OTS Doc# 86-890000080. (microfiche)
*Mobay Corporation. 1989. Chronic inhalation toxicity and oncogenicity study with attached appendices and cover letter. EPA/OTS doc#86-900000055. (microfiche)
*Moos GE, Mcquire JA, Kitchlew WA, 197 1. Inhibition of growth of erhlich asciteS tumors in ICR-Ha Swiss mice by isocyanates. Cancer Res 3 1:937–941.
*Morel CM, Gendre M, Cavigneax A, 1981. 1,6-hexamethylene diisocyanate. Hazard Summary. Cahiers de Notes Documentaires 105:633–636.
*Musk AW, Peters JM, Diberardinis L, 1982. Absence of respiratory effects in subjects exposed to low concentrations of toluene diisocyanate and diphenylmethyldiisocyanate. J Occup Med 24(10):746–750.6292385
*Musk AW, Peters JM, Wegman DH, 1988. Isocyanates and respiratory disease. Am J Ind Med 13(3):331–349.3281455
*Myer HE, O’Block ST, Dharmarajan V. 1993. A survey of airborne HDI, HDI-based polyisocyanate and solvent concentrations in the manufacture and application of polyurethane coatings. Am Ind Hyg Assoc Journal 54(11):663–670.8256690
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press.
*NATICH. 1992. National Air Toxics Inventory Clearinghouse data base report of federal, state, and local air toxics activities. Environmental Protection Agency.
*National Paint and Coastings Association. 1993. Paint Industry Labeling Guide. 4th ed. Washington DC: National Paint and Coatings Association, Inc.
*Nickula KJ, Sun JD, Barr EB, 1993. Thirteen-week, repeated inhalation exposure of F344/N rats and B6C3F_1_ Mice to Ferrocene. Fund Appl Toxicol 21(2):127–139.
*Nielsen J, Sango C, Winroth G, 1985. Systemic reactions associated with polyisocyanate exposure. Stand J Work Environ Health 11:5 l-54.
*NIOSH. 1978. Criteria for a recommended standard. Occupation exposure to diisocyanates. U. S. Department of Health, Education, and Welfare. Public Health Service. Center for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1984. Manual of Analytical Methods. U. S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Physical Sciences and Engineering, Cincinnati, OH.
*NIOSH. 1989. National Occupational Exposure Survey. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1997. Pocket Guide to Chemical Hazards. National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention, U. S. Department of Health and Human Services, DHHS (NIOSH) Publication No. 97–140, page 160.
*NIOSH. 1994. NIOSH Manual of Analytical Methods. U. S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health.
*NTP. 1986. Toxicology and carcinogenesis studies of commercial grade 2,4 (80%)- and 2,6 (20%)-toluene diisocyanate (cas no. 26471-62-5) in F344/n rats and B6C3F_1_ mice (gavage studies). National Toxicology Program Technical Report Series No. 251. U.S. Department of Health and Human Services, National Institutes of Health.
*Nuorteva P, Assmuth T, Haahtela T, 1987. The prevalence of asthma among inhabitants in the vicinity of polyurethane factory in Finland. Environ Res 43(2):308–3 16.3038509
*Olsen GW, Shellenberger R, Bodner KM, 1989. An epidemiologic investigation of forced expiratory volume at 1 second and respiratory symptoms among employees of a toluene diisocyanate production plant. J Occup Med 3 1 (8):664–667.
*Omae K. 1984. Two-year observation of pulmonary function in workers exposed to low concentrations of toluene diisocyanate. Int Arch Occup Environ Health 55( 1): 1–12.6098561
Omae K, Higachi T, Nakadale T, 1992. Four year follow up of effects of toluene diisocyanate exposure on the respiratory system in polyurethane foam manufacturing workers. II. Four year changes in the effects on the respiratory system. Int Arch Occup Environ Health 63:565–569.1316880
*OSHA. 1990. 2,butoxethanol(butyl cellosolve) 2, butoxethyl acetate (butyl cellosolve acetate). Method 83. Organic Methods Evaluation Branch. OSHA Analytical Laboratory, Salt Lake City, Utah.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Parmeggiani L. 1983. Encyclopedia of Occupational Health and Safety. 3rd ed. Geneva, Switzerland: International Labour Office. 116 l- 1162.
*Patterson R, Nugent KM, Harris KE, 1990. Immunologic hemorrhagic pneumonia caused by isocyanates. Am Rev Resp Dis 141(1):226–230.2153356
*Peel M, Marczynski B, Baur X. 1997. Comparison of the binding potential of various diisocyantes on DNA in vitro. J Toxicol Environ Health 52:517–526.9397183
*Persson P, Dalene M, Skarping G, 1993. Biological monitoring of occupational exposure to toluene diisocyanate: measurement of toluenediamine in hydrolysed urine and plasma by gas chromatography-mass spectrometry. Br J Ind Med 50( 12): 111 l- 1118.
*Peters JM, Wegman DH. 1975. Epidemiology of toluene diisocyanate (TDI)-induced respiratory disease. Environ Health Perspect 11:97– 100.170078
*Plunkett ER. 1987. Isocyanates. In: Handbook of Industrial Toxicology. Third Edition. Chemical Publishing Co., Inc. 3 11.
*Potts AM, Rouse EF, Eiferman RA, 1986. An unusual type of keratopathy observed in polyurethane workers and its reproduction in experimental animals. Am J Ind Med 9(2):203–2 13.3963001
*Purnell CJ, Walker RF. 1985. Methods for the determination of atmospheric organic isocyanates. A review. Analyst 110(8):893–905.2998224
*Rando RJ, Abdel-Kader H, Hughes J, 1987. Toluene diisocyanate exposures in the flexible polyurethane foam industry. Am Ind Hyg Assoc J 48(6):580–585.3039821
*Reuzel PG J, Arts JH E, Lomax LG, 1994. Chronic inhalation toxicity and carcinogenicity study of respirable polymeric methylene diphenyl diisocyanate (polymeric MDI) aerosol in rats. Fund Appl Toxicol 22(2):195–210.
*Reuzel PG J, Kuper CF, Feron VJ, 1994. Acute, subacute, and subchronic inhalation toxicity studies of respirable polymeric methylene dipheyl diisocyanate (polymeric MDI) aerosol in rats. Fund Appl Toxicol 22(2):186–194.
*Rosenberg C. 1984. Direct determination of isocyanates and amines as degradation products in the industrial production of polyurethane-coated wire. Analyst 109:859–866.
*Rosenberg C, Savolainen H. 1985. Detection of urinary amine metabolites in toluene diisocyanate exposed rats. J Chromatogr 323(2):429–433.2987281
*Rosenberg C, Savolainen H. 1986. Determination in urine of diisocyanate-derived amines from occupational exposure by gas chromatography-mass. Analyst 3:169–173.
*Rosenberg C, Tuomi T. 1984. Airborne isocyanates in polyurethane spray painting: Determination and respiratory efficiency. Am Ind Hyg Assoc J 45(2):117–121.6702605
*RTECS. 1998. Registry of Toxic Effects of Chemical Substances (RTECS). National Institute for Occupational Safety and Health (NIOSH). Computer database online.
*Rudzinski WE, Pin L, Sutcliffe R, 1994. Determination of hexamethylene diisocyanate in spray-painting operations using capillary zone electrophoresis. Anal them 66(10):1664–1666.
*Sangha GK, Matijak M, Alarie Y. 1981. Comparison of some mono-and diisocyanates as sensory irritants. Toxicol Appl Pharmacol 57:241–246.7222041
*Sango C, Zimerson E. 1980. A new reagent for determination of isocyanates in working atmospheres by HPLC Using UV or fluorescence detection. J Liq Chromatogr 3(7):971–990.
*Saunders JH, Frisch KC. 1962. In: Polyurethane chemistry and technology. l-27,63–113, 129–186.
*Schmidt-Nowara WW, Murphy RL H, Atkinson JD. 1973. Lung function after acute toluene di-isocyanate inhalation. Chest 63(6):1039–1040.4711854
*Schmidtke F, Seifert B. 1990. A highly sensitive high-performance liquid chromatographic procedure for the determination of isocyanates in air. Fresenius’ J Anal Chem 336(8):647–654.
*Seguin P, Allard A, Cattier A, 1987. Prevalence of occupational asthma in spray painters exposed to several types of isocyanates, including polymethylene polyphenylisocyanate. J Occup Med 29(4):340–344.3585565
*Sesana G, Nano G, Baj A. 1991. A new tool for sampling airborne isocyanates. Am Ind Hyg Assoc J 52(5):183–186.1659169
*Shepperly D, Hathaway JA. 1991. Evaluation of pulmonary function of HDI exposed workers at Freeport, Texas Plant.
*Simons WW. 1979. The Sadtler handbook of ultraviolet spectra. Sadtler Research Laboratories, Inc.
*Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. Second edition. Noyes Publication.
“Skarping G, Dalene M, Mathiasson L. 1988. Trace analysis of airborne 1,6-hexamethylenediisocyanate and the related aminoisocyanate and diamine by glass capillary gas chromatography. J Chromatogr 435(3):453–468.3356757
*Skarping G, Smith BE F, Dalene M. 1985. Trace analysis of amines and isocyanates using glass capillary gas chromatography and selective detection. V. Direct Determination of isocyanates using nitrogen-selective and electron-capture detection. J Chromatogr 33 1(2):33 l-338.
*Snipes MB, Spoo JW, Brookins LK, 1991. A method for measuring nasal and lung uptake of inhaled vapor. Fund Appl Toxicol 16( 1): 8 l-9 1.
*SRC. 1994a. Syracuse Research Corporation. Henry’s Law Constant Program. Chemical Hazard Assessment Division Environmental Chemistry Center, Syracuse, NY. (HENRYWIN).
*SRC. 1994b. Syracuse Research Corporation. Aqueous Hydrolysis Rate Program. Chemical Hazard Assessment Division Environmental Chemistry Center, Syracuse, NY. (HYDROWIN).
*SRC. 1995a. Syracuse Research Corporation. Atmospheric Oxidation Program. Chemical Hazard Assessment Division Environment Chemistry Center, Syracuse, NY. (AOPWIN).
*SRC. 1995b. Syracuse Research Corporation. Octanol-Water Partition Coefficient Program. Chemical Hazard Assessment Division Environment Chemistry Center, Syracuse, NY. (KOWWIN).
*SRI. 1994. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International.
*SRI. 1996. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International.
*Stadler JC, Karol MH. 1985. Use of dose-response data to compare the skin sensitizing abilities of dicyclohexylmethane-4,4’-diisocyanate and picryl chloride in two animal species. Toxicol Appl Pharmacol 78(3):445–450.4049393
*Subramanyan B, Caller-y PS, Geelhaar LA, 1989. A cyclic imine intermediate in tlie in vitro metabolic conversion of 1,6-diamnohexane to 6-aminohexanoic acid and caprolactam. Xenobiotica 19( 1):33–42.2502880
*Swarm R, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
*Subramanyan B, Callery PS, Geelhaar LA, 1989. A cyclic imine intermediate in the in vitro metabolic conversion of 1,6-diamnohexane to 6-aminohexanoic acid and caprolactam. Xenobiotica 19( 1):33–42.2502880
*Swarm R, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85: 17–28.
*Ted CS, Pesce AJ. 1979. Chemical characterization of isocyanate-protein conjugates. Toxicol Appl Pharmacol 5 1:39–46.
*Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Rheehl WF, Rosenblatt DH, eds. Handbook of Chemical Property Estimation Methods. American Chemical Society, Washington, DC. 7–4.
*Thorne PS, Hillebrand JA, Lewis GR, 1987. Contact sensitivity by diisocyanates potencies and cross-reactivities. Toxicol Appl Pharmacol 87( 1): 155– 165.3798450
*Tortding G, Alexandersson R. 1990. Decreased lung function and exposure to diisocyanates (HDI and HDI-BT) in car repair painters: Observations on reexamination 6 years after initial study. Amer J Ind Med 17:299–3 10.2305810
*Trevisan A, Moro G. 1981. Role of acetylcholinesterase inhibition in toluene diisocyanate induced bronchoconstriction. Int Arch Occup Environ Health 49(2): 129–136.
*TRI94. 1996. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Tse CS T, Pesce AJ. 1979. Chemical characterization of isocyanate-protein conjugates. Toxicol Appl Pharmacol5 1:39–46.
*Medican Tulane. 1982a. Isocyanate induced asthma. Eur J Respir Dis Suppl 123:78–81.6297947
*Tulane Medican. 198213. Twelve month progress report on the studies of toluene diisocyanate induced pulmonary diseases. EPA/OTS Dot #86-870000688
*U. S. Congress. 1990. Clean Air Act Amendments. Title 1. Section 112, 42 USC 7412. National Emission Standards for Hazardous Air Pollutants. Public Law 10 l-549.
*Ulrich H. 1989. Ullmann’s Encyclopedia of Industrial Chemicals. VCH Publishers, New York, NY. 14:61 l-625.
*USITC. 1992. United States International Trade Commission. Synthetic Organic Chemicals. USITC publication 2720.
*Usui Y, Aida H, Kimula Y, 1992. Hypersensitivity pneumonitis induced by hexamethylene diisocyanate. Intern Med 3 1(7):912–916.
*Von Burg R. 1993. Hexamethylene diisocyanate. J Appl Toxicol 13(6):435–439.8288848
*Waggy GT, Conway RA, Hansen JL, 1994. Comparison of 20-d BOD and OECD closed-bottle biodegradation tests. Environ Toxicol Chem 13: 1277– 1280.
*Weast RC. 1988. CRC handbook of chemistry and physics. 69th edition 1988–1989. Boca Raton, FL: CRC Press, Inc.
*Wegman DH, Peters JM, Pagnotto L, 1977. Chronic pulmonary function loss from exposure to toluene diisocyanate. Br J Ind Med 34(3): 196–200.199229
*Weill H, Salvaggio J, Neilson A, 1975. Respiratory effects in toluene diisocyanate manufacture: a multidisciplinary approach. Environ Health Perspect 11: 10 1- 108.
*Welinder H, Nielsen J, Bensryd I, 1988. IgG Antibodies against Polyisocyanates in Car Painters. Clin Allergy 18( 1):85–93.3349596
*Weyel DA, Rodney BS, Alarie Y. 1982. Sensory irritation, pulmonary irritation, and acute lethality of a polymeric isocyanate and sensory irritation of 2,6-toluene diisocyanate. Toxicol Appl Pharmacol 64(3):423–430.6291194
Wiethege TH, Potthast J, Marczynskil, 1995. Studies on the induction of rat liver foci by inhalation exposure to diisocyanate. Pneumologie 49(6):373–377.7644458
*Wu WS, Stoyanoff RE, Szklar RS, 1990. Application of Tryptamine as a derivatising agent for airborne Isocyanate determination. Part 3 evaluation of total isocyanates analysis by high-performance liquid chromatography with fluorescence and amperometric detection. Analyst 115:801–807.2393084