# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of HDI is located in Table 3-1. Most of the HDI manufactured in, or imported into, the United States is converted into HDI prepolymers (polyisocyanates). These prepolymers are biurets and trimers. Information for those prepolymers is shown in Table 3-2.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of HDI is located in Table 3-3. HDI is a monomer used in the production of polyurethane foams and other related products, and is found in some industrial paints and spray painting operations. It is a compound which reacts readily with water and alcohols (Von Burg 1993). It has a vapor pressure of 0.05 mm Hg at room temperature, but can be present in aerosol form allowing a potentially higher exposure to individuals. The HDI-BT trimer is often present for similar industrial uses. It would be expected to have a lower vapor pressure; however, the aerosol form can also be present, allowing potentially higher exposure of HDI-BT to individuals. HDI reacts slowly with water to form carbon dioxide (HSDB 1996). The base-catalyzed reaction of HDI with alcohols should be carried out in inert solvents; the reaction may occur with explosive violence in the absence of solvents (NFPA 1994).

Table 3-1 Chemical Identity of Hexamethylene Diisocyanate

Characteristic | Information | Reference
Chemical name | 1,6-Hexamethylene diisocyanate | HSDB 1996
Synonym(s) | 1,6-Diisocyanatohexane; HDI; HMDI | HSDB 1996
Registered trade name(s) | TL-78; Desmodur H; Mondur HX | HSDB 1996; Bagon et al. 1984; Dunlap 1976
Chemical formula | OCN-(CH_2_)_6_-NCO | HSDB 1996
Chemical structure | [image]
Identification numbers:
CAS Registry | 822-06-0 | Lewis 1993
NIOSH RTECS | M01740000 | HSDB 1996
EPA Hazardous Waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO | UN2281; IMO 6.1 | HSDB 1996
HSDB | 6134 | HSDB 1996
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/lnternational Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Chemical Identity of Hexamethylene Diisocyanate Prepolymers

Characteristic | HDI biuret | HDI trimer
Chemical name | Hexamethylene diisocyanate biuret | Hexamethyene diisocyanate trimer
Synonym(s) | N,N′,2-tris(6-isocyanatohexyl)-imidodicarbonic diamide; HDI-BT | 1,3,5-Tris(6-isocyanatohexyl)-1,3,5-triazine-2,4,6(1H,3H,5H)-trione; HDI isocyanurate
Registered trade name(s) | Desmodur N-75; Desmodur N-100; Desmodur N-3200 | Desmodur N-3300; Desmodur N3390
Chemical formula | C_23_H_38_N_6_O_5_ | C_24_H_36_N_6_O_6_
Chemical structure | [image] | [image]
Identification numbers:
CAS registry | 4035-89-6 | 3779-63-3
NIOSH RTECS | NR0195000 | None
EPA hazardous waste | None | None
OHM/TADS | None | None
DOT/UN/NA/IMCO shipping | None | None
HSDB | None | None
NCI | None | None

CAS = Chemical Abstracts Service; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/lnternational Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

References:

CCOHS 1998

Janko et al. 1992

Maitre et al. 1996

Myer et al. 1993

RTECS 1998

Table 3-3 Physical and Chemical Properties of Hexamethylene Diisocyanate

Property | Information | Reference
Molecular weight | 168.22 | HSDB 1996
Color | Pale yellow | Von Burg 1993
Physical state | Liquid | Lewis 1993
Melting point | −67 °C | ASTER 1995
Boiling point | 255 °C | ASTER 1995
| 212.8 °C at 760 mm Hg | NIOSH 1978
Density at 25 °C | 1.04 g/mL | HSDB 1996
| 1.0528 g/mL | Weast 1988
Odor | Pungent | Von Burg 1993
Odor threshold:
Water | Not applicable, reacts with water | HSDB 1996
Air | 0.001–0.02 ppm | HSDB 1996
Solubility:
Fresh water at 20 °C | Poorly soluble; reacts | NIOSH 1978; Von Burg 1993
Saltwater at 25 °C | No data
Organic solvent(s) | Soluble in organic solvents | NIOSH 1978
| Reacts with alcohols | Von Burg 1993
Partition coefficients:
Log K_ow_ | 3.1956 (estimated) | SRC 1995b
Log K_oc_ | No data
Vapor pressure at 20 °C | 0.014 mbar; 0.05 mm Hg (24 °C) | Morel et al. 1981; NIOSH 1978
Henry’s law constant: at 25 °C | 4.8×10^−5^ atm-m^3^/mole | SRC 1994a
Autoignition temperature | 454 °C | Morel et al. 1981
Flashpoint | 140 °C; 135 °C (open cup) | NIOSH 1978; Morel et al. 1981
Flammability limits at 25 °C | No data
Conversion factors (25 °C) | 1 μg/m^3^ = 0.145 ppb | NIOSH 1978
Conversion factors (25 °C) | 1 ppb = 6.879 μg/m^3^ | NIOSH 1978
Explosive limits | 1–24% | Von Burg 1993