# 8 REFERENCES

*Cited in text

Abrams EF, Derkics D, Fong CV, . 1975. Identification of organic compounds in effluents from industrial sources. Springfield, VA: National Technical Information Service PB-241 641.
*ACGIH. 1991. Documentation of the Threshold Limit Values and Biological Exposure Indices. 6th ed. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*ACGIH. 1993. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1992 to 1993. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: odor thresholds compared with threshold limit values and volatilites for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*APHA. 1992. Standard methods for the examination of water and wastewater. 18th ed. Washington, DC: American Public Health Association, American Water Works Association, Water Environment Federation, 6-77–6-89.
Archer WL. 1979 Other chloroethanes. In: Kirk-Othmer Encyclopedia of chemical technology. 3rd Ed. In: John Wiley & Sons, New York, NY. 5:722–742.
Ardran GM. 1964. Phosgene poisoning. Br Med J February 8:375.
Ashby J, Tennant RW. 1990. Definitive relationships among chemical structure, carcinogenicity and mutagenicity for 301 chemicals tested by the U.S. NTP. Mutat Res 257:229–306.
*Ashley DL, Bonin MA, Cardinali FL. 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Part V. Federal Register 54:37619–37633.
Bakale G, McCreary RD. 1990. Response of the k_e_ test to NCI/NTP-screened chemicals. I. Nongenotoxic carcinogens and genotoxic noncarcinogens. Carcinogenesis 11: 181l–1818.2403858
Baker RWR. 1977. GEL filtration of phthalate esters. In: Elsevier Scientific Publishing Company, Amsterdam.
*Banerjee S, Baughman GL. 1991. Bioconcentration factors and lipid solubility. Environ Sci Technol 25:536–539.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:47l–486.
Barrett JC, Huff J. 1991. Cellular and molecular mechanisms of chemically induced renal carcinogenesis. Renal Failure 13:21l–225.
Bartlet AL. 1976. Actions of carbon tetrachloride, hexachloroethane and the products of their metabolism in sheep onfusciola hepatica. Br J Pharmacol 58:395–400.990593
Baxter RM. 1989. Reductive dehalogenation of environmental contaminants: a critical review. Water Pollution Reseach Journal 24:299–322.
Bonse G, Henschler D. 1976. Chemical reactivity, biotransformation, and toxicity of polychlorinated aliphatic compounds. CRC Critical Reviews in Toxicology 395–409.
*Borghoff SJ. 1993. y2u-Globulin-mediated male rat nephropathy and kidney cancer: relevance to human risk assessment. Chemical Industry Institute of Technology (CIIT) Activities l–8.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company. 10: 143–144.
*Bronzetti G, Morichetti E, Del Carratore R, . 1989. Tetrachloroethane, pentachloroethane, and hexachloroethane: genetic and biochemical studies. Teratogenesis Carcinog Mutagen 9:349–357.2576814
*Brown RF, Marrs TC, Rice P, . 1990. The histopathology of rat lung following exposure to zinc oxidekexachloroethane smoke or instillation with zinc chloride followed by treatment with 70% oxygen. Environ Health Perspect 85:81–87.2384070
*Budavari S, O’Neil MJ, Smith A, ., eds. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck and Co., Inc., 740.
*Callahan MA, Slimak MW, Gael NW, . 1979. Water-related environmental fate of 129 priority pollutants. Vol. II. Report to U.S. Environmental Protection Agency, Office of Water Planning and Standards, Washington, DC, by Versar Incorporated, Springfield VA. NTIS No. PB80-204381.
*Camanzo J, Rice CP, Jude DJ, . 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments, 1983. J Great Lakes Res 13(3):296–309.
*Cataldo DA, Ligotke MW, Bolton H, . 1989. Evaluate and characterize mechanisms controlling transport, fate and effects of army smokes in the aerosol wind tunnel. Pacific Northwest Laboratory ADA - 215 415.
Chopra NM. 1972. Breakdown of chlorinated hydrocarbon pesticides in tobacco smokes: A short review. In: Tahori AS, ed. Fate of pesticides in environment. Vol VI. 245–261.
*Clark CS, Meyer CR, Gartside PS, . 1982. An environmental health survey of drinking water contamination by leachate from a pesticide waste dump in Hardeman County, Tennessee. Arch Environ
*Class TH, Ballschmiter K. 1986. Chemistry of organic traces in air VI: distribution of chlorinated C_1_ – C_4_ hydrocarbons in air over the northern and southern Atlantic ocean. Chemosphere 15:413–427.
Clode SA, Riley RA, Blowers SD, . 1991. Studies on the mutagenicity of a zinc oxide-hexachloroethane smoke. Human & Experimental Toxicology 10:49–57.1673625
*Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56(7)898–908.
*Crebelli R, Benigni R, Franekic J, . 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillue nidulans: unspecific or specific mechanism? Mutat Res 201:401–411.3050490
*Griddle CS, McCarty PL, Elliott MC, . 1986. Reduction of hexachloroethane to tetrachloroethylene in groundwater. Ada, OK: U.S. Environmental Protection Agency, Office of Research and Development. PB86-201324.
*Curtis GP, Roberts PV, Reinhard M. 1986. A natural gradient experiment on solute transport in a sand aquifer 4. sorption of organic solutes and its influence on mobility. Water Resources Research 22:2059–2067.
*Dacre JC, Burrows WD, Wade CWR, . 1979. Problem definition studies on potential environmental pollutants v. physical, chemical toxicological, and biological properties of seven substances used in pyrotechnic compositions. U.S. Army Medical Research and Development Command Technical Report 7704.
Davidson KA, Hovatter PS, Ross RH. 1988. Water quality criteria for hexachloroethane. Draft report, Oak Ridge, TN: Oak Ridge National Laboratory. ORNL-6469.
DeMarini DM, Inmon JP, Simmons JE, . 1987. Mutagenicity in salmonella of hazardous wastes and urine from rats fed these wastes. Mutat Res 189:205–216.3313035
*Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloro methanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
*Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,l ,1 -trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9:833–838.
Dowd RW. 1990. Review of studies concerning effects of well casing materials on trace measurements of organic compounds. In: Friedman D, ed. Waste Testing and Quality Assurance: Second V’olume. 31–42.
Eaton JC, Young JY. 1989. Medical criteria for respiratory protection in smoke: the effectiveness of the military protective mask. Frederick MD: U.S. Army Biomedical Research & Development Laboratory, AD-A204-303.
*Eichelberger JW, Bellar TA, Donnelly JP, . 1990. Determination of volatile organics in drinking water with USEPA method 524.2 and the ion trap detector. J Chromatogr Sci 28:460–467.2273069
*Eichelberger JW, Kerns EH, Olynyk P, . 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1391.
*Ellington JJ, Stancil FE, Payne WD, . 1987. Measurement of hydrolysis rate constants for evaluation of hazardous waste land disposal: Volume 2. Data on 54 chemicals. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory. EPA/600/S3-87/019.
*EPA. 1980a. Ambient water quality criteria for chlorinated ethanes. Washington, DC: U.S. Environmental Protection Agency, Criteria and Standards Division. EPA-440/5-80-029.
*EPA. 1980b. U.S. Environmental Protection Agency. Federal Register 45:33132–33133.
*EPA. 1982. Chlorinated hydrocarbons - method 612. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory l–7.
EPA. 1986a. Gas chromatography/mass spectrometry for semivolatile organics: capillary column technique. Method 8270. Washington, DC: U.S. Environmental Protection Agency l–32.
EPA. 1986b. Gas chromatography/mass spectrometry for semivolatile organics: packed column technique. Method 8250. In: Test methods for evaluating solid waste. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, l–30.
EPA. 1987a. Health effects assessment for hexachloroethane. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development EPA/600/8-88/043.
*EPA. 1987b. U.S. Environmental Protection Agency. Part II. Federal Register 52:25942–25953.
*EPA. 1988a. Recommendations for and documentation of biological values for use in risk assessment. Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment, Office of Research and Development, Cincinnati, OH.
*EPA. 1988b. U.S. Environmental Protection Agency. Part II. Federal Register 53:4500–4507
EPA. 1988c. U.S. Environmental Protection Agency. Part V. Federal Register 53:38642–38654.
*EPA. 1989. U.S. Environmental Protection Agency. Part V. Federal Register 54:33418–33419, 33459.
*EPA. 1990a. Chlorinated hydrocarbons by gas chromatography: capillary column technique. Method 8 121. Washington, DC: U.S. Environmental Protection Agency, l–21.
*EPA. 1990b. Chlorinated hydrocarbons by gas chromatography. Method 8120A. Washington, DC: U.S. Environmental Protection Agency, 1 - 16.
*EPA. 1990c. U.S. Environmental Protection Agency. Method 1625, Revision B. Semivolatile organic compounds by isotope dilution GC/MS. Code of Federal Regulations, 40:516–536.
*EPA. 1990d. U.S. Environmental Protection Agency. Part II. Federal Register 55:22520–22537, 22593, 22712.
*EPA. 1990e. Interim methods for development of inhalation reference doses. Research Triangle Park, NC. U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*EPA. 1991a. Alph_2µ_-globulin: association with chemically induced renal toxicity and neoplasia in the male rat. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA/625/3-91/019F.
*EPA. 1991b. U.S. Environmental Protection Agency. Part II. Federal Register 55:3864–3870,3890, 3910.
*EPA. 1991~. U.S. Environmental Protection Agency. Part III. Federal Register 56:7134–7135,7234.
*EPA. 1992. U.S. Environmental Protection Agency. Part II. Federal Register 57:62608–62619, 62690–62693.
*EPA. 1995. U.S. Environmental Protection Agency. Identification and listing of hazardous waste. CFR 40:261.24.
Erickson MD, Harris III BSH, Pellizzari ED, . Acquisition and chemical analysis of mother’s milk for selected toxic substances. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances, EPA 560/13-80-029.
*Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: criteria for skin notation. Am J Ind Med 17:617–635.2337085
Fishbein L. 1979. Potential halogenated industrial carcinogenic and mutagenic chemicals II. Halogenated saturated hydrocarbons. Sci Total Environ 11: 163–195.373115
*Fowler JS. 1969a. Carbon tetrachloride metabolism in the rabbit. Br J Pharmacol 37:733–737.5348474
*Fowler JS. 1969b. Some hepatotoxic action of hexachloroethane and its metabolites in sheep. Br J Pharmacol 35:530–542.5809742
Fowler JS. 1970. Chlorinated hydrocarbon toxicity in the fowl and duck. J Comp Pathol 80:465–471.5478005
*FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee. Report 7, p. 17.
*Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: evaluations of 108 chemicals. Environ Mol Mutagen 10:1–175.3319609
*Gordon L, Hartley WR, Roberts WC. 1991. Health advisory on hexachloroethane. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
*Gorzinski SJ, Nolan RJ, McCollister SB, . 1985. Subchronic oral toxicity, tissue distribution and clearance of hexachloroethane in the rat. Drug Chem Toxicol 8:155–169.4054010
Gorzinski SJ, Wade CE, McCollister SB, . 1980. Hexachloroethane: results of a 16-week toxicity study in the diet of CDF Fischer 344 rats. Midland, MI: Dow Chemical, Health and Environmental Sciences.
Grant WM. 1974. Hexachloroethane. In: Toxicology of the eye. 2nd Ed. Drugs, Chemicals, Plants, Venoms. Springfield, IL: Thomas CC, publisher.
urbelash AT. 1969. Effect of hexachloroethane on the protein and amino acid composition of the blood in cattle milk. Veterinariia 51–52.
Hanson D. 1993. OSHA won’t appeal toxics exposure ruling. Chemical and Engineering News 5.
*Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1980. Environmental Monitoring and Assessment 2:249–271.24264296
*Haworth S, Lawlor T, Mortelmans, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen Suppl 1:3–142.
*HazDat. 1995. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. March 9, 1993.
Helmes CT, Atkinson DL, Jaffer J, . 1982. Evaluation and classification of the potential carcinogenicity of organic air pollutants. J Environ Sci Health A 17:321–389.
Henry MC, Barkley JJ, Rowlett CD. 1981. Mammalian toxicologic evaluation of hexachloroethane smoke mixture and red phosphorus. Frederick, MD: U.S. Army Medical Bioengineering Research and Development Laboratory. Final Report. ADA109583.
*Ho JS, Tang PH, Eichelberger JW, . 1993. Determination of organic compounds in water by liquid solid extraction followed by supercritical fluid elution and capillary column gas chromatography/mass spectrometry. Denver, CO: American Chemical Society, 313–315.
*Hodge HC, Sterner JH. 1949. Tabulation of toxicity classes. American Industrial Hygiene Association Quarterly 10:93–96.24536943
Houk VS, DeMarini DM. 1988. Use of the microscreen phage-induction assay to assess the genotoxicity of 14 hazardous industrial wastes. Environ Mol Mutagen 11:13–29.2962869
*Howard PH, 1989. Handbook of Environmental Fate and Exposure Data for Organic Chermcals. Vol. I. Large Production and Priority Pollutants. In: Lewis Publishers, New York, NY.
Howard PH, Boethling RS, Jarvis WF, . eds. 1991. Handbook of Environmental Degradation Rates. In: Lewis Publishers, New York, NY.
*HSDB. 1995. Hazardous substances data bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*IARC. 1979. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans: some halogenated hydrocarbons. Vol. 20. International Agency for Research on Cancer, Lyon, France, October, 1979.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Suppl 7. Overall evaluations of carcinogenicity: Updating of IARC monographs volumes l-42. World Health Organization, International Agency for Research on Cancer, Lyon, France, 29–33,64.
*International Joint Commission. 1983. An inventory of chemical substances identified in the Great Lakes Ecosystem. Vol. 1 Summary. December, 1983.
*IRIS. 1995. Integrated Risk Information System. U.S. Environmental Protection Agency, Washington, DC.
*Jondorf WR, Parke DV, Williams RT. 1957. The metabolism of [^14^C]hexachloroethane. In: Proceedings of the Biochemical Society. 14P–15P.
Kaiser JP, Bollag JM. 1990. Microbial activity in the terrestrial subsurface. Experientia 46:797–806.
Kallqvist T, Carlberg GE, Kringstad A. 1989. Ecotoxicological characterization of industrial wastewater - sulfite pulp mill with bleaching. Ecotoxicol Environ Safety 18:321–336.2612424
*Karlsson N, Cassel G, Fangmark I, . 1986. A comparative study of the acute inhalation toxicity of smoke from TiO_2_-hexachloroethane and Zn-hexachloroethane pyrotechnic mixtures. Arch Toxicol 59:160–166.3813883
Karlsson N, Fangmark I, Haggqvist I, . 1991. Mutagenicity testing of condensates of smoke from titanium dioxidekexachloroethane and zinc/hexachloroethane pyrotechnic mixtures. Mutat Res 260:39–46.2027339
*Katz S, Snelson A, Farlow R, . 1980. Physical and chemical characterization of fog oil smoke and hexachloroethane smoke. Chicago, IL: IIT Research Institute.
Keith LH. 1976. Identification of organic compounds in unbleached treated kraft paper mill wastewaters. Environ Sci Technol 10:555–564.
*Keith LH, Garrison AW, Allen FR, . 1976. Identification of organic compounds in drinking water from thirteen U.S. cities. In: Identification and analysis of organic pollutants in water. Keith, LW ed. Ann Arbor, MI: Ann Arbor Science Publishers, Inc.
Kenaga EE. 1983. Predictability of chronic toxicity from acute toxicity of chemicals in fish and aquatic invertebrates. Environ Toxicol Chem 1:347–358.
*Kinkead ER, Wolfe RE. 1992. Single oral toxicity of various organic compounds. J Am Co11 Toxicol 11(6):713.
*Kitchens JF, Harward WE, Lauter DM, . 1978. Preliminary problem definition study of 48 munitions-related chemicals. Vol. III. Pyrotechnic Related Chemicals. Alexandria, VA: Atlantic Research Corporation.
*Kleopfer RD, Fairless BJ. 1972. Characterization of organic components in a municipal water supply. Environ Sci Technol 12:1036–1037.
*Knoevenagel K, Himmelreich R. 1976. Degradation of compounds containing carbon atoms by photooxidation in the presence of water. Arch Environ Contam Toxicol 4:324–333.970984
Knoietzko H. 1984. Chlorinated ethanes: sources, distribution, environmental impact, and health effects. 401–448.
Kraybill HF. 1983. Assessment of human exposure and health risk to environmental contaminants in the atmosphere and water with special reference to cancer. J Environ Sci Health 2: 175–232.
*Kriegman-King MR, Reinhard M. 1991. Reduction of hexachloroethane and carbon tetrachloride at surfaces of biotite, vermiculite, pyrite, marcasite. In: Organic substances and sediments in water, volume 2. Lewis Publishers, Inc. 349–364.
Kroneid R. 1985. Recovery and reproducibility in determination of volatile halocarbons in water and blood. Bull Environ Contam Toxicol 34:486–496.3986386
*Lattanzi G, Colacci A, Grilli S, . 1988. Binding of hexachloroethane to biological macromolecules from rat and mouse organs. J Toxicol Environ Health 24:403–411.2456401
Ligocki MP, Pankow JF. 1985. Assessment of adsorption/solvent extraction with polyurethane foam and adsorption/thermal desorption with Tenax-GC for the collection and analysis of ambient organic vapors. Anal Chem 57:1138–1144.
*Ligocki MP, Leuenberger C, Pankow JF. 1985. Trace organic compounds in rain-II. gas scavenging of neutral organic compounds. Atmos Environ 19:1609–1617.
Loew CH, Rebagliati M, Poulsen M. 1984. Metabolism and relative carcinogenic potency of chloroethanes: a quantum chemical structure-activity study. Cancer Biochem Biophys 7:109–132.6088030
Lopez-Avila V, Baldin E, Benedict0 J, . 1990. Application of open-tubular columns to SW-846 GC methods. Las Vegas, NV: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA/600/S4-90/021.
*Lopez-Avila V, Dodhiwala NS, Beckert WF. 1991. Method for the supercritical fluid extraction of soils/sediments. Las Vegas, NV: U.S. Environmental Protection Agency, Environmental Monitoring Systems Laboratory. EPA/600/S4-90/026.
*Mabey WR, Smith JH, Pod011 RT, . 1982. Aquatic fate process data for organic priority pollutants. Report to U.S. Environmental Protection Agency, Office of Water Regulations and Standards, Washington, DC, by SRI International, Menlo Park, CA. EPA 440/4-81-014.
Mackay D, Leinonen PJ. 1975. Rate of evaporation of low-solubility contaminants from water bodies to atmosphere. Environ Sci Technol 9: 1178–1180.
*Marrs TC, Clifford WE, Colgrave HF. 1983. Pathological changes produced by exposure of rabbits and rats to smokes from mixtures of hexachloroethane and zinc oxide. Toxicol Lett 19:247–252.6658837
Marrs TC, Colgrave I-IF, Edginton JA, . 1988. The repeated dose toxicity of a zinc oxide/hexachloroethane smoke. Arch Toxicol 62: 123–132.3196147
McManus KP. 1982. Health hazard evaluation; Timber Lake Manufacturing, Alton, Hampshire. Cincinnati, OH: National Institute for Occupational Safety and Health, PB84–148402.
Mennear JH, Haseman JK, Sullivan DJ, . 1982. Studies on the carcinogenicity of pentachloroethane in rats and mice. Fund Appl Toxicol 2:82–87.
Mersch-Sundermann V, Muller G, Hofmeister A. 1989. Examination of mutagenicity of organic microcontaminations of the environment. IV. Communication: the mutagenicity of halogenated aliphatic hydrocarbons with SOS-Chromotest. Zentralbl Hyg Umweltmed 266–271.
*Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
Mico BA, Pohl LR. 1983. Reductive oxygenation of carbon tetrachloride: trichloromethylperoxyl radical as a possible intermediate in the conversion of carbon tetrachloride to electrophilic chlorine. Arch Biochem Biophys 225:596–609.6625601
Miller CT, Comalander DR. 1988. Groundwater quality. In: Fate and Effects of Pollutants. J Water Pollut Control Fed 60:961–978.
*Milman HA, Story DL, Riccio ES, . 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann N Y Acad Sci 521–530.
*Mitoma C, Steeger T, Jackson SE, . 1985. Metabolic disposition study of chlorinated hydrocarbons in rats and mice. Drug Chem Toxicol 8:183–194.4054011
*Mrsny RJ, Barles RW, Chin D, . 1978. Use of an internal standard in monitoring the bacterial degradation of crude oil. Appl Environ Microbial 36:776–779.
Munz C, Roberts PV. 1987. Air-water phase equilibria of volatile organic solutes. Research and Technology 62–69.
Mussalo-Rauhamaa H, Pyysalo H, Moilanen R. 1984. Influence of diet and other factors on the levels of organochlorine compounds in human adipose tissue in Finland. J Toxicol Environ Health 13:689–704.6436503
*Nakamura S, Oda Y, Shimada T, . 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: examination with 151 chemicals. Mutat Res 192:239–246.3317033
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
*Nastainczyk W, Ahr H, Uhich V, . 1982a. The mechanism of the reductive dehalogenation of polyhalogenated compounds by microsomal cytochrome P450. 799–808.
*Nastainczyk W, Ahr HJ, Ullrich V. 1982b. The reductive metabolism of halogenated alkanes by liver microsomal cytochrome P450. Biochem Pharmacol 31:391–396.7073766
*NATICH. 1995. National Air Toxics Information Clearinghouse: NATICH database report on state, local and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA-450/3-91-018.
NIOSH. 1978. Current Intelligence Bulletin 27, chloroethanes review of toxicity. Cincinnati, OH: National Institute for Occupational Safety and Health. PB85-119196.
*NIOSH. 1990. National Institute for Occupational Safety and Health. NIOSH pocket guide to chemical hazards. Washington, DC: Department of Health and Human Services, 122–123.
*NIOSH. 1994. Hydrocarbons, halogenated - method 1033. In: NIOSH manual of analytical methods. 4th ed. Vol. 2. Cincinnati, OH: National Institute for Occupational Safety and Health, Centers for Disease Control.
*NOES. 1991. National occupational exposure survey. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*Nolan RJ, Karbowski RJ. 1978. Hexachloroethane: tissue clearance and distribution in Fischer 344 rats. Midland, MI: Dow Chemical Company.
*Novak EW, Lave LB, Strukel JJ, . 1987. A revised health risk assessment for the use of hexachloroethane smoke on an Army training area. Champaign, IL: U.S. Army Construction, USA-CERL TR N-87126.
*NTP. 1977. National Toxicology Program. Bioassay of hexachloroethane for possible carcinogenicity. Bethesda, MD: National Institutes of Health, National Cancer Institute. NIC-CG-TR-68.
*NTP. 1989. National Toxicology Program. Toxicology and carcinogenesis studies of hexachloroethane (CAS No. 67-72-l) in F344/N rats (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services. National Institutes of Health. NTP TR 361. NIH Publication No. 89-2816.
*NTP. 1994. Seventh annual report on carcinogens. Summary 1994. U.S. Department of Health and Human Services, iv–viii, 226–229.
*Oliver BG, Niimi AJ. 1983. Bioconcentration of chlorobenzenes from water by rainbow trout: correlations with partition coefficients and environmental residues. Environ Sci Technol 17:287–291.
*Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
OSHA. 1989. Occupational Safety and Health Administration: Part III. Federal Register 54:2332, 2939.
OSHA. 1992. Occupational Safety and Health Administration: Part II. Federal Register 57:26002,26547, 26564,26581,26595.
*OSHA. 1993. Occupational Safety and Health Administration: Part V. Federal Register 5835338 35340, 35345.
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
*Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
Pankow JR, Isabelle LM, Kristensen TJ. 1982. Tenax-GC cartridge for interfacing capillary column gas chromatography with adsorption/thermal desorption for determination of trace organics. Anal Chem 54:1815–1819.
*Pellizzari ED, Sheldon LS, Bursey JT. 1985a. Method 25. GC/MS determination of volatile halocarbons in blood and tissue. In: Environmental Carcinogens selected methods of analysis. Fishbein L, O’Neill IK, eds. Lyon, France. International Agency for Research on Cancer, 7:435–444.
*Pellizzari ED, Zweidinger RA, Sheldon LS. 1985b. Method 24. GC/MS determination of volatile halocarbons in breath samples. In: Environmental Carcinogens selected methods of analysis. Fishbein L, O’Neill IK, eds. Lyon, France. International Agency for Research on Cancer, 7:413–441.
*Public Law 101-549. 1990. Clean air act amendments of 1990. Environmental Reporter 71:2022–2023.
*Reynolds ES. 1972. Comparison of early injury to liver endoplasmic reticulum by halomethanes, hexachloroethane, benzene, toluene, bromobenzene, ethionine, thioacetamide and dimethylnitrosamine. Biochem Pharmacol 21:2555–2561.4350551
*Richard RJ, Atkins J, Marrs TC, . 1989. The biochemical and pathological changes produced by the intratracheal instillation of certain components of zinc-hexachloroethane smoke. Toxicology 54:79–88.2916244
*Roberts AL, Gschwend PM. 1994. Interaction of abiotic and microbial processes in hexachloroethane reduction in groundwater. Journal of Contaminant Hydrology 16:157–174.
*Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, . 1991. An association between mutagenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6:199–205.1881351
*Salmon AG, Jones RB, Mackrodt WC. 1981. Microsomal dechlorination of chloroethanes: structurereactivity relationships. Xenobiotica 11:723–734.7336754
*Salmon AG, Nash JA, Walkin CM, . 1985. Dechlorination of halocarbons by microsomes and vesicular reconstituted cytochrome P-450 systems under reductive conditions. Br J Ind Med 42:305–311.3986141
*Santodonato J, Bosch S, Meylan W, . 1985. Monograph on human exposure to chemicals in the workplace: hexachloroethane. Syracuse, NY: Syracuse Research Corporation, Center for Chemical Hazard Assessment. PB86-149317.
Schaeffer DJ, Lower WR, Kapila S, . 1986. Preliminary study of effects of military obscurant smokes on flora and fauna during field and laboratory exposures. Frederick, MD: U.S. Army Medical Bioengineering Research and Development Command. USA-CERL Technical Report N-86/22.
*Schaeffer FJ, Kapila S, Meadows JE, . 1988. Chemical characterization of residues from military HC smokepots. Journal of Hazardous Materials 17:315–328.
*Selden A, Jacobson G, Berg P, . 1989. Hepatocellular carcinoma and exposure to hexachlorobenzene: a case report. Br J Ind Med 46:138–140.2538141
*Selden A, Kvamlof A, Bodin L, . 1994. Health effects of low level occupational exposure to hexachloroethane. Journal of Occupational Medicine and Toxicology 3(10):73–79.
*Selden A, Nygren M, Kvamlof A, . 1993. Biological monitoring of hexachloroethane. Int Ach Occup Environ Health 65:Sll l–S114.
*Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs) data base update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development.
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22:1381–1388.22200458
*Shimizu M, Noda T, Yamano T, . 1992. Safety evaluation of chemicals for use in household products (XVII). A teratological study on hexachloroethane in rats. Osaka City Institute of Public Health and Environmental Sciences 54:70–75. (Japanese) [translation in progress]
*Simmon VF, Kauhanen K. 1978. In vitro microbiological mutagenicity assays of hexachloroethane. Cincinnati, OH: U.S. Environmental Protection Agency, National Environmental Research Center, Water Supply Research Laboratory.
*Singh HB, Salas LJ, Shigeishi H, . 1979. Atmospheric distributions, sources, and sinks of selected halocarbons, hydrocarbons, SF_6_ and N_2_O. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development.
*Southcott WH. 1951. The toxicity and anthelmintic efficiency of hexachloroethane in sheep. The Australian Veterinary Journal 18–21.
*Spanggord RJ, Chou TW, Mill T, . 1985. Environmental fate of nitroguanidine, diethyleneglycol dinitrate, and hexachloroethane smoke. Menlo Park, CA: SRI International.
*SRI. 1977. Profiles on occupational hazards for criteria document priorities. Menlo Park, CA: Stanford Research Institute, National Institute for Occupational Safety and Health. PB-274 073.
*Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142. -.
*Story DL, Meierhenry EF, Tyson CA, . 1986. Differences in rat liver enzyme-altered foci produced by chlorinated aliphatics and phenobarbital. Toxicol Ind Health 2:351–362.3296316
Strong L, Wall R. 1990. The chemical control of livestock parasites: problems and alternatives. Parasitology Today 6:291–296.15463365
*Stutz DR, Ulin S. 1992. Hazardous materials injuries: A handbook for pre-hospital care. Third edition. Beltsville, MD: Bradford Communications Corporation, 286–287.
*Suffet IH, Brenner L, Cairo PR. 1980. GC/MS identification of trace organics in Philadelphia drinking waters during a 2-year period. Water Res 14:853–867.
*Swenberg JA. 1993. ∝2µ-globuin mediated male rat kidney carcinogens. In: Coping with nongenotoxic carcinogens: mode of action, detection, and risk assessment. New Orleans, LA: Society of Toxicology.
*Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tennant RW, Elwell MR, Spalding JW, . 1991. Evidence that toxic injury is not always associated with induction of chemical carcinogenesis. Mol Carcinog 4:420–440.1793481
*Thompson JA, Ho B, Mastovich SL. 1984. Reductive metabolism of 1,1,1,2-tetrachloroethane and related chloroethanes by rat liver microsomes. Chem Biol Interactions 5 1:321–333.
*Thruston AD. 1978. High pressure liquid chromatography techniques for the isolation and identification of organics in drinking water extracts. J Chromatogr Sci 16:254–259.
Thruston RV, Gilfoil TA, Meyn EL, . 1985. Comparative toxicity of ten organic chemicals to ten common aquatic species. Water Res 19: 1145–1155.
*Town C, Leibman KC. 1984. The in vitro dechlorination of some polychlorinated ethanes. Drug Metab Disp 12:4–8.
Tracer Jitco, Inc. 1981. Environmental and health aspects of hexachloroethane, a comprehensive bibliography of published literature 1930-1981. Washington, DC: Environmental Protection Agency, Office of Pesticides and Toxic Substances. PB81-249674.
*TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Tu AS, Murray TA, Hatch KM, . 1985. In vitro transformation of BALB/c-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92.4027960
*Valkenburg CA, Munslow WD. 1989. Evaluation of modifications to extraction procedures used in analysis of environmental samples from Superfund sites. J Assoc Off Anal Chem 72:602–608.
Van Dyke RA. 1977.. Dechlorination mechanisms of chlorinated olefins. Environ Health Perspect 21:121–124.612436
Van Dyke RA, Wineman CG. 1971. Enzymatic dechlorination. Dechlorination of chloroethanes and propanes in vitro. Biochem Pharmacol 20:463–470.4402457
Van Rossum P, Webb RG. 1978. Isolation of organic water pollutants by XAD resins and carbon. J Chromatogr 150:381–392.
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York: Van Nostrand Reinhold Company.
Walker JD. 1987. Effects of chemicals on microorganisms. J Water Pollut Control Fed 59:614–625.
*Weast RC, ed. 1986. CRC handbook of chemistry and physics. 67th ed. Boca Raton, FL: CRC Press.
*Weeks MH, Angerhofer RA, Bishop R, . 1979. The toxicity of hexachloroethane in laboratory animals. Am Ind Hyg Assoc J 40:187–199.495459
*Weisburger EK. 1977. Carcinogenicity studies on halogenated hydrocarbons. Environ Health Perspect 21:7–16.206428
*Wiebolt RC, Adams GE, Later DW. 1988. Sensitivity improvement in infrared detection for supercritical fluid chromatography. Anal Chem 60:2422–2427.
*Yaws C, Yang HC, Pan X. 1991. Henry’s law constants for 362 organic compounds in water. Chemical Engineering 179–185.
Young JY, Smart DA, Allen JT, . 1989. Field exposure of chemical school students and cadre to fog oil and hexachloroethane (HC) smokes. Frederick, MD: U.S. Army Biomedical Research & Development Laboratory. AD-A225008
*Yurawecz MP, Puma BJ. 1986. Gas chromatographic determination of electron capture sensitive volatile industrial chemical residues in foods, using AOAC pesticide multiresidue extraction and cleanup procedures. J Assoc Off Anal Chem 6980–86.