# 7 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, numerous regulations, and advisories have been established for hexachloroethane by various international, national, and state agencies. Major regulations and advisories pertaining to hexachloroethane are summarized in Table 7-1.

ATSDR has calculated an MRL of 6 ppm for acute inhalation exposure to hexachloroethane based on a NOAEL of 48 ppm from a study in pregnant rats. The critical effect was tremors, which occurred during an 11 -day exposure period at a LOAEL of 260 ppm (Weeks et al. 1979). The intermediate inhalation MRL of 6 ppm was also calculated from a NOAEL of 48 ppm observed in a 6-week study in which tremors were observed in rats exposed intermittently at 260 ppm (Weeks et al. 1979).

An MRL of 1 mg/kg/day has been calculated for acute oral exposure to hexachloroethane based on a NOAEL of 100 mg/kg/day from a study in male rabbits (Weeks et al. 1979). Hepatic necrosis and degeneration were observed in the treated animals at doses of 320 and 1,000 mg/kg/day.

An intermediate-duration MRL of 0.01 mg/kg/day has been calculated for oral exposure to hexachloroethane in the diet based on a NOAEL of 1 mg/kg/day from a study in male and female rats (Gorzinski et al. 1985). Enlargement of the hepatocytes was seen in male rats at doses of 15 and 62 mg/kg/day. Relative liver weights were increased in males and females at the 62 mg/kg/day dose.

EPA has derived a chronic oral RfD of 0.001 mg/kg/day for hexachloroethane (IRIS 1995). This value is based on a NOAEL of 1 mg/kg/day for atrophy and degeneration of the renal tubules in rats exposed for 16 weeks (Gorzinski et al. 1985). The NOAEL was divided by an uncertainty factor of 1,000 to account for interspecies extrapolation, human variability, and the use of a subchronic study. EPA places medium confidence in this RfD (IRIS 1995).

TABLE 7-1 Regulations and Guidelines Applicable to Hexachloroethane

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | Group 3^a^ | IARC 1987
[underlined: NATIONAL]
Regulations:
a. Air:
EPA OAQPS | Hazardous Air Pollutant | Yes | Public Law 101-549 Section 112
EPA OAQPS | NESHAP for Source Categories: Organic HAPs from Synthetic Organic Chemical Manufacturing Industry (proposed) | Yes | EPA 1992
OSHA | PEL TWA | 1 ppm (10 mg/m^3^), skin | OSHA 1993 (29 CFR 1910.1000)
b. Water:
EPA OWRS | General permits under NPDES | Yes | 40 CFR 122
EPA OWRS | General Pretreatment Regulations for Existing and New Sources of Pollution | Yes | 40 CFR 403
EPA OWRS | Hazardous substance | Yes | 40 CFR 116
EPA OWRS | Reportable quantity | 100 pounds | 40 CFR 117.3
c. Other:
EPA OERR | Reportable quantity | 100 pounds | EPA 1989 (40 CFR 302.4)
EPA OSW | Hazardous Waste Constituent (Appendix VIII) | Yes | EPA 1980b (40 CFR 261)
EPA OSW | Groundwater Monitoring List (Appendix IX) | Yes | EPA 1987b (40 CFR 264)
EPA OSW | Land Disposal Restrictions | Yes | EPA 1990d, 1991b (40 CFR 268)
EPA OSW | Toxicity Characteristic Leaching Procedure Limit | 3 mg/L | EPA 1995 (40 CFR 261.24)
EPA OSW | Burning of Hazardous Waste boilers and industrial furnaces-residue concentration limit | 3x10^-2^ mg/kg | EPA 1991b
EPA OTS | Toxic Chemical Release Reporting Rule | Yes | EPA 1988b (40 CFR 372)
EPA OTS | Health and Safety Data Reporting Rule | Yes | EPA 1988b (40 CFR 716.120)
Guidelines:
a. Air:
ACGIH | TLV TWA | 1 ppm (9.7 mg/m^3^) A2 - suspect human carcinogen | ACGIH 1993
NIOSH | PEL TWA | 1 ppm; occupational carcinogen | NIOSH 1990
b. Water:
EPA ODW | Health Advisories | | Gordon et al. 1991
EPA ODW | 1-day (child) | 5 mg/L | Gordon et al. 1991
EPA ODW | 10-day (child) | 5 mg/L | Gordon et al. 1991
EPA ODW | Longer term (child) | 100 μg/L | Gordon et al. 1991
EPA ODW | Longer term (adult) | 450 μg/L | Gordon et al. 1991
EPA ODW | Lifetime (adult) | 1 μg/L | Gordon et al. 1991
EPA OWRS | Ambient Water Quality Criteria | | EPA 1980a
EPA OWRS | Ingesting water and organisms | 1.9 μg/L^b^ | EPA 1980a
EPA OWRS | Ingesting organisms only | 8.74 μg/L^b^ | EPA 1980a
c. Other:
EPA | RfD (oral) | 1x10^-3^ mg/kg/day | IRIS 1995
EPA | Carcinogenic classification | Group C^c^ | IRIS 1995
EPA | Cancer slope factor (q_1_*) | | IRIS 1995
EPA | q_1_* (oral) | 1.4x10^-2^ (mg/kg/day)^-1^ | IRIS 1995
EPA | q_1_* (inhalation) | 1.4x10^-2^ (mg/kg/day)^-1^ | IRIS 1995
NTP | May reasonably be anticipated to be a carcinogen | | NTP 1994
STATE
Regulations and Guidelines:
a. Air: | Acceptable ambient conditions | | NATICH 1995
Connecticut | 8-hour | 50 μg/m^3^ | NATICH 1995
Kansas | annual | 2.5x10^-1^ μg/m^3^ | NATICH 1995
Massachusetts | 24-hour | 5.3x10^-1^ μg/m^3^ | NATICH 1995
Massachusetts | annual | 2.5x10^-1^ μg/m^3^ | NATICH 1995
Nevada | 8-hour | 2.38 mg/m^3^ | NATICH 1995
North Dakota | 8-hour | 9.7x10^-2^ μg/m^3^ | NATICH 1995
Oklahoma | 24-hour | 2.0x10^2^ μg/m^3^ | NATICH 1995
Texas | 30-minute | 97 μg/m^3^ | NATICH 1995
Texas | annual | 10 μg/m^3^ | NATICH 1995
Vermont | annual | 2.5x10^-1^ μg/m^3^ | NATICH 1995
Virginia | 24-hour | 1.6x10^2^ μg/m^3^ | NATICH 1995
b. Water: | Drinking water standards and guidelines | | FSTRAC 1990
Kansas | | 1.9 μg/L | FSTRAC 1990
Minnesota | | 0.7 μg/L | FSTRAC 1990

a Group 3: Not classifiable as to human carcinogenicity

b Based on a lifetime incremental cancer risk of 1x10^-6^

c Group C: Possible human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; EPA = Environmental Protection Agency; HAP = Hazardous Air Pollutant; IARC = International Agency for Research on Cancer; NESHAP = National Emission Standards for Hazardous Air Pollutants; NIOSH = National Institute for Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; NTP = National Toxicology Program; OAQPS = Office of Air Quality Planning and Standards; ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; OTS = Office of Toxic Substances; OWRS = Office of Water Regulations and Standards; PEL = Permissible Exposure Limit; RfD = Reference Dose; TLV = Threshold Limit Value; TWA = Time-Weighted Average