# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Table 3-1 lists common synonyms, trade names, and other pertinent identification information for hexachloroethane.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Table 3-2 lists important physical and chemical properties of hexachloroethane.

TABLE 3-1 Chemical Identity of Hexachloroethane

Characteristic | Information | Reference
Chemical name | Hexachloroethane | HSDB 1995
Synonym(s) | Perchloroethane; carbon hexachloride; 1,1,1,2,2,2-hexachloroethane; hexachloroethylene; HCE; and others | ACGIH 1991; Gordon et al. 1991; HSDB 1995
Registered trade name(s) | Avlothane; Distokal; Distopan; Distopin; Egitol; Falkitol; Fasciolin; Mottenhexe; Phenohep | IARC 1979
Chemical formula | C_2_Cl_6_ | HSDB 1995
Chemical structure | [image] | Howard 1989
Identification numbers:
CAS registry | 67-72-1 | HSDB 1995
NIOSH RTECS | KI 4025000 | HSDB 1995
EPA hazardous waste | U131
OHM/TADS | No data | HSDB 1995
DOT/UN/NA/IMCO shipping | NA 9037 | HSDB 1995
HSDB | 2033 | HSDB 1995
NCI | C04604 | HSDB 1995

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Physical and Chemical Properties of Hexachloroethane

Property | Information | Reference
Molecular weight | 236.74 | Weast 1986
Color | Colorless | HSDB 1995
Physical state | Solid | HSDB 1995
Melting point | Sublimes | ACGIH 1991; Budavari et al. 1989
Boiling point | 186.8°C (triple point) | Budavari et al. 1989
Density:
at 20°C | 2.091 g/mL | Weast 1986
Odor | Camphoraceous | Budavari et al. 1989
Odor threshold:
Water | 0.010 mg/L | Amoore and Hautala 1983
Air | 0.15 ppm (1.5 mg/m^3^) | Amoore and Hautala 1983
Solubility:
Water at 22°C | 50 mg/L | Verschueren 1983
Water at 25°C | 14 mg/L | Spanggord et al. 1985
Organic solvent(s) | Soluble in alcohol, benzene, chloroform, ether, oils | Budavari et al. 1989
Partition coefficients:
Log K_ow_ | 3.82 | Howard 1989
Log K_ow_ | 3.34 | Callahan et al. 1979
Log K_oc_ | 4.3 | Mabey et al. 1982
Vapor pressure:
at 20°C | 0.4 mmHg | Verschueren 1983
at 30°C | 0.8 mmHg | Verschueren 1983
Henry’s law constant:
at 25°C: | 2.237×10^−2^ atm m^3^/mole | Yaws et al. 1991
at 25°C: | 6,100 L-torr/mol | Spanggord et al. 1985
at 25°C: | (8.0×10^−3^ atm m^3^/mol
at 25°C: | 2.8×10^−3^ atm m^3^/mole | Howard 1989
Autoignition temperature | Nonflammable | IARC 1979
Flashpoint | Nonflammable | IARC 1979
Flammability limits | Nonflammable | IARC 1979
Conversion factors | 1 ppm = 9.68 mg/m^3^ | Verschueren 1983
Conversion factors | 1 mg/m^3^ = 0.10 ppm | Verschueren 1983
Explosive limits | No data