# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Hexachloroethane Acute Inhalation

MINIMAL RISK LEVEL WORKSHEETS

Chemical Name: | Hexachloroethane
CAS Number: | 67-72-1
Date: | September 1996
Profile Status: | Draft 3 Post-public comments
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 4
Species: | Rat

[underlined: Minimal Risk Level]: [underlined: 6] [ ] mg/kg/day [x] ppm

[underlined: Reference]: Weeks et al. 1979

[underlined: Experimental design]:

Groups of 22 pregnant Sprague-Dawley rats were exposed to vapors of hexachloroethane (0, 15,48, or 260 ppm) 6 hours/day on gestation days 6-16. Specific details of methods and results are not reported in this paper.

[underlined: Effects noted in study and corresponding doses]:

Hexachloroethane resulted in tremors at 260 ppm, with no neurological effects at 48 ppm. Transient mucopurulent nasal exudate in 85% of the animals and an unspecified decrease in maternal weight gain were noted in animals at 48 ppm. This effect was considered a result of an endemic mycoplasma infection and was not observed at 48 ppm in the 6-week study (Weeks et al. 1979). The 260-ppm concentration is a serious LOAEL for neurological effects and the 48-ppm concentration is a NOAEL.

[underlined: Dose and end point used for MRL derivation]:

[X] NOAEL [] LOAEL

48 ppm

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 3 for use of a minimal LOAEL
- [x] 3 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/bodv weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

Human Equivalent Concentration was calculated using default values from EPA (1988a).

48 ppm [(0.22 m^3^/day/0.204 kg) / (20 m^3^/day/70 kg)] = 181 ppm

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

Other than the study by Weeks et al. (1979), there are no inhalation studies useful for estimating an acute inhalation MRL.

## Hexachloroethane Intermediate Inhalation

Chemical Name: | Hexachloroethane
CAS Number: | 67-72-1
Date: | September 1996
Profile Status: | Draft 3 Post-public comments
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 14
Species: | Rat

[underlined: Minimal Risk Level]: [underlined: 6] [ ] mg/kg/day [x] ppm

[underlined: Reference]: Weeks et al. 1979

[underlined: Experimental design]:

Groups of 25 male and 25 female Sprague-Dawley rats were exposed to vapors of hexachloroethane (0, 15, 48 or 260 ppm) 6 hours/day, 5 days/week for 6 weeks. Half of the animals were sacrificed at the end of the exposure period while the remainder were sacrificed 12 weeks after the end of the study. Quantitative data are not reported in this paper.

[underlined: Effects noted in study and corresponding doses]:

One male and one female rat exposed at 260 ppm died. There was an increased incidence of mycoplasma infection at 260 ppm that the authors attributed to hexachloroethane-induced potentiation of an endemic infection. Histopathologic changes were not observed in the brain, lungs, heart, liver, kidneys, spleen, eyes, bone marrow, trachea, nasal turbinates, thymus, stomach, small intestines, large intestines, pancreas, adrenal glands, bladder, testes, skin, skeletal muscle, and bone. Body weights (quantitative data not given) were reduced, and eye irritation was noted at 260 ppm. The high concentration is a serious effect level associated with tremors and less serious effects, reduced resistance to infection, eye irritation, and reduced body weight. The 48-ppm concentration is a NOAEL.

[underlined: Dose and end point used for MRL derivation]:

[x] NOAEL [ ] LOAEL

48 ppm

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [x] 3 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/bodv weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

Human Equivalent Concentration was calculated using default values from EPA (1988a).

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

Other than the study by Weeks et al. (1979) there are no inhalation studies useful for estimating an intermediate inhalation MRL. Studies in guinea pigs and dogs confirm that 260 ppm hexachloroethane is a serious effect concentration; 4/10 guinea pigs, and 1/4 dogs died at this concentration. These studies do not clearly identify a less serious LOAEL that does not have some serious effects. The 48-ppm concentration is a NOAEL for the most sensitive toxicity endpoint in all three species.

## Hexachloroethane Acute Oral

Chemical Name: | Hexachloroethane
CAS Number: | 67-72-1
Date: | September 1996
Profile Status: | Draft 3 Post-public comments
Route: | [] Inhalation [x] Oral
Duration: | [x] Acute [] Intermediate [ ] Chronic
Graph Key: | 8
Species: | Rabbit

[underlined: Minimal Risk Level]: [underlined: 1] [x] mg/kg/day [] ppm

[underlined: Reference]: Weeks et al. 1979

[underlined: Experimental design]:

Groups of five male New Zealand rabbits were treated by gavage with hexachloroethane in methyl cellulose for 12 days at 0, 100, 320, or 1,000 mg/kg/day. Body weights were recorded daily, clinical signs were monitored, and serum chemistry parameters were evaluated (alanine aminotransferase, aspartate aminotransferase, blood urea nitrogen, alkaline phosphatase, bilirubin, total protein, potassium, and sodium). Necropsies were performed 4 days after the last dose and organs (lungs, liver, kidneys, spleen, testes) were weighed. Histopathological examinations of selected tissues and organs (eye, brain, lung, kidney, liver, spleen, heart, stomach, pancreas, small intestine, large intestine, skeletal muscle, bone, urinary bladder, testes) were also conducted.

[underlined: Effects noted in study and corresponding doses]:

Liver degeneration and necrosis occurred in a dose-related manner at 320 and 1,000 mg/kg/day. Effects were characterized as fatty degeneration, coagulative necrosis, hemorrhage, ballooning degeneration, eosinophilic change, and hemosiderin-laden macrophages and giant cells. Comparable effects were not seen in the 100-mg/kg/day dose group (lowest dose tested). Also, liver weights increased at the highest dose tested; however, quantitative data were not provided for evaluation. For the most part, serum clinical chemistry parameters were not significantly affected, except that levels of potassium and glucose were decreased significantly at dose levels of 320 mg/kg/day or greater. No quantitative data were provided for evaluation. Toxic tubular nephrosis of the convoluted tubules was seen at dose levels of 320 and 1,000 mg/kg/day; however, comparable effects were not observed at the lowest dose tested (100 mg/kg/day). Effects observed among treatment groups did not occur in a dose-dependent manner. Minimal tubular nephrocalcinosis occurred in a dose-related manner at dose levels of 320 mg/kg/day or greater. Also, kidney weights increased significantly (p<0.05) at the highest dose tested. Quantitative data were not provided for evaluation. No treatment-related gross or histopathological lesions of the urinary bladder were reported. Body weights were reduced significantly (p<0.05) at exposure levels of 320 and 1,000 mg/kg/day. Effects were seen within 7 days after compound exposure in the highest dose group and within 10 days at the intermediate dose. No changes in body weight were found at 100 mg/kg/day, the lowest dose tested. Quantitative data were not provided for evaluation.

[underlined: Dose and end point used for MRL derivation]:

[x] NOAEL [] LOAEL

100 mg/kg/day for lack of liver effects

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/bodv weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

There are no other acute oral studies of hexachloroethane which support this MRL. However, intermediate-duration oral studies of hexachloroethane in rats described further in the worksheet for the intermediate-duration oral MRL provide support that the liver is a target following oral exposure to hexachloroethane.

## Hexachloroethane Intermediate Oral

Chemical Name: | Hexachloroethane
CAS Number: | 67-72-1
Date: | September 1996
Profile Status: | Draft 3 Post-public comments
Route: | [] Inhalation [x] Oral
Duration: | [] Acute [x] Intermediate [ ] Chronic
Graph Key: | 18
Species: | Rat

[underlined: Minimal Risk Level]: [underlined: 0.01] [x] mg/kg/day [] ppm

[underlined: Reference]: Gorzinski et al. 1985

[underlined: Experimental design]:

Groups of 10 male and 10 female Fischer-344 rats were fed hexachloroethane in the diet for 16 weeks at levels that provided doses of 0, 1, 15, or 62 mg/kg/day. Procedures were taken to minimize volatilization from food, and the doses are actual doses rather than target doses. Body weights were monitored weekly and food consumption biweekly. At 13 weeks, blood samples were collected and analyzed for red cell count, hemoglobin concentration, and leukocyte counts. Urine specimens (13-week) were analyzed for pH, glucose, protein, ketones, occult blood, and urobilinogen. Blood samples taken at 16 weeks were analyzed for serum urea nitrogen, creatine, glutamate-pyruvate transaminase, and alkaline phosphatase. After sacrifice, the weights of the brain, heart, liver, kidneys, and testes were determined. The tissues of the organs were preserved and examined histologically.

[underlined: Effects noted in study and corresponding doses]:

Liver weights were increased in male rats at the highest dose and there was swelling of the hepatocytes in males at the highest two doses. Differences were significant for absolute and relative liver weights at the highest dose. Increased relative liver weights were seen in females at the highest dose. The kidneys in the two highest male dose groups displayed tubular atrophy, hypertrophy, and dilation. At the highest dose, kidney weights were increased by 10% and relative kidney weight by 5.5%. These changes in the kidneys were not seen in females except at the highest dose. There were no differences in the urinalysis results for the controls and exposed animals. Histopathologic changes in other organs were not observed. The 15-mg/kg/day dose is considered a minimal LOAEL for swelling of hepatocytes, and the 1-mg/kg/day dose is a NOAEL.

[underlined: Dose and end point used for MRL derivation]:

[x] NOAEL [] LOAEL

1 mg/kg/day for lack of liver effects

[underlined: Uncertainty Factors used in MRL derivation]:

- [] 10 for use of a LOAEL
- [x] 10 for extrapolation from animals to humans
- [x] 10 for human variability

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose:]

[underlined: Other additional studies or pertinent information which lend support to this MRL]:

Increased liver weights and an increase in the number of gamma glutamyl transpeptidase positive foci (dimethylnitrosoamine was used as an initiator), were reported in rats treated by gavage with hexachloroethane in com oil at 497 mg/kg/day 5 days/week for 7 weeks (Milman et al. 1988; Story et al. 1986). No other doses were used in this study. Centrilobular necrosis was observed in female Fischer-344 rats treated by gavage with hexachloroethane in com oil 5 days/week for 13 weeks (NTP 1989). No liver effects were observed at 94 mg/kg/day, suggesting that the LOAEL identified in the Gorzinski et al. (1985) study may be conservative. No liver effects were observed in female rats treated by gavage with hexachloroethane in com oil 5 days/week for 2 years (NTP 1989) providing further support that the 15-mg/kg/day LOAEL observed in the Gorzinski et al. (1985) study may be conservative.