# 8 REFERENCES

* Cited in text

*Abdo KM, Montgomery CA, Kluwe WM. 1984. Toxicity of hexachlorocyclopentadiene: Subchronic (13-week) administration by gavage to F344 rats and B6C3Fl mice. J Appl Toxicol 4:75–81.6736554
ACGIH. 1990. Hexachlorocyclopentadiene. Documentation of the threshold limit values and biological exposure indices. 6th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1992. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1992-1993. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1998. Threshold limit values for chemical substances and physical agents. Biological exposure Indices. 1998 TLVs and BEIs. American Conference of Governmental Industrial Hygienists. March 1, 1998.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Developmental Medicine & Child Neurology 27:532–537.4029526
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book, Volume III, second edition. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987-2008,204l.
*Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 2 14 industrial chemicals in air and water dilution. J Appl Toxicol 3:272–290.6376602
*Andersen ME, Krishman K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H., ed. Current concepts and approaches on animal test altematves. U.S. Army Chemical Research Development and Engineering Center, Aberdeen Proving Ground, Maryland.
*Andersen ME, MacNaughton MG, Clewell HJ, 1987. Adjusting exposure limits for long and short exposure periods using a physiological pharmacokinetic model. Am Ind Hyg Assoc J 48(4):335–343.3591649
*Anderson GC. 1983. Human exposure to atmospheric concentrations of selected chemicals. Vol 2, 16-4 to 16-13. Environmental Protection Agency; Office of Air Quality Planning and Standards, Research Triangle Park, NC. NTIS Accession No. PBS3 265248.
*APHA. 1992. Method 6410B. Liquid-liquid extraction gas chromatographic/mass spectrometric method. In: Standard methods for the examination of water and wastewater. 18th ed. Washington, DC: American Public Health Association.
*Atallah YH Whitacre DM, Butz RG. 1981. Fate of hexachlorocyclopentadiene in the environment. In: Khan MA Q, Stanton RI-I, eds. Toxicology of halogenated hydrocarbons. New York, NY: Pergamon Press, 344–355.
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Part V. Federal Register 54:37619–37633.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Bauer S, Wolff I, Werner N, 1995. Toxicological investigations in the semiconductor industry: iv: studies on the subchronic oral toxicity and genotoxicity of vacuum pump oils contaminated by waste products from aluminum plasma etching processes. Toxicology and Industrial Health 5:523–541.
*Bell MA, Ewing RA, Lutz GA. 1980. Reviews of the environmental effects of pollutants: XII. Hexachlorocyclopentadiene. Cincinnati, OH: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Office of Research and Development. EPA-600/l-78-047.
*Benoit FM, Williams DT. 1981. Determination of hexachlorocyclopentadiene at the nanogram per liter level in drinking water. Bull Environ Contam Toxicol 27:303–308.7296063
*Boogaard PJ, Rocchi PSJ, van Sittert NJ. 1993. Effects of exposure to low concentrations of chlorinated hydrocarbons on the kidney and liver of industrial workers. British Journal of Industrial Medicine 50:33 l-339.
*Boyd KW, Emory MB, Dillon HK. 1981. Development of personal sampling and analytical methods for organochlorine compounds. In: Chemical hazards in the workplace. American Chemical Society 4:49–64.
Brennecke LH. 1992. Pathology working group chairperson’s report on the 65-week interim sacrifice and chronic inhalation study of hexachlorocyclopentadiene in F344 rats. Research Triangle Park, NC: National Toxicology Program, National Institute of Environmental Health Sciences.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company, 10:103–104.
*Butz RG, Yu CC, Atallah YH. 1982. Photolysis of hexachlorocyclopentadiene in water. Ecotoxicol Environ Safety 6:347–357.7117186
*Callahan MA, Slimak MW, Gabel NW, 1979. Water-related environment fate of 129 priority pollutants. Vol. II. Washington, DC: U.S. Environmental Protection Agency, Office of Water and Waste Management, Office of Water Planning and Standards. PB80-20438 1.
*Camanzo J, Rice CP, Jude DJ. 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments, 1983. Journal of Great Lakes Research 13:296–309.
*Chernoff N, Kavlock RJ. 1982. An in vivo teratology screen utilizing pregnant mice. J. Toxicol Environ Health 10:541–550.7161814
Chernoff N, Kavlock RJ. 1983. A teratology test system which utilizes postnatal growth and viability in the mouse. Environmental Science Research 27:417–427.
Chopra NM, Campbell BS, Hurley JC. 1978. Systematic studies on the breakdown of endosulfan in tobacco smokes: Isolation and identification of the degradation products from the pyrolysis of endosulfan I in a nitrogen atmosphere. J Agric Food Chem 26:255–258
*Chou SF, Fisher BW, Griffin RA. 1981. Aqueous chemistry and adsorption of hexachlorocyclopentadiene by earth materials. Proceedings, Seventh Annual Symposium, U.S. EPA. EPA-600/9-81-002b, 29–42.
*Chou SF, Griffin RA. 1983. Soil, clay, and caustic soda effects on solubility, sorption, and mobility of hexachlorocyclopentadiene. Champaign, IL: Illinois State Geological Survey Division, U.S. Department of Commerce, PB84-116060.
*Chou SF, Griffin RA, Chou MI. 1987. Products of hexachlorocyclopentadiene (C-56) in aqueous solution. Environmental Toxicology and Chemistry 6:371–376.
*Clark CS, Meyer CR, Gartside PS, 1982. An environmental health survey of drinking water contamination by leachate from a pesticide waste dump in Hardeman County, Tennessee. Arch Environ Health 37:9–18.7059235
Clark CS, Que Hee SS, Newman MA, 1986. D-glucaric acid excretion of workers in a wastewater facility receiving pesticide wastes. Cincinnati, OH: Department of Environmental Health.
*Clewell HJ III, Andersen M. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Cole EJ. 1954. Treatment of sewage with hexachlorocyclopentadiene. Applied Microbiology 2:198–199.13181399
*Cupitt LT. 1980. Fate of toxic and hazardous materials in the air environment. U.S. Environmental Protection Agency. Cincinnati, OH. EPA 600/3-80-084.
*DeLeon IR, Maberry MA, Overton EB, 1980a. Determination of trace levels of hexachlorocyclopentadiene and octachlorocyclopentene in body fluids. J Anal Toxicol 4:314–317.7206662
*DeLeon IR, Maberry MA, Overton EB, 1980b. Rapid gas chromatographic method for the determination of volatile and semivolatile organochlorine compounds in soil and chemical waste disposal site samples. J Chromatogr Sci 18:85–88.
DHHS. 1995. Report to Congress on workers’ home contamination study conducted under the workers’ family protection act (29 U.S.C. 671a). U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health (Cincinnati, OH).
Dillon HK. 1980. For toxic chlorinated organic compounds - research report for hexachlorocyclopentadiene. Cincinnati, OH: Public Health Service, Department of Health and Human Services, National Institute for Occupational Safety and Health. SORI-EAS-80-057.
*Dorough HW, Ranieri TA. 1984. Distribution and elimination of hexachlorocyclopentadiene in rats and mice. Drug Chem Toxicol 7:73–89.6723547
*Eichelberger JW, Bellar TA, Donnelly JP, 1990. Determination of volatile organics in drinking water with USEPA method 524.2 and the ion trap detector. J. Chromatogr Sci 28:460–467.2273069
*Eichelberger JW, Kerns EH, Olynyk P, 1983. Precision and accuracy in the determination of organics in water by fused silica capillary column gas chromatography/mass spectrometry and packed column gas chromatography/mass spectrometry. Anal Chem 55:1471–1479.
*Eisenreich SJ 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environmental Sci Technology 15:30–38.
*El Dareer SM, Noker PE, KF, 1983. Investigations on the basis for the differential toxicity of hexachlorocyclopentadiene administered to rats by various routes. J Toxicol Environ Health 12:203–211.6655730
*Elia VJ, Clark CS, Majeti VA, 1983. Hazardous chemical exposure at a municipal wastewater treatment plant. Environ Res 32:260–37 1.
*EPA. 1980a. Ambient water quality criteria for hexachlorocyclopentadiene. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards PB8 l-l 17665.
*EPA. 1980b. U.S. Environmental Protection Agency. Federal Register 45:33 132–33 133.
*EPA. 1981a. Effluent guidelines and standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.
*EPA. 1981b. Engineering handbook for hazardous waste incineration. U.S. Environmental Protection Agency EPA 68-03-3025.
*EPA. 1982a. Test method - chlorinated hydrocarbons - method 612. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. 612-1–612-8.
EPA. 1982b. U.S. Environmental Protection Agency. Federal Register 47:58023–58025.
EPA. 1982c. U.S. Environmental Protection Agency. Federal Register 47:26992–27008.
*EPA. 1984a. Guidelines establishing test procedures for the analysis of pollutants under the clean water act; final rule and interim final rule and proposed rule. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136. October 26, 1984.
EPA. 1984b. Health effects assessment for hexachlorocyclopentadiene. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. EPA/540/1-86/001.
EPA. 1984c. Health assessment document for hexachlorocyclopentadiene. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria & Assessment Office, Office of Research and Development. PB 85-124915.
*EPA. 1985. U.S. Environmental Protection Agency. Part II. Federal Register 50:40672–40777.
EPA. 1986. Method 8250. Gas chromatography/mass spectrometry for semivolatile organics: packed column technique. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1987. U.S. Environmental Protection Agency. Part II. Federal Register 52:400.
*EPA. 1988a. Compendium of methods for the determination of toxic organic compounds in ambient air. U.S. Environmental Protection Agency, June 1988, EPA 600/4-89/017 (PB90-127374).
*EPA. 1988b. U.S. Environmental Protection Agency. Part II. Federal Register, Section 313.
*EPA. 1988~. U.S. Environmental Protection Agency. Part V. Federal Register 53:38642–38654.
*EPA. 1989a. Ambient water quality criteria document for hexachlorocyclopentadiene. Addendum. Final Draft. Cincinnati, OH: US. Environmental Protection Agency, Office of Water Regulations and Standards. PB91-161422.
*EPA. 1989b. Method 505. Analysis of organohalide pesticides and commercial polychlorinated biphenyl (PCB) products in water by microextraction and gas chromatography. Rev. 2.0. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, 109– 14 1.
*EPA. 1989c. U.S. Environmental Protection Agency. Federal Register 54:52057–53065.
*EPA. 1989d. U.S. Environmental Protection Agency. Part V. Federal Register 54:33459, 33483.
*EPA. 1989e. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.
*EPA. 1990a. Method 8 12 1. Chlorinated hydrocarbons by gas chromatography: Capillary column technique. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1990b. Method 8 120A. Chlorinated hydrocarbons by gas chromatography. Rev. 1. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1990c. U.S. Environmental Protection Agency. Part II. Federal Register 55:30370–30448.
*EPA. 1990d. U.S. Environmental Protection Agency. Part II. Federal Register 55:22521, 22712.
*EPA. 1990e. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. U. S. Environmental Protection Agency: Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1991a. Drinking water criteria document for hexachlorocyclopentadiene. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Water. ECAO-CIN-D007.
*EPA. 1991 b. Method 525.1. Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. Rev. 2.2. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. 323–360.
EPA. 1991c. U.S. Environmental Protection Agency. Part II. Federal Register 56:3526–3597.
*EPA. 1991d. U.S. Environmental Protection Agency. Part III. Federal Register 56:7234.
*EPA. 1992a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-90/066A.
*EPA. 1992b. U.S. Environmental Protection Agency. Part III. Federal Register 57:31778, 31829–31830.
*EPA. 1993. Standards for the management of hazardous waste and specific types of hazardous waste facilities. Health-based limits for exclusion of waste-derived residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix VII.
*EPA. 1995a. Designation, reportable quantities, and notification. List of hazardous substances and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1995b. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.
*EPA. 1995~. Emergency planning and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355.
*EPA. 1995d. EPA administered permit programs: the national pollutant discharge elimination system. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122.
*EPA. 1995e. National primary drinking water regulations. Maximum contaminant levels. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
*EPA. 1995f. Methods for the determination of organic compounds in drinking water - supplement III. U.S. Environmental Protection Agency, Office of Research and Development, August 1995, EPA 600/R-95/1 31.
*EPA. 1996a. Health and safety data reporting. Substances and listed mixtures to which the subpart applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 7 16.120.
*EPA. 1996b. Land disposal restrictions. Prohibitions on storage. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, Appendix VII.
*EPA. 1996c. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1996d. Test methods for evaluating solid waste - Volume IB: Laboratory manual physical/chemical methods. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response, December 1996, SW 846, Third Edition.
*EPA. 1997a. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 26 1.
*EPA. 1997b. Land disposal restrictions. Universal treatment standards. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.48
*EPA. 1997c. Toxic release inventory reporting form R and instructions. U.S. Environmental Protection Agency, Washington, D.C.
*FEDRIP. 1998. FEDRIP Literature Search (References and Abstracts) for HCCP. Federal Research in Progress. Dialog Information Service.
*Feron VJ, Beems RB, Reuzel PGJ, Zwart A. 1996. Respiratory toxicology: Pathophysiology, toxicological pathology and mechanisms of toxicity. Chapter 18. In: Niesink RJ M, de Vries J, and Hollinger M, eds. Toxicology. Principles and applications. New York, NY: CRC Press, 534.
*Fornan SJ. 1966. Body composition of the infant (Part I: The male reference infant). In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Foman SJ, Haschke F, Ziegler EE 1982. Body composition of reference children from birth to ge 10 years. American Journal of Clinical Nutrition 35:1169-l 175.7081099
*FSTRAC 1995. Summary of state and federal drinking water standards and guidelines. 1993-1995. U.S. Envirommental Protection Agency. Office of Science and Technology. Office of Water.
Geyer H, Politzki G, Freitag D. 1984. Prediction of ecotoxicological behaviour of chemicals: Relationship between n-octanol/water partition coefficient and bioaccumulation of organic chemicals by alga chlorella. Chemosphere 13:269–284.
Geyer H. Viswanathan R, Freitag D, 1981. Relationship between water solubility of organic chemicals and their bioaccumulation by the alga chlorella. Chemosphere 10:1307–1313.
Gill US, Schwartz HM, Wheatley B. 1996. Development of a method for the analysis of PCB congeners and organochlorine pesticides in blood/serum. Chemosphere 32(6): 1055– 106 1.8920591
*Goggelmann W, Greim H, Bonse G, 1978. Mutagenicity of chlorinated cyclopentadienes due to metabolic activation. Biochemical Pharmacol 27:2927–2929.
*Gray LE, Kavlock RJ. 1984. An extended evaluation of an in viva teratology screen utilizing postnatal growth and viability in the mouse. Teratogenesis Carcinog Mutagen 4:403–426.6150557
Gray LE, Kavlock RJ, Chernoff N. 1980. A research protocol for postnatal evaluation of teratogenic effects. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. Teratology 2 1:4 1 A.
Gray LE, Kavlock RJ, Ostby J. 1983. Assessment of the utility of postnatal testing following prenatal exposure to forty chemicals. In: Liss AR, ed. Abnormal functional development of the heart, lungs, and kidneys: approaches to functional teratology. New York, NY: Alan R. Liss, Inc., 39–62.
*Gray LE, Kavlock RJ, Ostby J, 1986. An evaluation of figure-eight maze activity and general behavioral development following prenatal exposure to forty chemicals: Effects of cytosine arabinoside, dinocap, nitrofen, and vitamin A. Neurotoxicology 7:449–462.3537858
*Great Lakes Water Quality Board. 1983 An inventory of chemical substances identified in the Great Lakes Ecosystem. Vol. 1. December 3 1, 1983.
*Greim H Bimboes D, Egert G, 1977. Mutagenicity and chromosomal aberrations as an analytical tool for in vitro detection of mammalian enzyme-mediated formation of reactive metabolites. Arch Toxicol 39: 159–169.414695
Grosjean D. 1991. Atmospheric chemistry of toxic contaminants. 5. Unsaturated halogenated aliphatics: ally1 chloride, chloroprene, hexachlorocyclopentadiene, vinylidene chloride. J Air Waste Management Association 4 1: 182-l 89.
*Grosjean D, Williams EL. 1992. Environmental persistence of organic compounds estimated from structure-reactivity and linear free-energy relationships, unsaturated aliphatics. Atmos Environ 8:1395–1405.
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: implications for risk assessment. International Life Sciences Institute Press, Washington, D.C.
Harris RH, Highland JH, Rodricks JV, 1984. Adverse health effects at a Tennessee hazardous waste disposal site. Hazardous Waste 1:183–204.
Hartung G, Mansour M, Hustert K, 1980. [Reaktionen einiger chlorathylene mit 0(3P)]. Chemosphere 9:325–328.
*Hauser TR, Bromberg SM. 1982. EPA’s monitoring program at Love Canal 1990. Environmental Monitoring Assessment 2:249–271.24264296
*Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5:3–142.
*HazDat. 1998. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA
Hoecker JE, Durkin PR, Hanchett A, 1977. Information profiles on potential occupational hazards. Syracuse, NY: Center for Chemical Hazard Assessment, 16– 18.
Holloman ME: Layton BR Kennedy MV, 1975. Identification of the major thermal degradation products of the insecticide mirex. J Agric Food Chem 5: 101 l-1012.
*HSDB. 1998. Hazardous substances data bank (HCCP). National Library of Medicine. National Toxicology Program, Bethesda, MD.
Hunter CG. 1968. Allowable human body concentrations of organochlorine pesticides. Med Lav 10577–582.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risk to humans. Overall evaluations of carcinogenicity: An updating of IARC monographs Volume 1 to 42. Supplement 7. International Agency for Research on Cancer. World Health Organization. March 1987.
*IRDC. 1972. Acute toxicity studies in rats and rabbits. International Research and Development Corporation.
*IRIS. 1997. Integrated risk information system. Hexachlorocyclopentadiene (HCCPD). CASRN 77-47-4. (03/01/97). U.S. Environmental Protection Agency. IRIS Substance File. http://www.epa.gov/ngisngm3/iris/subst/0059.htm.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals, international register of potentially toxic chemicals. United Nations Environmental Programme, Geneva Switzerland, 154.
* Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Research 190:3–16.6769537
John JA, Murray FJ, Murray JS, 1979. Evaluation of environmental contaminants, tetrachloroacetone, hexachlorocyclopentadiene, and sulfuric acid aerosol for teratogenic potential in mice and rabbits. Teratology 19:32A-33A.
Jokinen MP. 1992. 26-, 33-, 42-, and 64-week stop exposures and continuous 2-year inhalation studies of hexachlorocyclopentadiene (C55607B) administered to B6C3Fl mice. In: Pathology Associates, Inc. Pathology working group chairperson’s report.
*Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion process. Chemosphere 9: 187–230.
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–3 8.7379718
Khan MA, Feroz M; Podowski, 1980. Ecological and health effects of the photolysis products of chlorinated hydrocarbon pesticides. In: Haque R ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science Publishing, Inc. 25: 394–4 13.
Khan MA, Sudershan P, Feroz M, 1981. Biotransformations of cyclodienes and their photoisomers and hexachlorocyclopentadiene in mammals and fish. In: Toxicol halogenated hydrocarbons: Health ecological effects, 27 l-288.
*Kilzer L, Scheunert I, Geyer H, 1979. Laboratory screening of the volatilization rates of organic chemicals from water and soil. Chemosphere lo:75 1-761.
Korninsky JR, Wisseman CL. 1978. Hazard evaluation and technical assistance report no. TA 77-79. Cincinnati, OH: National Institute for Occupational Safety and Health, U.S. Department of Health, Education, and Welfare, Centers for Disease Control. PB82-178088.
*Kominsky JR, Wisseman CL, Morse DL. 1980. Hexachlorocyclopentadiene contamination of a municipal wastewater treatment plant. Am Ind Hyg Assoc J 415.52–556.
*Komori M, Nishio K, Kitada M 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Wallace Hayes, ed. Principles and methods of toxicology. 3rd edition. New York, NY: Raven Press, Ltd.
*Krishnan K, Andersen ME, Clewell HJ III, 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang R.S. A., ed. Toxicology of chemical mixtures. New York, NY: Academic Press.
Kuehl DW, Leonard ED. 1983. Polychlorinated chemical residues in fish from major watersheds near the Great Lakes. Environment International 9:293–299.
*Lawrence LJ, Dorough HW. 1981. Retention and fate of inhaled hexachlorocyclopentadiene in the rat. Bull Environ Contam Toxicol 26:663–668.7260438
*Lawrence LJ, Dorough HW. 1982. Fate of inhaled hexachlorocyclopentadiene in albino rats and comparison to the oral and IV routes of administration. Fundam Appl Toxicol 2:235–240.7185621
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: implications for practice. Pediatric Clinics of North America 44:55–77.9057784
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. In: Ballantine B, Marro T, Turner T, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Litton Bionetics. 1978a. Mutagenicity evaluation of hexachlorocyclopentadiene in the mouse lymphoma forward mutation assay. Kensington, MD: Litton Bionetics, Inc. l-10.
*Litton Bionetics. 1978b. Mutagenicity evaluation of hexachlorocyclopentadiene in the mouse dominant lethal assay. Kensington, MD: Litton Bionetics, Inc. l-A-8.
Lopez-Avila V, Benedicto J. 1996. Microwave-assisted extraction combined with gas chromatography and enzyme-linked immunosorbent assay. Trends in Analytical Chemistry 15 (8):334–341.
*Lopez-Avila V, Dodhiwala NS, Beckert WF. 1991. Method for the su@ercritical fluid extraction of soils/sediments. Las Vegas, NV: Environmental Monitoring Systems Laboratory. EPA/600/S4-90/026.
*Lopez-Gonzalvez MA, Gomez MM, Camara C 1994. On-line microwave oxidation for the determination of organoarsenic compounds by high-performance liquid chromatography-hydride generationatomic absorption spectrometry. Journal of Analytical Atomic Spectrometry 9(3):291–295.
*Lu PY Metcalf RL, Hirwe AS, 1975. Evaluation of environmental distribution and fate of hexachlbrocyclopentadiene, chlordene, heptachlor, and heptachlor epoxide in a laboratory model ecosystem. J Agric Food Chem 23:967–973.1174135
Lurker PA, Clark CS, Elia VJ. 1982. Atmospheric release of chlorinated organic compounds from the activated sludge process. J Water Pollut Control Fed 54: 1566–1573.
*Mabey WR, Smith JH, Pod011 RT, 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Offrce of Water Regulations and Standards. EPA-440/4-81-014.
*Mason JM, Valencia R Zimmering S. 1992. Chemical mutagenesis testing in drosophila: VIII. Reexamination of equivocal results. Environ Mol Mutagen 19:227–234.1572346
*Matsui S Yamamoto R, Yamada H. 1989. The bacillus subtilis/microsome ret-assay for the detection of DNA damaging substances which may occur in chlorinated and ozonated waters. Water Science and Technology 21:875–887.
Matsumura F, Tanaka K. 1984. Molecular basis of neuroexcitatory actions of cyclodiene--type insecticides. In: Narahashi T, ed. San Diego, CA: Cellular and Molecular Neurotoxicology Meeting, August 26-27, 1983. New York, NY: Raven Press, 225–240.
*Mehendale HM. 1977. Chemical reactivity-absorption, retention, metabolism, and elimination of hexachlorocyclopentadiene. Environ Health Perspect 2 1:275–278.
*Meier JR Ringhand HP, Coleman WE, 1985. Identification of mutagenic compounds formed duringchlorinationofhumic acid. Mutat Res 157:111–122.3160948
*Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
Mod RR, Magne FC, Skau EL, 1970. Hexachlorocyclopentadiene adducts of unsaturated amides. J Med Chem 13:332–333.5418524
*Morrison RT, Boyd RN. 1983. Organic chemistry. 4th ed. Allyn and Bacon, Inc. 32: 1182-l 184.
*Morse DL, Kominsky JR, Wisseman CL, 1979. Occupational exposure to hexachlorocyclopentadiene. How safe is sewage? JAMA 20:2177–2179.
*Morselli PL, France-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants Clinical Pharmacokinetics 5:485–527.7002417
*Murray FJ, Schwetz BA, Balmer MF, 1980. Teratogenic potential of hexachlorocyclopentadiene in mice and rabbits. Toxicol Appl Pharmacol 53:497–500.7385246
*Nagelsmit A, Van Vliet PW, Van der Wiel-Wetzels WA, 1979. Porphyrins as possible parameters for exposure to hexachlorocyclopentadiene, allychloride, epichlorohydrin and endrin. In: Strik JJ, Koeman JH, eds. Chemical porphyria in man. Amsterdam, NY: ElsevierNorth-Holland Biomedical Press, 55–61.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC. National Academy Press, 15–35.
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Research Council. Board of Environmental Studies and Toxicology. Committee on Biological Markers. 15–35.
*NATICH. 1992. NATICH data base report of federal, state, and local air toxics activities. National Air Toxics Information Clearinghouse. September 1992.
New York State Department of Health. 1989. Health assessment for S-area landfill/Hooker, Niagara Falls, New York, Region 2. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB90-138785.
*NIOSH. 1985. Hexachloro-1,3-cyclopentadiene - method 25 18. In: NIOSH manual of analytical methods. Cincinnati, OH: National Institute for Occupational Safety and Health, 2518-I-25 18-4.
*NIOSH. 1992. NIOSH recommendations for occupational safety and health. Compendium of policy documents and statements. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control. National Institute for Occupation Safety and Health. Division of Standards Development and Technology Transfer. Cincinnati, Ohio. January 1992.
NIOSH. 1994. Pocket guide to chemical hazards. U. S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health.
*NIOSH. 1997. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services. Public Health Services. Centers for Disease Control and Prevention National Institute for Occupation Safety and Health. June 1997.
NRC. 1978. Kepone/mirex/hexachlorocyclopentadiene: an environmental assessment. National Research Council. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Ecological Effects, Office of Research and Development. PB-280 289.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington DC: National Academy Press.
*NTP. 1993. National Toxicology Program. Toxicology and carcinogenesis studies of hexachloro-cyclopentadiene (CAS No. 77-47-4) in F344 rats and B6C3Fl mice. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NTP TR 437. NIH Publication No. 93-3168.
*NTP. 1994. National Toxicology Program. Toxicology and carcinogenesis studies of hexachlorocyclopentadiene (CAS No. 77-47-4) in F344 rats and B6C3Fl mice. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. Final Copy.
*NTP. 1998. National Toxicology Program. Eighth report on carcinogens. 1998 Summary. U.S. Department of Health and Human Services. Public Health Services.
*Nubbe ME, Adams VD, Moore WM. 1995. The direct and sensitized photo-oxidation of hexachlorocyclopentadiene. Water Research 29(5):1287–1293.
*OSHA. 1974. Toxic and hazardous substances. Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1989. Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Federal Register. 54 FR 2332. January 19, 1989.
*OSHA. 1989. Occupational Safety and Health Administration: Federal Register 54:2923–2960.
*OSHA. 1993. Air contaminants. U.S. Department of Labor. Occupational Safety and Health Administration. Federal Register. 58 FR 35338. June 30, 1993.
*OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
*Otson R, Williams DT. 1981. Evaluation of a liquid-liquid extraction technique for water pollutants. J Chromatogr 212:187–197.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: Saunders, 222–238.
*Pankow JR, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column crytotrapping. Environmental Science Technology 22:398–405.
Peters JA, Tackett KM, Eimutis EC. 1981. Measurement of fugitive hydrocarbon emissions from a chemical waste disposal site. Philadelphia, PA: Air Pollution Control Association 8 l-41.1:2–12.
*Podowski AA, Feroz M, Mertens P, 1984. HPLC analysis of organochlorines using UV and radioactivity flow detectors. Bull Environ Contam Toxicol 32:301–309.6713123
*Podowski AA, Khan M AQ. 1996, Hydrolysis and photolysis of hexachlorocyclopentadiene. Archives of Environmental Contamination and Toxicology 30(1):21–29.
*Podowski AA, Khan MA. 1984. Fate of hexachlorocyclopentadiene in water and goldfish. Arch Environ Contam Toxicol 13:47 l-48 1.
*Podowski AA, Sclove SL, Pilipowicz A, 1991. Biotransformation and disposition of hexachlorocyclopentadiene in fish. Arch Environ Contam Toxicol 20:488–496.2069422
Que Hee SS, Igwe OJ, Clark CS. 1987. Thioether excretion of workers in a wastewater facility receiving pesticide wastes. In: Ho MH, Dillon HK, eds. Biological monitoring of exposure to chemicals. New York, NY: John Wiley and Sons, 219–225.
*Rand GM, Nees PO, Calo CJ, 1982a. Effects of inhalation exposure to hexachlorocyclopentadiene on rats and monkeys. J Toxicol Environ Health 9:743–760.7120508
*Rand GM, Nees PO, Calo CJ, 1982b. The Clara cell: An electron microscopy examination of the terminal bronchioles of rats and monkeys following inhalation of hexachlorocyclopentadiene. J Toxicol Environ Health 1059–72.
Ribick MA, Zajicek J. 1983. Gas chromatographic and mass spectrometric identification of chlordane components in fish from Manoa stream, Hawaii. Chemosphere 12: 1229– 1242.
Root MS, Rodwell DE, Goldenthal ET. 1983. Teratogenic potential of hexachlorocyclopentadiene in rats. Toxicologist 3:66.
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: a review. Am Ind Hyg Assoc J. 47:A142–A15 1.3706135
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Chapter 6 in Handbook of physiology: Endocrinology V (Creep RO, Astwood EB (eds); Geiger SR (executive ed.). American Physiological Society, Washington DC.
*Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs) database update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA/600/3-88/010a.
*Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environmental Science and Technology 12:1381–1388.
*Shear NM, Schmidt CW, Huntley SL, 1996. Evaluation of the factors relating combined sewer overflows with sediment contamination of the lower Passaic River. Marine Pollution Bulletin 32(3):288–304.
*Shindell S, Ulrich S. 1986. Mortality of workers employed in the manufacture of chlordane: An update. J Occup Med 28:497–50 1.3734918
Sinhaseni P, D’Alecy LG, Hartung R, 1983. Respiratory effects of hexachlorocyclopentadiene on intact rainbow trout (Salmo gairdneri) and on oxidative phosphorylation of isolated trout heart mitochondria. Toxicol Appl Pharmacol 67:2 15-223.
Sovocool GW, Lewis RG, Harless RL, 1977. Analysis of technical chlordane by gas chromatography/mass spectrometry. Anal Chem 6:734–740.
Specker B, Gartside PS, Meyer C, 1981. Epidemiologic investigation of the health effects associated with drinking water contaminated by leachate from a pesticide waste dump. Society for Epidemiologic Research. Am J Epidemiol 114:449.
*Spehar RL, Veight GD, DeFoe DL, 1979. Toxicity and bioaccumulation of hexachloro-cyclopentadiene, hexachloronorbornadiene and heptachloronorbornene in larval and early juvenile fathead minnows, pimephales promelas. Bull Environ Contam Toxicol 2 1:576–583.
*Spehar RL, Veith GD, DeFoe DL, 1977. A rapid assessment of the toxicity of three chlorinated cyclodiene insecticide intermediates to fathead minnows. Duluth, MN: U.S. Environmental Protection Agency, Office of Research and Development, EPA-600/3-77-99, August 1977.
*SRI International. 1997. 1997 Directory of Chemical Producers - United States of America. Menlo Park, CA: Stanford Research Institute International, 660.
Stanker LH, Watkins B, Vanderlaan M, 1991. Analysis of heptachlor and related cyclodiene insecticides in food products. In: Vanderlaan M, Stauker LH, Watkins BE, eds. ACS Symposium Series 45 1. Immunoassays for trace chemical analysis. Washington, DC: American Chemical Society. 10:109–122.
*Staples CA, Werner AF, Hoogheem TJ. 1985. Environmental chemistry: assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4: 13l- 142.
Stemrnler EA, Hites RA. 1985. Methane enhanced negative ion mass spectra of hexachlorocyclopentadiene derivatives. Anal Chem 57:684–692.
*Stevens JE. 1979. Chlorinated derivatives of cyclopentadiene. In: Kirk-Othmer encyclopedia of chemical technology, vol. 5, third edition, 791–797.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Bradford Communications Corporation, Beltsville, MD.
*Suffet IH, Brenner L, Cairo PR. 1980. GCh4S identification of trace organics in Philadelphia drinking waters during a 2-year period. Water Research 14:853–867.
*Tabak HH, Quave SA, Mashni CI, 1981. Biodegrability studies with organic priority pollutant compounds. J Water Pollut Control Fed 10:1503–1518.
*Thuma NK, O’Neill PE, Brownlee SG, 1983. Microbial degradation of selected hazardous materials: pentachlorophenol, hexachlorocyclopentadiene, and methyl parathion. Cincinnati, OH: Office of Research and Development. PB84-123934.
*Treon JF, Cleveland FP, Cappel J. 1955. The toxicity of hexachlorocyclopentadiene. Industrial Health 459–472.
*TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI96. 1998. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Trussell AR, Moncur JG, Lieu FY, 1983. New developments in dynamic headspace analysis of halogenated organics. Water Chlorination 582–592.
*U.S. Congress. 1990. Clean Air Act (CAA) Amendment. Title III: National Emission Standards for Hazardous Air Pollutants. U.S. Congress. Public Law 101-549. November 15, 1990.
Uk S, Himel CM, Dirks TF. 1972. Mass spectral pattern of mirex (dodecachlorooctahydro-1,3,4-metheno-2H-cyclobuta [cd] pentalene) and of kepone (decachlorooctahydro-1,3,4-metheno-2H-cyclobuta [cd]-pentalene-2-one), and its application in residue analysis. Bull Environ Contam Toxicol 7:207–215.4669488
*USITC. 1991. Synthetic organic chemicals. United States production and sales, 1990. Washington, DC: U.S. International Trade Commission, Publication No. 2470.
Valkenburg CA, Munslow WD. 1989. Evaluation of modifications to extraction procedures used in analysis of environmental samples from superfund sites. J Assoc Off Anal Chem 72602–608.
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 726.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2El in the human liver: hypermethylation control of gene expression during the neonatal period. European Journal of Biochemistry 238:476–483.8681961
Walker JD. 1990. Review of chemical fate testing conducted under Section 4 of the Toxic Substances Control Act: chemicals, tests, and methods. In: Landis WG, Van der Schalie WH, eds. Aquatic toxicology and risk assessment: Vol 13. Aquatic Toxicol 13:77–90.
*Wang HH, MacMahon B. 1979. Mortality of workers employed in the manufacture of chlordane and heptachlor. J Occup Med 21:745–748.556268
*Weast RC. 1989. CRC handbook of chemistry and physics. Weast RC, ed. 66th ed. Boca Raton, FL: CRC Press.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J. of Pediatrics 32a: lo- 18.
*WHO. 1991. World Health Organization. Hexachlorocyclopentadiene health and safety guide. World Health Organization: Geneva, Switzerland.
*WHO. 1996. Guidelines for drinking-water quality. Second Edition. Volume 2. Health criteria and other supporting information. World Health Organization. Geneva. 1996.
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar C.L. and Felix Bronner, eds. Mineral metabolism: An advanced treatise, Volume II - the elements part A. New York, NY: Academic Press.
*Wieboldt RC, Adams GE, Later DW. 1988. Sensitivity improvement in infrared detection for supercritical fluid chromatography. Anal Chem 60:2422–2427.
Williams GM. 1979. Liver cell culture systems for the study of hepatocarcinogenesis. Ann N Y Acad Sci 349:273–280.
Williams GM. 1980. Classification of gentoxic and epigenetic hepatocarcinogens using liver culture assays. Ann N Y Acad Sci 349:273–282.6939363
*Wolfe NL, Zepp RG, Schlotzhauer P, 1982. Transformation pathways of hexachlorocyclopentadiene in the aquatic environment. Chemosphere 11:9 l- 101.
*Yao CC, Haag WR. 1991. Rate constants for direct reactions of ozone with several drinking water contaminants. Water Research 7:761–733.
*Youngren SH, Rachman NJ, Turnbull D. 1991. Risk assessment for children playing on lawns treated with a pesticide. In: Garrick BJ, Gekler WC, eds. The analysis, communication and perception of risk. New York, NY: Plenum Press, 77–86.
*Yu CC, Atallah YH. 1981. Pharmacokinetics and metabolism of hexachlorocyclopentadiene in rats. Velsicol Chemical Corporation.
*Yurawecz MP, Puma BJ. 1986. Gas chromatographic determination of electron capture sensitive volatile industrial chemical residues in foods, using AOAC pesticide multiresidue extraction and cleanup procedures. J Assoc Off Anal Chem 6980–86.
*Ziegler EE, Edwards BB, Jensen RL 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372