# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Hexachlorocyclopentadiene (HCCPD) is a yellow to yellow-green dense oily liquid with a pungent odor. It is used as an intermediate in the manufacture of pesticides, flame-retardant materials, and some plastics. Information regarding the chemical identity of HCCPD is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

HCCPD is slightly soluble in water and will react slowly with water to form hydrochloric acid (HSDB 1998). It is a corrosive chemical, and contact can burn the eyes and skin. While HCCPD itself does not burn, it may decompose upon heating to produce toxic fumes (HSDB 1998). Information regarding the physical and chemical properties of HCCPD is located in Table 3-2.

Table 3-1 Chemical Identity of HCCPD

Characteristic | Information | Reference
Chemical name | Hexachlorocyclopentadiene | HSDB 1998
Synonym(s) | HCCPD; 1,3-cyclopentadiene; 1,2,3,4,5,5-hexachloro-; hex; perchlorocyclopentadiene | HSDB 1998
Registered trade name(s) | C-56; graphlox; HRS 1655
Chemical formula | C_5_Cl_6_ | HSDB 1998
Chemical structure | [image] | Verschueren 1983
Identification numbers:
CAS registry | 77-47-4 | HSDB 1998
NIOSH RTECS | G Y1225000 | HSDB 1998
EPA hazardous waste | U130 | HSDB 1998
OHM/TADS | 7800117 | HSDB 1998
DOT/UN/NA/IMCO shipping | UN2646 IMCO 6.1 | HSDB 1998
HSDB | 4011 | HSDB 1998
NCI | C55607 | HSDB 1998

CAS = Chemical Abstracts Service; DOT/UN/NA/IMO = Dept. of Transportation/United Nations/ North America/lnternational Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of HCCPD

Property | Information | Reference
Molecular weight | 272.77 | Weast 1989
Color | Lemon yellow/yellow-green | EPA 1991a
Physical state | Liquid | EPA 1991a
Melting point | −9 °C | Weast 1989
Bolling point at 753 mm Hg | 239 °C | Weast 1989
Density at 25 °C | 1.7019 g/mL | Weast 1989
Odor | Pungent | EPA 1991a
Odor threshold:
Water | 0.0014–0.0074 mg/L | Amoore and Hautala 1983; Verschueren 1983
Air | 0.03 ppm (0.34 mg/m^3^) | Amoore and Hautala 1983
| 1.5–3.3 mg/m^3^ | Ruth 1986
Solubility:
Water at 25 °C | 2.1 mg/L | EPA 1991a
| 1.03–1.25 mg/L | WHO 1991
Organic solvents | Miscible in acetone carbon tetrachloride, methanol, hexane | ACGIH 1992
Partition coefficients:
Log K_ow_ | 4.0–5.04 | Mabey et al 1982; Wolfe et al. 1982
Log K_oc_ | 3.68–4.08 | Mabey et al. 1982; Wolfe et al. 1982
Vapor pressure at 25 °C | 0.08 mm Hg | Verschueren 1983
Henry’s law constant
at 24.8 °C | 2.7×10^−2^ atm-m^3^/mol | Wolfe et al. 1982
Autoignition temperature | No data
Flashpoint | No data
Flammability limits | No data
Conversion factors: | 1 ppm = 11.3 mg/m^3^; 1 mg/m^3^ = 0.088 ppm | WHO 1991
Explosive limits | No data