# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-4991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Hexachlorocyclopentadiene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name(s): | Hexachlorocyclopentadiene
CAS number(s): | 77-47-4
Date: | January 15, 1999
Profile status: | Final Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 44
Species: | rat

MRL: 0.01 [ ] mg/kg/day [X] ppm [ ] mg/m^3^

[underlined: Reference:] Rand GM, Nees PO, Calo CJ, 1982b. The Clara cell. An electron microscopy examination of the terminal bronchioles of rats and monkeys following inhalation of hexachlorocyclopentadiene. J Toxicol Environ Health 10:59–72.7131590

[underlined: Experimental design:] Groups of Sprague-Dawley rats (3/dose) were exposed to HCCPD vapors for up to 14 weeks (6 hours/day, 5 days/week). Doses of 0.01, 0.05, and 0.2 ppm were used. Following exposure, animals were sacrificed and lung tissue prepared for histological examination using light and electron microscopy. No other parameters were measured.

[underlined: Effects noted in study and corresponding doses:] A statistically significant (p<0.01) dose--related increase in the number of electron-lucent inclusions in Clara cells in the lungs was reported at all exposure levels following electron microscopic examination. Light microscopy did not reveal treatment--related histopathological lesions of the lungs.

[underlined: Dose and endpoint used for MRL derivation:] A concentration of 0.2 ppm was used to derive the MRL, based on the presence of effects on the Clara cells of the lungs. Clara cells are nonciliated epithelial cells located in the terminal bronchiole region. The response of the Clara cells was considered to be an adaptive response to the exposure to inhaled toxicants, since Clara cells contain mixed function oxidases and are responsible for detoxifying inhaled chemicals. Thus, Clara cells are biomarkers of exposure, and not effect. This concentration was not normalized due to the chemical activity of HCCPD and its tendency to form lesions in directly exposed tissues.

[X ] NOAEL [] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a minimally adverse LOAEL)

[ ] 1 [X] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/bodv weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

The intermediate inhalation MRL for HCCPD is derived as follows.

- VE_a_ = (0.25 m^3^/d)^a^ x (1000 L/m^3^) x (ld/24 hr) x (1 hr/60 min) x (1000 mL/L) = 170 mL/min
  a Average inhalation rate for male and female Sprague-Dawley rats for subchronic duration.
- VE_h_ = (20 m^3^/d)^b^ x (1000 L/m^3^) x (ld/24 hr) x (1 hr/60 min) x (1000 mL/L) = 13800 mL/min
  b Average inhalation rate for humans.
- RGDR_[PU]_^c^ = (VE/SA_PU_)_A_/(VE/SA_pu_)_h_ = (170 mL/min/0.34 m^3^)/(13800 mL/min/54 m^3^) = 1.95
  c Derived from equation 4-28 of EPA 1994 (EPA/600/8-90-066F).
- NOAEL_Hec_ = NOAEL x RGDR = 0.2 ppm x 1.95 = 0.39 ppm
- MRL = NOAEL_Hec_ ÷ UF
- MRL = 0.4 ppm ÷ 30
- MRL = 0.01 ppm

[underlined: Was a conversion used from intermittent to continuous exposure?] No. A conversion factor was not used to adjust for intermittent exposure due to the corrosive nature of HCCPD. The chemical exerts a direct contact effect, and the effects are concentration- rather than time-dependent.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Treon JR, Cleveland FP, Cappel J, 1955. The toxicity of hexachlorocyclopentadiene. Arch Ind Health 11:459–472.

Groups of mice (5), guinea pigs (2), rats (4), and rabbits (3) were exposed to vapors of HCCPD (0.13 ppm, 7 hours/day, 5 days/week, generated from 89.5% pure HCCPD) for 30 weeks. Following exposure, clinical signs and survival were monitored. Gross necropsy was performed. Pulmonary edema and bronchitis were reported in mice. Compound exposure was associated with pneumonia in rats and guinea pigs. Comparable effects were not seen in rabbits survival was not affected following compound exposure in rabbits, rats, and guinea pigs. On the other hand, mice were more sensitive to HCCPD toxicity, with death occurring in 4 of 5 mice.

Rand GM, Nees PO, Calo CJ, 1982a. Effects of inhalation exposure to hexachlorocyclopentadiene on rats and monkeys. J Toxicol Environ Health 9:743–760.7120508

Groups of Sprague-Dawley rats (40/sex/dose) were exposed to vapors of HCCPD at concentrations of 0, 0.01, 0.05, or 0.20 ppm for 90 days (up to 14 weeks) (6 hours/day, 5 days/week). Following exposure, clinical signs, food and water consumption were monitored daily, and body weights were recorded weekly during the treatment period. Standard blood chemistry, hematologic, and urinalysis parameters were evaluated. Gross necropsy was performed and organ weights (adrenal, brain, heart, kidneys, liver, lungs, ovaries, pituitary, spleen, testes, thyroid, and uterus) were determined. Histopathological examinations of major organs were performed at 4, 8, and after 13 weeks in the control and high-dose groups. There was a slight marginal increase in hemoglobin, red blood cell count, and mean corpuscular hemoglobin concentration and a decrease in mean cell volume at concentrations of 0.01 (males), 0.05 (females), and 0.2 (both sexes) ppm after 12 weeks exposure to the compound. These changes may represent a compensatory response to impaired oxygen transport and thus provide some support for impaired lung function. Adverse clinical signs (dark red eyes) were evident at concentrations of 0.05 pm or greater; however, these effects were reversible after day 20 of the 90-day exposure period. Liver weights were reduced in both sexes at all exposure levels, and kidney weights were reduced in males at comparable exposure levels. Otherwise, the compound did not cause adverse effects under conditions of this study. Food and water consumption and body weight gain were comparable in exposed and control groups. No treatment-related deaths were reported. Clinical chemistry and urinalysis did not differ significantly from controls. No gross or histopathological lesions were found.

In a separate portion of this study, 5 male and 5 female rats were exposed to 0.5 ppm HCCPD vapor for 5 days (6 hours/day) and allowed to recover for up to 21 days. Another 10 rats of each sex were exposed to this same concentration for up to 2 weeks (6 hours/day, 5 days/week) with no recovery period. All of the males and 2 females exposed for 2 weeks died. There was bronchial erosion of the epithelium, hyperplastic changes in the cuboidal and columnar cells of the epithelium, inflammatory cell infiltration, and fibroblastic proliferation in the lungs of the treated animals. After 7 days for males and 10 days for females, there were significant increases in packed cell volume, hemoglobin concentration and erythrocyte count which were hypothesized to be a compensatory response for impaired lung function.

Three males from the recovery group died with 7 days of their fifth and last exposure, but all the females and two males survived. The histopathologic changes in the lung of the recovery group survivors were resolved when the animals were examined after sacrifice at the end of the recovery period.

Rand et al. (1982a) also studied the effects of inhalation exposure to HCCPD on monkeys. Groups of cynomolgous monkeys (6/sex/dose) were exposed to vapors of HCCPD at concentrations of 0, 0.01, 0.05, or 0.2 ppm for 13 weeks. Following exposure, clinical signs, and food and water consumption were monitored daily and body weights were recorded weekly during the treatment period. Blood chemistry, hematological and urinalysis parameters were evaluated. Gross necropsy was performed and organ weights (adrenals, brain, heart, kidneys, liver, lungs, ovaries, pituitary, spleen, testes, thyroid, and uterus) were determined. Histopathological examination was performed on the following organs or tissues after 13 weeks in the control and high-dose groups: adrenals, aorta, brain, eye, heart, esophagus, stomach, intestine, kidneys, larynx, liver, lungs, nasal turbinates, ovaries, lymph nodes, spleen, urinary bladder, pancreas, pituitary, prostate, uterus, seminal vesicles, skeletal muscle, trachea, testes, thymus, thyroid, parathyroid, sciatic nerve and salivary gland. No mortalities or adverse clinical signs were reported. Body weight and food consumption were comparable in exposed and control groups. No treatment-related effects on tissue weight were reported and the compound did not cause any gross or histopathological lesions in any tissues examined. Pulmonary function tests (e.g., lung mechanics, pulmonary ventilation, and blood gas analysis) were comparable in exposed and control groups. Erythrocyte sedimentation rate, packed cell volume, hemoglobin, red blood cell count, reticulocyte count, mean corpuscular hemoglobin concentration, mean cell volume, total white blood cell count, differential count and clotting time were comparable in exposed and control groups. Blood chemistry parameters (serum urea, total protein, albumin, cholesterol, creatinine, alkaline phosphatase, alanine aminotransferase, aspartate aminotransferase and lactate dehydrogenase) were comparable in exposed and control groups. Urine parameters (volume, pH, specific gravity, protein, reducing substances, glucose, ketones, bile pigments, urobilinogen and hemoglobin) were comparable in exposed and control groups.

In a separate experiment, groups of cynomologous monkeys were exposed to HCCPD vapors for up to 14 weeks. Animals (3M, 3F) from each treatment group were evaluated to determine the effects of the compound on the lungs, especially ultrastructural changes in Clara cells of the terminal bronchioles of the lungs. Except in one monkey, the compound did not cause histopathological lesions in the terminal bronchioles under the conditions of this study. Inclusions in the Clara cells were noted in one monkey. Since the Clara cells of the terminal bronchioles contain detoxifying enzymes and function to eliminate inhaled toxicants, the appearance of inclusion bodies is considered to be an indication of exposure, and not a sign of toxicity.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.

## Hexachlorocyclopentadiene Chronic Inhalation

MINIMAL RISK LEVEL WORKSHEET

Chemical name(s): | Hexachlorocyclopentadiene
CAS number(s): | 77-47-4
Date: | January 15,1999
Profile status: | Final Draft
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Species: | rat
Key to figure: | 71

MRL: 0.0002 [ ] mg/kg/day [X] ppm [ ] mg/m^3^

[underlined: Reference:] NTP. 1994. National Toxicology Program. Toxicology and carcinogenesis studies of hexachlorocyclopentadiene (CAS No. 74-47-4) in F344 rats and B6C3F1 mice. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NTP TR 437. NIH Publication No. 93-3168.

[underlined: Experimental design:] Groups of 50 male and 50 female rats were exposed to concentrations of 0, 0.01, 0.05, or 0.2 ppm HCCPD for 6 hours/day, 5 days/week for 2 years. At sacrifice, the tissues were examined for the occurrence of tumors and histological abnormalities.

[underlined: Effects noted in study and corresponding doses:] Yellow-brown pigmentation of the nose, trachea, and/or lungs was noted at sacrifice. At the lowest dose tested, 68% of the exposed females had pigmentation in the nasal epithelium; 0%, in the trachea; and 50% in the bronchioles. In males, 92% had pigmentation in the nasal epithelium; 0%, in the trachea; and 0% in the bronchioles. Although the number of affected animals and the severity of the pigmentation increased with dose, there was no clear dose-response trend. The occurrence of pigmentation apparently had little effect on survival based on a comparison of the Kaplan-Meier survival curves for the exposed and control animals. Chemical evaluation of the pigment indicated that it was a reducing substance and may have been either a ceroid or lipofuscin deposit. The 0.01 ppm dose was identified as the LOAEL in this study.

[underlined: Dose endpoint used for MRL derivation:] The 0.01 ppm LOAEL was selected as the basis for the MRL derivation. Exposure to this concentration of HCCPD for 6 hours/day, 5 days/week for 2 years resulted in the formation of yellow-brown pigment in the nasal, tracheal, and/or bronchial epithelium.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [X] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [X] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/bodv weight dose?]

If so, explain: NA

If an inhalation study in animals, list conversion factors used in determining human equivalent dose:

The chronic inhalation MRL for HCCPD is derived as follows.

- VE_A_ = (0.3 m^3^/d)^a^ x (1000 L/m^3^) x (ld/24 hr) x (1 hr/60 min) x (1000 mL/L) = 170 mL/min
  a Average inhalation rate for male and female F344 rats for chronic duration.
- RGDR_[PU]_^b^ = (VE/SA_PU_)_A_/(VE/SA_pu_)_h_ = (210 mL/min/0.34 m^3^)/(13800 mL/min/54 m^3^) = 2.4
  b Derived from equation 4-28 of EPA 1994 (EPA/600/8-90-066F).
- LOAEL_HEC_ = LOAEL x RGDR = 0.01 ppm x 2.4 = 0.02 ppm
- MRL = LOAEL_HEC_ ÷ UF
- MRL = 0.02 ppm ÷ 90
- MRL = 0.0002 ppm

[underlined: Was a conversion used from intermittent to continuous exposure?] No. A conversion factor was not used to adjust for intermittent exposure due to the corrosive nature of HCCPD. The chemical exerts a direct contact effect, and the effects are concentration- rather than time-dependent.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] NTP. 1994. National Toxicology Program. Toxicology and carcinogenesis studies of hexachlorocyclopentadiene (CAS No. 74-47-4) in F344 rats and B6C3F1 mice. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NTP TR 437. NIH Publication No. 93-3168.

Groups of 50 male and 50 female mice were exposed to concentrations of 0, 0.01, 0.05, or 0.2 ppm HCCPD for 6 hours/day, 5 days/week for 2 years. At sacrifice, the tissues were examined for the occurrence of tumors and histological abnormalities.

Yellow-brown pigmentation of the epithelium of the nose, trachea, and/or lungs was noted at sacrifice. At the lowest dose tested, 90% of the exposed males had pigmentation in the nasal epithelium; 58% had pigmentation in the trachea; and 4% had pigmentation in the lungs. In females, 80% had pigmentation in the nasal epithelium; 12% had pigmentation in the trachea; and 0% had pigmentation in the lings. Although the number of affected animals and the severity of the pigmentation increased with dose, there was no clear dose-response trend.

In a separate component of the NTP (1994) bioassay, groups of male mice were exposed to concentrations of 0.2 ppm HCCPD for 33 or 66 weeks, or to 0.5 ppm for 26 or 42 weeks under parallel exposure conditions (6 hours/day, 5 days/week). The animals were sacrificed at either 104 or 105 weeks and the respiratory tract tissue was examined. Pigmentation was found in the mucosa of the nose, trachea, and lungs of nearly all animals. Any pigmentation that formed in these tissues during exposure was still present 38 to 79 weeks after exposure ceased. The pigment apparently had little effect on survival because there were minimal differences among groups for the percent probability of survival or the number of animals surviving until study termination.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.

## Hexachlorocyclopentadiene Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name(s): | Hexachlorocyclopentadiene
CAS number(s): | 77-47-4
Date: | January 15, 1999
Profile status: | Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 17
Species: | rat

MRL:0.1 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference:] Abdo K, Montgomery CA, Kluwe WM, 1984. Toxicity of hexachlorocyclopentadiene: subchronic (13-week) administration by gavage to F344 rats and B6C3F1 mice. J Appl Toxicol 4(2):75–81.6736554

[underlined: Experimental design:] Groups of F344 rats (10/sex/dose) were administered HCCPD (0, 10, 19, 38, 75, 150 mg/kg/day) in corn oil by gavage, 5 days/week for 13 weeks. Body weights were determined initially and weekly during the treatment period. Clinical signs and mortality were monitored daily. Gross necropsy was performed and organ weights (liver, right kidney, thymus, heart, brain, and lungs) were determined. Histopathological examination was performed on the following organs or tissues after 13 weeks in the control, 75, and 150 mg/kg/day dose groups: skin, mandibular lymph nodes, mammary gland, salivary gland, thigh muscle, sciatic nerve, bone marrow, costochondral junction (rib) thymus, larynx, trachea, lungs and bronchi, heart, thyroid, parathyroid, esophagus, stomach (also at 38, 19, and 10 mg/kg/day), duodenum, jejunum, ileum, colon, mesenteric nodes, liver, pancreas, spleen, kidney (also at 38, 19, and 10 mg/kg/day), adrenal, urinary bladder, seminal vesicle, prostate, testes, ovaries, uterus, nasal cavity, brain, pituitary, and spinal cord.

[underlined: Effects noted in study and corresponding doses:] Nephrosis was evident in both sexes at dose levels of 38 mg/kg/day or greater and effects were confined to the terminal portion of the proximal convoluted tubules in the inner cortex. The lower NOAEL of 10 mg/kg/day for the absence of forestomach lesions was not used as the basis of the MRL because humans do not possess a forestomach. Kidney weights were not affected. Because the batch of HCCPD used in the study also contained hexachlorobutadiene (0.5%) as and impurity, there may be some synergistic effect between the two chemicals at the highest doses. Forestomach hyperplasia was reported in females at dose levels of 19 mg/kg/day or greater. This effect was also seen in male rats, but occurred at doses of 38 mg/kg/day or greater. Focal inflammation of the forestomach was also observed in females (19 mg) and males (38 mg). Although the number of animals with inflammation increased in the exposed group compared to controls, it should be noted that the incidence of this lesion shoed a weak dose-related trend among the treatment groups. Ulcerations were detected in males in the 38 and 75 mg/kg/day dose groups, but were not reported in the high-dose group or in controls. No ulcerations were seen in female rats. Ruffled fur and inactivity occurred at dose levels of 75 mg, otherwise clinical signs were comparable in exposed and control groups, body weight was reduced a dose levels of 38 mg.

[underlined: Dose endpoint used for MRL derivation:] A NOAEL of 19 mg/kg/day was used to derive the MRL, based on the absence of effects on the kidneys. This dose was converted to 13.6 mg/kg/day, incorporating adjustments for intermittent exposure (5 days/week).

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/bodv weight dose?]

If so, explain: NA

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] If so, explain: 0.19 mg/kg/day x 5/7 = 0.1357 mg/kg/day

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Abdo K, Montgomery CA, Kluwe WM, 1984. Toxicity of hexachlorocyclopentadiene: subchronic (13-week) administration by gavage to F344 rats and B6C3F1 mice. J Appl Toxicol 4(2):75–81.6736554

Groups of B6C3F1 mice (10/sex/dose) were administered HCCPD (0, 19, 38, 75, 150 mg/kg/day) in corn oil by gavage. Body weights were determined initially and weekly during the treatment period. Clinical signs and mortality were monitored daily. Gross necropsy was performed and organ weights (liver, right kidney, thymus, heart, brain, and lungs) were determined. Histopathological examination was performed on the following organs or tissues after 13 weeks in the control, 150, and 300 mg/kg/day dose groups: skin, mandibular lymph nodes, mammary gland, salivary gland, thigh muscle, sciatic nerve, bone marrow, costochondral junction (rib) thymus, larynx, trachea, lungs and bronchi, heart, thyroid, parathyroid, esophagus, stomach (also at 38, 19, and 10 mg/kg/day), duodenum, jejunum, ileum, colon, mesenteric nodes, liver, pancreas, spleen, kidney (also at 38, 19, and 10 mg/kg/day), adrenal, urinary bladder, seminal vesicle, prostate, testes, ovaries, uterus, nasal cavity, brain, pituitary, and spinal cord.

Hyperplasia and inflammation of the forestomach were reported in both females (2/9, 22%) and males (2/10, 20%) at 38 mg/kg/day and also occurred at dose levels of 75 mg when compared to untreated controls. Although the number of animals showing forestomach lesions in he treated group was increased over untreated control levels, the incidence among all exposed groups showed a weak dose-related trend. Ulcerations were not observed in the control or exposed group (except at the high-dose in both sexes). There were also treatment-related lesions of the kidneys. Toxic nephrosis was observed in female mice at dose levels of 75 mg; kidney weights were not affected. Histopathological lesions were not seen in other organs, nor were there changes in organ weights. Clinical signs were comparable in exposed and control mice, except that ruffled fur and slight inactivity occurred at dose levels of 150 mg. Body weights were reduced at dose levels of 150 mg. Forestomach lesions appear to be the most sensitive end point under conditions of this study. A NOAEL of 19 mg/kg/day is identified for this study based oh this end point.

[underlined: Agency Contact (Chemical Manager):] Carolyn Harper, Ph.D.