# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Carolyn Harper, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Lisa Ingerman, Ph.D., DABT
  Laura McIlroy, B.S.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA, National Center for Environmental Assessment.

## PEER REVIEWERS

1. Wei-Hsiang Chen, Ph.D., Associate Professor, Institute of Environmental Engineering, National Sun Yat-sen University
2. Shane Que Hee, Ph.D., Associate, Department of Environmental Health Sciences, University of California, UCLA, UCLA Fielding School of Public Health
3. James V. Bruckner, Ph.D., Professor of Pharmacology & Toxicology, Department of Pharmaceutical & Biomedical Sciences, College of Pharmacy, University of Georgia, Athens, Georgia

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.