# VERSION HISTORY

Date | Description
March 2021 | Final toxicological profile released
December 2019 | Draft for public comment toxicological profile released
December 2012 | Addendum to the toxicological profile released
May 1994 | Final toxicological profile released