# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding hexachlorobutadiene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for hexachlorobutadiene.

Table 7-1 Regulations and Guidelines Applicable to Hexachlorobutadiene

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 1993
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
| 1-Day health advisory | 0.3 mg/L
| 10-Day health advisory | 0.3 mg/L
| DWEL | 0.01 mg/L
| Lifetime health advisory | No data
| 10^−4^ Cancer risk | 0.09 mg/L
| National primary drinking water regulations | Not listed | EPA 2009
| RfD | Withdrawn | IRIS 1993
| Provisional chronic and subchronic RfD | 0.001 mg/kg/day | EPA 2007
WHO | Drinking water quality guidelines | | WHO 2017
| Guideline value | 0.0006 mg/L (0.6 gg/L)
| TDI | 0.2 μg/kg body weight
FDA | Substances added to food^a^ | No data | FDA 2020
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | C^b^ | IRIS 1993
IARC | Carcinogenicity classification | Group 3^c^ | IARC 1999
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | No data | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | 0.02 ppm (0.24 mg/m^3^)^d,e^ | NIOSH 2016
| IDLH | No data^e^
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
| PAC-1^f^ | 1 ppm
| PAC-2^f^ | 3 ppm
| PAC-3^f^ | 10 ppm

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b C: possible human carcinogen.

c Group 3: not classifiable as to its carcinogenicity to humans.

d Skin notation.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentrations; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TDI = tolerable daily intake; TWA = time-weighted average; WHO = World Health Organization