# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of hexachlorobutadiene is located in Table 4-1.

Table 4-1 Chemical Identity of Hexachlorobutadiene

Characteristic | Information | Reference
Chemical name | Hexachlorobutadiene | Montgomery and Welkom 1990
Synonym(s) and registered trade name(s) | Perchlorobutadiene; HCBD; 1,1,2,3,4,4-Hexachloro-1,3-butadiene; 1,3-Hexachlorobutadiene; Dolen-Pur; GP-40-66:120 | Montgomery and Welkom 1990; NLM 2020
Chemical formula | C_4_Cl_6_ | Montgomery and Welkom 1990
Chemical structure | [image] | Montgomery and Welkom 1990
CAS Registry Number | 87-68-3 | Montgomery and Welkom 1990

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of hexachlorobutadiene is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Hexachlorobutadiene

Property | Information | Reference
Molecular weight | 260.76 | Montgomery and Welkom 1990
Color | Colorless | NLM 2020
Physical state | Liquid | Montgomery and Welkom 1990
Melting point | −21°C | Montgomery and Welkom 1990
Boiling point | 215°C | Montgomery and Welkom 1990
Density at 20°C | 1.55 g/cm^3^ | NLM 2020
Odor | Mild to pungent | Montgomery and Welkom 1990
Odor threshold:
Water | No data
Air | 12.0 mg/m^3^ | Ruth 1986
Solubility:
Water at 20°C | 2–2.55 mg/L | Montgomery and Welkom 1990
Organic solvents | Soluble in ethanol and ether | Montgomery and Welkom 1990
Partition coefficients:
Log K_ow_ | 4.78 | Montgomery and Welkom 1990
Log K_oc_ | 3.67 | Montgomery and Welkom 1990
Vapor pressure at 25°C | 0.15 mmHg | Montgomery and Welkom 1990
Henry’s law constant | 0.001–0.026 atm-m^3^/mol | Montgomery and Welkom 1990
Autoignition temperature | 610°C | NLM 2020
Flashpoint | Noncombustible | Montgomery and Welkom 1990
Flammability limits | Noncombustible | Montgomery and Welkom 1990
Conversion factors | 1 ppm=10.5 mg/m^3^; 1 mg/m^3^=0.095 ppm
Explosive limits | No data