# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for hexachlorobutadiene.

Rationale for Not Deriving an MRL: The acute-duration inhalation database was not considered suitable for derivation of an MRL due to the lack of a repeated exposure study which examined the kidney and serious body weight effects at the lowest concentration (10 ppm) tested in a 5-day study.

Five studies have evaluated the acute toxicity of inhaled hexachlorobutadiene in rats or mice and reported respiratory tract, kidney, body weight, eye, adrenal gland, and nervous system effects; the results of these studies are summarized in Table A-1. In addition to these effects, NIOSH (1981) reported 100% mortality in mice exposed to 50 ppm hexachlorobutadiene for 5 days (7 hours/day).

Table A-1 Summary of Effects Resulting from Acute-Duration Inhalation Exposure to Hexachlorobutadiene

Species | Exposure | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Respiratory effects
Mouse; 6 M | 15 minutes | | 155 | Decreased respiratory rate | de Ceaurriz et al. 1988
Rat; 4 M, 4 F | 4 hours/day; 2 days | | 250 | Nose irritation and respiratory difficulty | Gage 1970
Renal effects
Mouse; NS M | 4 hours | | 2.75 | Histochemical evidence of damaged proximal tubules | de Ceaurriz et al. 1988
Rat; 4 M, 4 F | 4 hours/day; 2 days | | 250 | Degeneration of proximal tubules | Gage 1970
Body weight effects
Rat; 10 M | 7 hours/day; 5 days | | 10* | 57% decrease body weight gain | NIOSH 1981
Mouse; 10 M | 7 hours/day; 5 days | | 10* | Weight loss (4.6% loss between days 1 and 2) | NIOSH 1981
Ocular effects
Rat; 4 M, 4 F | 4 hours/day; 2 days | | 250 | Eye irritation | Gage 1970
Endocrine effects
Rat; 4 M, 4 F | 4 hours/day; 2 days | | 250 | Degeneration in adrenal cortex | Gage 1970
Neurological effects
Rat; 10 M | 7 hours/day; 5 days | 10 | 50 | Animals appeared subdued and showed little response to audio stimuli | NIOSH 1981
Death
Mouse; 10 M | 7 hours/day; 5 days | | 50 (serious LOAEL) | 100% mortality | NIOSH 1981

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = males(s); NOAEL = no-observed-adverse-effect level

The lowest LOAEL identified in the available studies is 2.75 ppm for histochemical evidence of proximal tubule damage in mice (de Ceaurriz et al. 1988). This study is not suitable as the basis of an MRL because it involved a single 4-hour exposure to hexachlorobutadiene and there is considerable uncertainty that the value would be protective of continuous exposure for 14 days. The lowest LOAEL in repeated exposure studies is 10 ppm in rats and mice exposed 7 hours/day for 5 days (NIOSH 1981). However, 10 ppm was categorized as a serious LOAEL for large decreases in body weight gain in rats and weight loss in mice. Additionally, this study did not evaluate the kidney, which is the presumed most sensitive target of toxicity. Given the uncertainty in using a single exposure study and the lack of a repeated exposure study that examined the kidney and identified a NOAEL or less serious LOAEL, the acute-inhalation database was not considered suitable for derivation of an MRL.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for hexachlorobutadiene.

Rationale for Not Deriving an MRL: The intermediate-duration inhalation database was not considered suitable for derivation of an MRL due to the limited number of endpoints examined in the two available studies and the lack of study details reported in the general toxicity study.

Two studies have examined the toxicity of hexachlorobutadiene following intermediate-duration inhalation exposure. In rats exposed to hexachlorobutadiene 6 hours/day, 5 days/week for 15 exposures, Gage (1970) reported decreases in body weight gain at 10 ppm and respiratory difficulty and histological alterations in the renal proximal tubules at 25 ppm. At 100 ppm (animals only exposed 12 times), 50% of the female rats died and anemia and degeneration of the renal cortical tubules were observed. No adverse effects were observed at 5 ppm. The second study is a developmental toxicity study that found decreases in maternal weight gain at ≥5 ppm and decreases in fetal body weight at 15 ppm; no other developmental effects were observed (Saillenfait et al. 1989). The intermediate-duration database was not considered suitable for derivation of an MRL because the two available studies examined a limited number of endpoints; additionally, the general toxicity study (Gage 1970) did not provide information on the magnitude of the body weight changes, description of the renal lesions observed at 25 ppm, incidence data, or statistical analyses.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for hexachlorobutadiene.

Rationale for Not Deriving an MRL: No chronic duration inhalation studies were identified for hexachlorobutadiene.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.006 mg/kg/day
Critical Effect: | Renal proximal tubular degeneration
Reference: | Harleman and Seinen 1979
Point of Departure: | LOAEL of 5.9 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 2
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.006 mg/kg/day was derived for hexachlorobutadiene based on an increased incidence of renal proximal tubule degeneration in rats exposed to hexachlorobutadiene in the diet for 14 days (Harleman and Seinen 1979). The MRL is based on a LOAEL of 5.9 mg/kg/day and a total uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Three studies have evaluated the acute oral toxicity of hexachlorobutadiene. Two studies involved a single gavage dose of hexachlorobutadiene, which resulted in necrosis in the renal proximal tubules in rats exposed to ≥100 mg/kg (Birner et al. 1995; Jonker et al. 1993a); at 200 mg/kg, there was evidence of impaired renal function (increases in blood urea nitrogen, urine volume, urinary protein, and urinary glucose levels) (Jonker et al. 1983a). The third study was a range-finding study that found renal proximal tubule degeneration in male and female rats exposed to 5.9 or 6.2 mg/kg/day, respectively, hexachlorobutadiene in the diet for 14 days (Harleman and Seinen 1979). Decreases in body weight gain (9.5%) were also observed in the female rats exposed to 6.2 mg/kg/day and the male rats exposed to 19 mg/kg/day (21%). The study did not find any histological alterations in the liver of rats exposed to doses as high as 59 or 62 mg/kg/day.

The available acute oral studies identify the kidney as the most sensitive target of hexachlorobutadiene toxicity. Although the studies examined a limited number of potential endpoints, more extensive intermediate-duration studies confirm that the kidney is the most sensitive target of toxicity (Harleman and Seinen 1979; Kociba et al. 1971; NTP 1991; Schwetz et al. 1977).

Selection of the Principal Study: The Harleman and Seinen (1979) study identified the lowest LOAEL for renal effects and was selected as the principal study for the MRL.

Summary of the Principal Study:

Harleman JH, Seinen W. 1979. Short-term toxicity and reproduction studies in rats with hexachloro(1,3)-butadiene. Toxicol Appl Pharmacol 47:1–14.425109

Groups of six male and six female Wistar rats were exposed to 0, 50, 150, or 450 ppm hexachlorobutadiene in the diet for 2 weeks. Doses of 0, 5.9, 19, and 59 mg/kg/day for males and 0, 6.2, 20, and 62 mg/kg/day for females were estimated using reported body weights and EPA’s allometric equation to calculate food intake. Parameters used to assess toxicity included body weight, food consumption, liver and kidney weights, and histopathological examination of the liver and kidney.

Significant decreases in body weight gain were observed in males at 19 and 62 mg/kg/day (21 and 31% of controls, respectively) and in females at 6.2, 20, and 62 mg/kg/day (9.5, 26, and 33% of controls, respectively). Decreases in food intake were also observed; however, decreases in food efficiency (growth/food intake) were only observed at the highest dose. Significant increases in relative kidney weight were observed in the males and females at ≥19 and 20 mg/kg/day; no alterations in relative liver weight were observed. Degeneration of the proximal tubular epithelial cells was observed at all hexachlorobutadiene exposure levels; no alterations were observed in the liver. Although incidence data were not provided, the investigators noted that histological changes were observed in the kidneys of all animals exposed to hexachlorobutadiene.

Selection of the Point of Departure: The lowest LOAEL value of 5.9 mg/kg/day identified for renal effects in males was selected as the point of departure for the MRL; the study did not identify a NOAEL value. The lack of incidence data precluded using benchmark dose modeling to calculate a point of departure.

Uncertainty Factor: The LOAEL of 5.9 mg/kg/day is divided by a total uncertainty factor (UF) of 1,000:

- 10 for the use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability
  - MRL = LOAEL ÷ UFs
  - 5.9 mg/kg/day ÷ (10 × 10 × 10) = 0.006 mg/kg/day

Other Additional Studies or Pertinent Information: No human studies examining the acute oral toxicity of hexachlorobutadiene were identified. In addition to the previously discussed acute studies, a number of intermediate- and chronic-duration oral studies (Harleman and Seinen 1979; Kociba et al. 1971, 1977; NTP 1991; Schwetz et al. 1977) and acute-duration parenteral studies (Boroushaki 2003; Chiusolo et al. 2008; Cristofori et al. 2013; Kirby and Bach 1995; Maguire et al. 2013; Swain et al. 2011; Zanetti et al. 2010) support the identification of the kidney as the most sensitive target of toxicity for hexachlorobutadiene.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.002 mg/kg/day
Critical Effect: | Renal proximal tubular regeneration
Reference: | NTP 1991
Point of Departure: | NOAEL of 0.2 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 13
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.002 mg/kg/day was derived for hexachlorobutadiene based on an increased incidence of renal proximal tubule regeneration in mice exposed to hexachlorobutadiene in the diet for 13 weeks (NTP 1991). The MRL is based on a NOAEL of 0.2 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of hexachlorobutadiene toxicity following intermediate-duration oral exposure. These studies have identified several targets of toxicity including body weight, liver, kidney, nervous system, hematological system, reproductive system, and developing organism. A summary of the lowest LOAEL values for these endpoints is presented in Table A-2. A comparison of the LOAEL values across endpoints supports the identification of the kidney as the most sensitive target of toxicity.

Table A-2 Lowest LOAELs Identified in Intermediate-Duration Oral Studies of Hexachlorobutadiene

Endpoint | Effect | NOAEL^a^ (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 9.9% decrease in body weight gain in mice exposed for 13 weeks | 1.5 | 4.9 | NTP 1991
Hematological | Increased hemoglobin concentration in rats exposed for 30 days | 3 | 10 | Kociba et al. 1971
Hepatic | Increased cytoplasmic basophilia in rats exposed for 13 weeks | 6.3 | 15.6 | Harleman and Seinen 1979
Renal | Proximal tubular epithelial regeneration in mice exposed for 13 weeks | 0.2 | 0.5 | NTP 1991
Neurological | Lethargy, hunched posture, incoordination in mice exposed to 40 mg/kg/day for 15 days | 12 | 40 | NTP 1991
Reproductive | Infertility in female rats exposed for 15 weeks | 15 | 150 | Harleman and Seinen 1979
Developmental | 16–19% decrease in pup body weight (rat dams exposed for 18 weeks) | | 15 | Harleman and Seinen 1979

a NOAEL identified in the same study as the lowest LOAEL.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: A summary of the NOAEL and LOAEL values for renal effects is presented in Table A-3.

Table A-3 Summary of Renal Effects Observed in Intermediate-Duration Oral Studies of Hexachlorobutadiene

Species | Exposure | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Mouse | 13 weeks (F) | 0.2 F; 1.5 M | 0.5 F; 4.9 M | Tubular epithelial regeneration | NTP 1991
Rat | 147 days (F) | 0.2 F; 2 M | 2 F; 20 M | Tubular dilation and hypertrophy with foci of degeneration and regeneration | Schwetz et al. 1977
Rat | 13 weeks (GO) | 1 F; 2.5 M | 2.5 F; 6.3 M | Enlarged hyperchromatic nuclei in the proximal tubules; decreased urine osmolarity in females | Harleman and Seinen 1979
Rat | 4 weeks (F) | | 2.5 F | Decreased BUN in females | Jonker et al. 1993b
Rat | 32 days (GO) | 1 F | 4 F | Focal tubular vacuolization and increased relative kidney weight | Jonker et al. 1996
Rat | 18 weeks (F) | | 15 F | Proximal tubular degeneration and necrosis | Harleman and Seinen 1979
Rat | 30 days (F) | 10 F | 30 F | Tubular degeneration, necrosis, and regeneration | Kociba et al. 1971
Rat | 3 weeks (F) | 37 M | 190 M | Proximal tubules lined with basophilic epithelium | Nakagawa et al. 1998
Rat | 30 weeks (F) | 94 M | | | Nakagawa et al. 1998

BUN = blood urea nitrogen; (F) = feed; F = female(s); (GO) = gavage in oil; LOAEL = lowest-observed-adverse-effect level; M = male(s); NOAEL = no-observed-adverse-effect level

In all studies involving exposure of male and female rats or mice, the lower LOAEL values were identified in the females. The lowest LOAEL for renal effects was 0.5 mg/kg/day identified in female mice exposed to hexachlorobutadiene in the diet for 13 weeks (NTP 1991); no effects were observed at 0.2 mg/kg/day. The Schwetz et al. (1977) reproductive/developmental toxicity study also identified a NOAEL of 0.2 mg/kg/day for kidney effects with a LOAEL of 2 mg/kg/day. The NTP (1991) study was selected as the principal study because it identified the lowest LOAEL for renal effects.

Summary of the Principal Study:

NTP. 1991. National Toxicology Program. Toxicity studies of hexachloro-1,3-butadiene in B6C3F_1_ mice (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH publication no. 91-3120.

Groups of 10 male and 10 female B6C3F1 mice were exposed to 0, 1, 10, 30, or 100 ppm hexachlorobutadiene in the diet for 13 weeks; the investigators estimated the doses to be 0, 0.1, 0.4, 1.5, 4.9, and 16.8 mg/kg/day in males and 0, 0.2, 0.5, 1.8, 4.5, and 19.2 mg/kg/day in the females. The following parameters were used to assess toxicity: body weight, food intake (measured weekly), organ weight (brain, heart, kidney, liver, spleen, testis), gross necropsy, histopathological examination of major tissues and organs in the controls and high-dose animals and all animals dying early; histopathology of kidneys in all groups; sperm morphology; and vaginal cytology.

One male in the 0.1 mg/kg/day group died early. No overt clinical signs were observed in exposed mice. Decreases in body weight gain were observed in males at 4.9 and 16.8 mg/kg/day (9.9 and 15.8%, respectively) and in females at 19.2 mg/kg/day (15%); no alterations in feed intake were noted. Significant decreases in absolute and relative kidney weights were observed at ≥4.9 mg/kg/day in males; relative kidney weight was also decreased in males at 1.5 mg/kg/day. In females, the only significant alteration in kidney weight was a decrease in absolute weight at 19.2 mg/kg/day. The investigators noted that a decrease in absolute heart weight in males at 16.8 mg/kg/day may be clinically relevant; however, no histological alterations were observed in the heart. Renal tubular epithelial regeneration, prominent in the outer stripe of the outer medullary rays (pars recta) was observed in 0/10, 0/10, 0/10, 0/9, 10/10, and 10/10 males at 0, 0.1, 0.4, 1.5, 4.9, and 16.8 mg/kg/day, respectively, and in 0/10, 1/10, 9/10, 10/10, 10/10, and 10/10 females at 0, 0.2, 0.5, 1.8, 4.5, and 19.2 mg/kg/day, respectively. A significant decrease in sperm motility was observed at 1.5, 4.9, and 16.8 mg/kg/day, but the magnitude of the decrease was not dose-related. No significant alterations in sperm count, incidence of abnormal sperm, estrual cyclicity, or average estrous cycle length were observed.

Selection of the Point of Departure: The NOAEL of 0.2 mg/kg/day identified in female mice was selected as the point of departure for the MRL. The incidence data for renal tubular regeneration was not considered suitable for benchmark dose modeling due to the lack of dose-response data between the extremes in the incidence in the control and lowest dose groups and the incidences in higher dose groups.

Uncertainty Factor: The NOAEL of 0.2 mg/kg/day is divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability
  - MRL = LOAEL ÷ UFs
  - 0.2 mg/kg/day ÷ (10 × 10) = 0.002 mg/kg/day

Other Additional Studies or Pertinent Information: No human studies examining the toxicity of hexachlorobutadiene following intermediate-duration oral exposure were identified. The identification of the kidney as the most sensitive target of toxicity is supported by a number of intermediate-duration oral studies and a chronic-duration oral study.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobutadiene
CAS Numbers: | 87-68-3
Date: | March 2021
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for hexachlorobutadiene.

Rationale for Not Deriving an MRL: One study has evaluated the chronic oral toxicity of hexachlorobutadiene (Kociba et al. 1977). In this study, an increase in the incidence of tubular epithelial hyperplasia was observed at 20 mg/kg/day. The investigators also noted that there was a possible increase in incidence of hyperplasia at 2 mg/kg/day; however, no incidence data were provided. An increase in the incidence of total number of renal tubular neoplasms were observed at 20 mg/kg/day. The Kociba et al. (1977) study was not considered suitable for derivation of an MRL because incidence data were not provided to allow for an independent assessment of whether there was a significant increase in the incidence of hyperplasia at 2 mg/kg/day.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.