# 9 REFERENCES

* Not cited in text

Abd-Allah AMA. 1999. Organochlorine contaminants in microlayer and subsurface water of Alexandria Coast, Egypt. J AOAC Int 82(2):391–398.
Abraham K, Hille A, Ende M, . 1994. Intake and fecal excretion of PCDDs, PCDFs, HCB and PCBs (138,153,180) in a breast-fed and a formula-fed infant. Chemosphere 29(9–11):2279–2286.7850375
Abraham K, Papke O, Wahn U, . 2000. POP accumulation in infants during breast feeding. Organohalogen Compounds 48:25–26.
ACGIH. 2014. Hexachlorobenzene. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 33, 72–77.
Ackerman LK, Schwindt AR, Simonich SL, . 2008. Atmospherically deposited PBDEs, pesticides, PCBs, and PAHs in Western U.S. National Park fish: Concentrations and consumption guidelines. Environ Sci Technol 42(7):2334–2341.18504962
Addae C, Cheng H, Martinez-Ceballos E. 2013. Effect of the environmental pollutant hexachlorobenzene (HCB) on the neuronal differentiation of mouse embryonic stem cells. Int J Environ Res Public Health 10(10):5244–5256.24157519
Adjarov DG. 1990. Decreased activity of liver coproporphyrinogen oxidase in hexachlorobenzene-induced porphyria. Exp Pathol 40:117–122.2079105
*Adjarov DJ, Elder GH. 1986. Accumulation of uroporphyrin does not provoke further inhibition of liver uroporphyrinogen decarboxylase activity in hexachlorobenzene-induced porphyria. In: Hexachlorobenzene: Proceedings of an international symposium. IARC Sci Publ 77:467–469.
Adjarov D, Ivanov E, Keremidchiev D. 1982. Gamma-glutamyl transferase: A sensitive marker in experimental hexachlorobenzene intoxication. Toxicology 23:73–77.6124055
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Adolfsson-Erici M, Akerman G, McLachlan MS. 2012. Measuring bioconcentration factors in fish using exposure to multiple chemicals and internal benchmarking to correct for growth dilution. Environ Toxicol Che m 31(8):1853–1860.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
*Ahlborg UG, Larsson K, Thunberg T. 1978. Metabolism of pentachlorophenol in vivo and in vitro. Arch Toxicol 40:45–53.580375
AIHA. 2014. Current ERPG Values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. March 4, 2015.
Akkina J, Reif J, Keefe T, . 2004. Age at natural menopause and exposure to organochlorine pesticides in Hispanic women. J Toxicol Environ Health A 67(18):1407–1422.15371229
Alawi MA, Ababneh M. 1991. Residue analysis of chlorinated pesticides in Jordanian human adipose tissue. Anal Lett 25(10):1897–1911.
Alawi MA, Ammari N, Al-Shuraiki Y. 1992. Organochlorine pesticide contaminations in human milk samples from women living in Amman, Jordan. Arch Environ Contam Toxicol 23:235–239.1514844
Albro PW, Thomas R. 1974. Intestinal absorption of hexachlorobenzene and hexachlorocyclohexane isomers in rats. Bull Environ Contam Toxicol 12:289–294.4139995
*Alleman MA, Koster JF, Wilson JHP, . 1985. The involvement of iron and lipid peroxidation in the pathogenesis of HCB induced porphyria. Biochem Pharmacol 34(2):161–166.3966921
Allen-Gil SM, Gubala CP, Wilson R, . 1997. Organochlorine pesticides and polychlorinated biphenyls (PCBs) in sediments and biota from four US arctic lakes. Arch Environ Contam Toxicol 33:378–387.9419256
Almeida-Gonzalez M, Luzardo OP, Zumbado M, . 2012. Levels of organochlorine contaminants in organic and conventional cheeses and their impact on the health of consumers: An independent study in the Canary Islands (Spain). Food Chem Toxicol 50(12):4325–4332.22981847
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Fed Am Soc Exp Biol, 1987–2008, 2041.
Alvarado-Hernandez DL, Montero-Montoya R, Serrano-Garcia L, . 2013. Assessment of exposure to organochlorine pesticides and levels of DNA damage in mother-infant pairs of an agrarian community. Environ Mol Mutagen 54(2):99–111.23355095
Alvarez L, Randi A, Alvarez P, . 2000. Reproductive effects of hexachlorobenzene in female rats. J Appl Toxicol 20:81–87.10641019
Álvarez-Pedrerol M, Ribas-Fito N, Torrent M, . 2008a. Thyroid disruption at birth due to prenatal exposure to β-hexachlorocyclohexane. Environ Int 34(6):737–737 740.18207242
Álvarez-Pedrerol M, Ribas-Fito N, Torrent M, . 2008b. Effects of PCBs, p,p’-DDT, p,p’-DDE, HCB and β-HCH on thyroid function in preschool children. Occup Environ Med 65(7):452–457.17933884
Ames A, Van Vleet E. 1996. Organochlorine residues in the Florida manatee, Trichechus manatus latirostris. Mar Pollut Bull 32:374–377.
Amodio E, Turci R, Massenti MF, . 2012. Serum concentrations of persistent organic pollutants (POPs) in the inhabitants of a Sicilian city. Chemosphere 89(8):970–974.22840540
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Anderson HA, Falk C, Hanrahan L, . 1998. Profiles of Great Lakes critical pollutants: A sentinel analysis of human blood and urine. Environ Health Perspect 106(5):279–289.9560354
Ando M, Hirano S, Itoh Y. 1985. Transfer of hexachlorobenzene (HCB) from mother to new-born baby through placenta and milk. Arch Toxicol 56:195–200.3977600
Andrews JE, Courtney KD, Donaldson WE. 1988. Impairment of calcium homeostasis by hexachlorobenzene (HCB) exposure in Fischer 344 rats. J Toxicol Environ Health 23:311–320.3351979
Andrews JE, Courtney KD, Stead AG, . 1989. Hexachlorobenzene- induced hyperparathyroidism and osteosclerosis in rats. Fundam Appl Toxicol 12:242–251.2714525
Andrews JE, Jackson LD, Stead AG, . 1990. Morphometric analysis of osteosclerotic bone resulting from hexachlorobenzene exposure. J Toxicol Environ Health 31:193–201.2231778
Anezaki K, Nagahora S. 2014. Characterization of polychlorinated biphenyls, pentachlorobenzene, hexachlorobenzene, polychlorinated dibenzo-p-dioxins, and dibenzofurans in surface sediments of Muroran Port, Japan. Environ Sci Pollut Res Int 21(15):9169–9181.24691935
Ansari GAS, James GP, Hu AL, . 1986. Organochlorine residues in adipose tissue of residents of the Texas gulf coast. Bull Environ Contam Toxicol 36:311–316.3081069
Antunes P, Viana P, Vinhas T, . 2012. Emission profiles of polychlorinated dibenzodioxins, polychlorinated dibenzofurans (PCDD/Fs), dioxin-like PCBs and hexachlorobenzene (HCB) from secondary metallurgy industries in Portugal. Chemosphere 88:1332–1339.22704215
AOAC. 1990. Official methods of analysis of the association of official analytical chemists. Association of Official Analytical Chemist, Inc. 15 Edition, Arlington, Virginia.
Archibeque-Engle S, Tessari J, Winn D, . 1997. Comparison of organochlorine pesticide and polychlorinated biphenyl residues in human breast adipose tissue and serum. J Toxicol Environ Health 52:285–293.9354175
Arnold DL, Bryce FR, Clegg DJ, . 2000. Dosing via gavage or diet for reproduction studies: A pilot study using two fat-soluble compounds-hexachlorobenzene and Aroclor 1254. Food Chem Toxicol 38:697–706.10908817
Arnold DL, Moodie CA, Charbonneau SM, . 1985. Long-term toxicity of hexachlorobenzene in the rat and the effect of dietary vitamin A. Food Chem Toxicol 23:779–793.4043882
Arnot JA, Mackay D, Parkerton TF, . 2010. Multimedia modeling of human exposure to chemical substances: The roles of food web biomagnification and biotransformation. Environ Toxicol Chem 29:(1):45–55.20821418
Aronson KJ, Wilson JWL, Hamel M, . 2010. Plasma organochlorine levels and prostate cancer risk. J Expo Sci Environ Epidemiol 20(5):434–445.19513097
Arrebola JP, Cuellar M, Claure E, . 2012. Concentrations of organochlorine pesticides and polychlorinated biphenyls in human serum and adipose tissue from Bolivia. Environ Res 112:40–47.22078547
Ataniyazova OA, Baumann RA, Liem AKD, . 2001. Levels of certain metals, organochlorine pesticides and dioxins in cord blood, maternal blood, human milk and some commonly used nutrients in the surroundings of the Aral Sea (Karakalpakstan, Republic of Uzbekistan). Acta Paediatr 90:801–808.11519985
Atlas E, Giam CS. 1981. Global transport of organic pollutants: Ambient concentrations in the remote marine atmosphere. Science 211:163–165.17757266
Avrahami M. 1975. Hexachlorobenzene: IV. Accumulation and elimination of HCB in pigs after oral dosing. N Z J Exp Agric 3:285–287.
*Avrahami M, Steele RT. 1972a. Hexachlorobenzene: I. Accumulation and elimination of HCB in sheep after oral dosing. N Z J Agric Res 15:476–481.
*Avrahami M, Steele RT. 1972b. Hexachlorobenzene: II. Residues in laying pullets fed hexachlorobenzene in their diet and the effects on egg production, egg hatchability, and on chickens. N Z J Agric Res 15:482–488.
Axelson O. 1986. A review of porphyria and cancer and the missing link with human exposure to hexachlorobenzene. IARC Sci Publ 77:585–589.
Babineau KA, Singh A, Jarrell, JF, . 1991. Surface epithelium of the ovary following oral administration of hexachlorobenzene to the monkey. J Submicrosc Cytol Pathol 23:457–464.1913591
Badia-Vila M, Ociepa M, Mateo R, . 2000. Comparison of residue levels of persistent organochlorine compounds in butter from Spain and from other European countries. J Environ Sci Health B35(2):201–210.
Bailey J, Knauf V, Mueller W, . 1980. Transfer of hexachlorobenzene and polychlorinated biphenyls to nursing infant rhesus monkeys: Enhanced toxicity. Environ Res 21:190–196.6771134
Bailey RE. 2001. Global hexachlorobenzene emissions. Chemosphere 43:167–182.11297396
Ballester F, Sala M, Sunyer J, . 2000. Serum concentrations of hexachlorobenzene in family members of workers in an electrochemical factory. Scand J Work Environ Health 26(1):67–70.10744180
Ballschmiter K, Wittlinger R. 1991. Interhemisphere exchange of hexachlorocyclohexanes, hexachlorobenzene, polychlorobipheneyls, and 1,1-trichloro-2,2-bis(p-chlorolophenyl)ethane in the lower troposphere. Environ Sci Technol 25(6):1103–1111.
Barber JL, Sweetman AJ, van Wijk D, . 2005. Hexachlorobenzene in the global environment: Emissions, levels, distribution, trends and processes. Sci Total Environ 349(1–3):1–44.16005495
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnett JB, Barfield L, Walls R, . 1987. The effect of in utero exposure to hexachlorobenzene on the developing immune response of Balb/c mice. Toxicol Lett 39:263–274.2961103
Basterrechea M, Lertxundi A, Iniguez C, . 2014. Prenatal exposure to hexachlorobenzene (HCB) and reproductive effects in a multicentre birth cohort in Spain. Sci Total Environ 466–467:770–776.
Bates MN, Hannah DJ, Buckland SJ, . 1994. Chlorinated organic contaminants in breast milk of New Zealand women. Environ Health Perspect 102(Supp 1):211–217.
Beall ML Jr. 1976. Persistence of aerially applied hexachlorobenzene on grass and soil. J Environ Qual 5:367–369.
Bebarta VS, Phillips SD. 2004. Fungicides. In: Dart RC, ed. Medical toxicology. 3^rd^ ed. Philadelphia, PA: Lippincott Williams & Wilkins, 1529–1532.
Beck J, Hansen KE. 1974. The degradation of quintozene, pentachlorobenzene, hexachlorobenzene and pentachloraniline in soil. Pestic Sci 5:41–48.
Becker K, Mussig-Zufika M, Conrad A, . 2008. German environmental survey for children 2003/06-Ger ES IV. Human biomonitoring. Levels of selected substances in blood and urine in children in Germany. Robert Koch-Institut (RKI), Berlin: Environment Research of the Federal Ministry of the Environment, Nature Conservation and Nuclear Safety.
Becker PR, Mackey EA, Demiralp R, . 1997. Concentrations of chlorinated hydrocarbons and trace elements in marine mammal tissues archived in the U.S. National Biomonitoring Specimen Bank. Chemosphere 34:2067–2098.9159906
Behrooz RD, Sari AE, Bahramifar N, . 2009. Organochlorine pesticide and polychlorinated biphenyl residues in human milk from the southern coast of Caspian Sea, Iran. Chemosphere 74(7):931–937.19042005
Belfroid A. 1995. Uptake, bioavailability and elimination of hydrophobic compounds in earthworms (Eisenia andrei) in field-contaminated soil. Environ Toxicol Chem 14(4):605–612.
Belles-Isles M, Bilrha H, Moreau B, . 2000. Immunological effects in newborns from Saint-Lawrence River coastal populations exposed to POPs and heavy metals. Organohalogen Compounds 48:227–230.
Ben Hassine S, Hammami B, Ben Ameur W, . 2014. Concentrations of organochlorine pesticides and polychlorinated biphenyls in human serum and their relation with age, gender, and BMI for the general population of Bizerte, Tunisia. Environ Sci Pollut Res Int 21(10):6303–6313.23338993
Beretta M, Dick T. 1994. Organochlorine compounds in human milk, Porto Alegre, Brazil. Environ Contam Toxicol 53(3):357–360.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bernhoft A, Skaare JU, Wiig O, . 2000. Possible immunotoxic effects of organochlorines in polar bears (Ursus maritimus) at Svalbard. J Toxicol Environ Health 59(Part A):561–574.
*Bertram HP, Kemper FH, Muller C. 1986. Hexachlorobenzene content in human whole blood and adipose tissue: Experiences in environmental specimen banking. IARC Sci Publ 77:173–183.
Beyer WN. 1996. Accumulation of chlorinated benzenes in earthworms. Bull Environ Contam Toxicol 57:729–736.8791547
Bidleman TF, Patton GW, Walla MD, . 1989. Toxaphene and other organochlorines in Arctic Ocean fauna: Evidence for atmospheric delivery. Arctic 42(4):307–313.
Biggs ML, Davis MD, Eaton DL, . 2008. Serum organochlorine pesticide residues and risk of testicular germ cell carcinoma: A population-based case-control study. Cancer Epidemiol Biomarkers Prev 17(8):2012–2018.18708392
Billi de Catabbi S, Aldonatti C, San Martin de Viale LC. 2000a. Heme metabolism after discontinued hexachlorobenzene administration in rats: Possible irreversible changes and biomarker for hexachlorobenzene persistence. Comp Biochem Physiol C 127:165–175.
Billi de Catabbi S, Rios de Molina MC, San Martin de Viale LC. 1991. Studies on the active center of rat liver porphyrinogen carboxylase in vivo effect of hexachlorobenzene. Int J Biochem 23:675–679.1864444
Billi de Catabbi S, Setton-Advruj CP, Sterin-Speziale N, . 2000b. Hexachlorobenzene-induced alterations on neutral and acidic sphingomyelinases and serine palmitoyltransferase activities. A time course study in two strains of rats. Toxicology 149:89–100.10967406
Bishop CA, Lean DRS, Brooks RJ, . 1995. Chlorinated hydrocarbons in early life stages of the common snapping turtle (Chelydra serpentina serpentina) from a coastal wetland on Lake Ontario, Canada. Environ Toxicol Chem 14(3):421–426.
Bishop CA, Ng P, Norstrom RJ, . 1996. Temporal and geographic variation of organochlorine residues in eggs of the common snapping turtle (Chelydra serpentina serpentina) (1981-1991) and comparisons to trends in the herring gull (Larus argentatus) in the Great Lakes Basin in Ontario, Canada. Arch Environ Contam Toxicol 31:512–524.8975824
Bjerregaard P, Hansen JC. 2000. Organochlorines and heavy metals in pregnant women from the Disko Bay area in Greenland. Sci Total Environ 245:195–202.10682367
Björnfoth H, Hardell L, Carlberg M, . 2007. Decreased survival in patients with pancreatic cancer associated with concentrations of organochlorines in adipose tissue. Organohalogen Compounds 69:1981–1984.
*Bleavins MR, Breslin WJ, Aulerich RJ, . 1982. Excretion and placental and mammary transfer of hexachlorobenzene in the European ferret (Mustela putorius furo). J Toxicol Environ Health 10:929–940.7161840
Blekkenhorst GH, Pimstone NR, Weber BL, . 1976. Hepatic HAEM metabolism in porphyria cutane tarda (PCT): Enzymatic studies and their relation to liver ultrastructure. Ann Clin Res 8(Supp 17):108–121.1008481
Bong RL. 1975. Determination of hexachlorobenzene and mirex in fatty products. J AOAC 58(3):557–561.
Booij K, van Bommel R, Jones KC, . 2007. Air-water distribution of hexachlorobenzene and 4,4’-DDE along a north-south Atlantic transect. Mar Pollut Bull 54(6):814–819.17296207
Booth NH, McDowell JR. 1975. Toxicity of hexachlorobenzene and associated residues in edible animal tissues. JAVMA 166(6):591–595.1091611
Bordet F, Mallet J, Maurice L, . 1993. Organochlorine pesticide and PCB congener content of French human milk. Bull Environ Contam Toxicol 50:425–432.8428123
Borgå K, Gabrielsen GW, Skaare JU. 2001. Biomagnification of organochlorines along a Barents Sea food chain. Environ Pollut 113:187–198.11383336
Bourque AC, Singh A, Lakhanpal N, . 1995. Ultrastructural changes in ovarian follicles of monkeys administered hexachlorobenzene. Am J Vet Res 56(12):1673–1677.8599532
Bouthillier L, Greselin E, Brodeur J, . 1991. Male rat specific nephrotoxicity resulting from subchronic administration of hexachlorobenzene. Toxicol Appl Pharmacol 110:315–326.1716383
Brady MN, Siyali DS. 1972. Hexachlorobenzene in human body fat. Med J Aust 1:158–161.4110954
Braune B, Muir D, DeMarch B, . 1999. Spatial and temporal trends of contaminants in Canadian Arctic freshwater and terrestrial ecosystems: A review. Sci Total Environ 230:145–207.10466229
Bristol DW, Crist HL, Lewis RG, . 1982. Chemical analysis of human blood for assessment of environmental exposure to semivolatile organochlorine chemical contaminants. J Anal Toxicol 6:269–275.6819409
Brock J, Melnyk L, Caudill S, . 1998. Serum levels of several organochlorine pesticides in farmers correspond with dietary exposure and local use history. Toxicol Ind Health 14(1–2):275–289.9460180
Brorström-Lundén E, Lindskog A, Mowrer J. 1994. Concentrations and fluxes of organic compounds in the atmosphere of the Swedish west coast. Atmos Environ 28(22):3605–3615.
Brubaker WW, Hites RA. 1998. OH reaction kinetics of gas-phase α- and γ-hexachlorocyclohexane and hexachlorobenzene. Environ Sci Technol 32(6):766–769.
Bryson PD. 1989. Chlorinated hydrocarbons (organochlorines). In: Comprehensive review in toxicology. Rockville, MD: Aspen Publication, 527–529.
Bucholski KA, Begerow J, Winneke G, . 1996. Determination of polychlorinated biphenyls and chlorinated pesticides in human body fluids and tissues. J Chromatogr 754:479–485.
Burkhard LP, Sheedy BR, McCauley DJ, . 1997. Bioaccumulation factors for chlorinated benzenes, chlorinated butadienes and hexachloroethane. Environ Toxicol Chem 16(8):1677–1686.
Burns JE, Miller FM. 1975. Hexachlorobenzene contamination: Its effects in a Louisiana population. Arch Environ Health 30:44–48.1109272
Burns JE, Miller FM, Gomes ED, . 1974. Hexachlorobenzene exposure from contaminated DCPA in vegetable spraymen. Arch Environ Health 29:192–194.4413672
Burns JS, Williams PL, Korrick SA, . 2014. Association between chlorinated pesticides in the serum of prepubertal Russian boys and longitudinal biomarkers of metabolic function. Am J Epidemiol 180(9):909–919.25255811
Burns JS, Williams PL, Sergeyev O, . 2012. Serum concentrations of organochlorine pesticides and growth among Russian boys. Environ Health Perspect 120(2):303–308.21984531
Burse VW, Head SL, Korver MP, . 1990. Determination of selected organochlorine pesticides and polychlorinated biphenyls in human serum. J Anal Toxicol 14:137–146.1695698
Burse VW, Najam AR, Williams CC, . 2000. Utilization of umbilical cords to assess in utero exposure to persistent pesticides and polychlorinated biphenyls. J Expo Anal Environ Epidemiol 10:776–788.11138670
Burton MA, Bennett BG. 1987. Exposure of man to environmental hexachlorobenzene (HCB)-an exposure commitment assessment. Sci Total Environ 66:137–146.3685945
Butler Walker J, Seddon L, McMullen E, . 2003. Organochlorine levels in maternal and umbilical cord blood plasma in arctic Canada. Sci Total Environ 302(1–3):27–52.12526896
Cabral JRP, Mollner T, Raitano F, . 1979. Carcinogenesis of hexachlorobenzene in mice. Int J Cancer 23:47–51.759379
Cabral JR, Shubik P, Mollner T, . 1977. Carcinogenic activity of hexachlorobenzene in hamsters. Nature 269:510–511.198674
Calamari D, Tremolada P, Guardo AD, . 1994. Chlorinated hydrocarbons in pine needles in Europe: Fingerprint for the past and recent use. Environ Sci Technol 28:429–434.22165877
Calaminus B, Trouve G, Delforsse L. 1993. Experimental study of the quantitative conversion of hexachlorobenzene during high temperature pyrolysis. J Anal Appl Pyrolysis 27(2):281–292.
Cam C, Nigogosyan G. 1963. Acquired toxic porphyria cutanea tarda due to hexachlorobenzene: Report of 348 cases caused by this fungicide. JAMA 183:88–91.14018209
Canas A, Richter P. 2012. Solid-phase microextraction using octadecyl-bonded silica immobilized on the surface of a rotating disk: Determination of hexachlorobenzene in water. Anal Chim Acta 743:75–79.22882826
Canonero R, Campart GB, Mattioli F, . 1997. Testing of p-dichlorobenzene and hexachlorobenzene for their ability to induce DNA damage and micronucleus formation in primary cultures of rat and human hepatocytes. Mutagenesis 12(1):35–39.9025095
Cantoni L, Budillon G, Cuomo R, . 1990. Protective effect of S-adenosyl-L-methionine in hepatic uroporphyria. Evaluation in an experimental model. Scand J Gastroenterol 25:1034–1040.2263875
Cantor KP, Strickland PT, Brock JW, . 2003. Risk of non-Hodgkin’s lymphoma and prediagnostic serum organochlorines: β-hexachlorocyclohexane, chlordane/heptachlor-related compounds, dieldrin, and hexachlorobenzene. Environ Health Perspect 111(2):179–183.12573902
Cao LL, Yan CH, Yu XD, . 2011. Relationship between serum concentrations of polychlorinated biphenyls and organochlorine pesticides and dietary habits of pregnant women in Shanghai. Sci Total Environ 409(16):2997–3002.21665017
*Carpenter HM, Williams DE, Henderson MC, . 1984. Hexachlorobenzene-induced porphyria in Japanese quail: Effect of pretreatment with phenobarbital or beta-naphthoflavone. Biochem Pharmacol 33:3875–3881.6439214
Carrizo D, Grimalt JO, Ribas-Fito N, . 2008. Pentachlorobenzene, hexachlorobenzene, and pentachlorophenol in children’s serum from industrial and rural populations after restricted use. Ecotoxicol Environ Saf 71(1):260–266.17935782
Carthew P, Smith AG. 1994. Pathological mechanisms of hepatic tumor formation in rats exposed chronically to dietary hexachlorobenzene. J Appl Toxicol 447–452.7884150
Carthew P, Edwards RE, Smith AG. 1990. Immunotoxic effects of hexachlorobenzene on the pathogenesis of systemic, pneumonic and hepatic virus infections in the mouse. Human Exp Toxicol 9:403–411.
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. http://www.cdc.gov/exposurereport/pdf/fourthreport.pdf. August 4, 2015.
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. March 10, 2015.
Cesh LS, Williams TD, Garcelon DK, . 2008. Patterns and trends of chlorinated hydrocarbons in nestling bald eagle (Haliaeetus leucocephalus) plasma in British Columbia and southern California. Arch Environ Contam Toxicol 55(3):496–502.18253687
Chaisuksant Y, Yu Q, Connell DW. 1997. Bioconcentration of bromo- and chlorobenzenes by fish (Gambusia affinis). Water Res 31(1):61–68.
Chalouati H, Gamet-Payrastre L, Ben Saad M. 2013. Irreversible thyroid disruption induced after subchronic exposure to hexachlorobenzene in male rats. Toxicol Ind Health:1–10.
Chan CH, Bruce G, Harrison B. 1994. Wet deposition of organochlorine pesticides and polychlorinated biphenyls to the great lakes. J Great Lakes Res 20(3):546–560.
Charlier C, Albert A, Herman P, . 2003. Breast cancer and serum organochlorine residues. Occup Environ Med 60(5):348–351.12709520
Charlier C, Foidart JM, Pitance F, . 2004. Environmental dichlorodiphenyltrichlorethane or hexachlorobenzene exposure and breast cancer: Is there a risk? Clin Chem Lab Med 42(2):222–227.15061365
Chavez-Almazan LA, Diaz-Ortiz J, Alarcon-Romero M, . 2014. Organochlorine pesticide levels in breast milk in Guerrero, Mexico. Bull Environ Contam Toxicol 93(3):294–298.24891143
Chen X, Panuwet P, Hunter RE, . 2014. Method for the quantification of current use and persistent pesticides in cow milk, human milk and baby formula using gas chromatography tandem mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 970:121–130.
Cheslack-Postava K, Rantakokko PV, Hinkka-Yli-Salomaki S, . 2013. Maternal serum persistent organic pollutants in the Finnish Prenatal Study of Autism: A pilot study. Neurotoxicol Teratol 38:1–5.23591055
Chevreuil M, Garmouma M, Teil MJ, . 1996. Occurrence of organochlorines (PCBs, pesticides) and herbicides (triazines, phenylureas) in the atmosphere and in the fallout from urban and rural stations of the Paris area. Sci Total Environ 182:25–37.8854939
Chevrier J, Eskenazi B, Holland N, . 2008. Effects of exposure to polychlorinated biphenyls and organochlorine pesticides on thyroid function during pregnancy. Am J Epidemiol 168(3):298–310.18550560
Chiappini F, Alvarez L, Lux-Lantos V, . 2009. Hexachlorobenzene triggers apoptosis in rat thyroid follicular cells. Toxicol Sci 108(2):301–310.19182106
Chiappini F, Pontillo C, Randi AS, . 2013. Reactive oxygen species and extracellular signal-regulated kinase 1/2 mediate hexachlorobenzene-induced cell death in FRTL-5 rat thyroid cells. Toxicol Sci 134(2):276–290.23708402
Chiappini F, Pontillo C, Randi A, . 2014. Hexachlorobenzene induces TGF-β1 expression, which is a regulator of p27 and cyclin D1 modifications. Toxicol Lett 230(1):1–9.25093615
Choi SD, Wania F. 2011. On the reversibility of environmental contamination with persistent organic pollutants. Environ Sci Technol 45(20):8834–8841.21905649
Choudhry GG, Webster GRB, Hutzinger O. 1986. Environmentally significant photochemistry of chlorinated benzenes and their derivatives in aquatic systems. Toxicol Environ Chem 13:27–81.
Chovancová J, Drobna B, Fabisikova A, . 2014. Polychlorinated biphenyls and selected organochlorine pesticides in serum of Slovak population from industrial and non-industrial areas. Environ Monit Assess 186(11):7643–7653.25098899
*Clark DE, Ivie GW, Camp BJ. 1981. Effects of dietary hexachlorobenzene on in vivo biotransformation, residue deposition, and elimination of certain xenobiotics by rats. J Agric Food Chem 29:600–608.7251991
Clayton GD, Clayton FE, eds. 1981. Patty’s industrial hygiene and toxicology: 3rd revised ed. Volume 2B: Toxicology. New York, NY: Wiley-Interscience Publication, 3626–3684.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cobb GP, Norman DM, Kendall RJ. 1994. Organochlorine contaminant assessment in great blue herons using traditional nonlethal monitoring techniques. Environ Pollut 83(3):299–309.15091735
Cochon AC, San Martin de Viale LC, Billi de Catabbi S. 2001. Phospholipid alterations elicited by hexachlorobenzene in rat brain are strain-dependent and porphyria-independent. Comp Biochem Physiol C 130:199–207.
Codru N, Schymura MJ, Negoita S, . 2007. Diabetes in relation to serum levels of polychlorinated biphenyls and chlorinated pesticides in adult Native Americans. Environ Health Perspect 115(10):1442–1447.17938733
Cohn WJ, Boylan JJ, Blanke RV, . 1978. Treatment of chlordecone kepone toxicity with cholestryamine: Results of a controlled clinical trial. N Engl J Med 298:243–248.74014
Çok I, Yelken C, Durmaz E, . 2011. Polychlorinated biphenyl and organochlorine pesticide levels in human breast milk from the Mediterranean city Antalya, Turkey. Bull Environ Contam Toxicol 86(4):423–427.21340456
Colles A, Koppen G, Hanot V, . 2008. Fourth WHO-coordinated survey of human milk for persistent organic pollutants (POPs): Belgian results. Chemosphere 73:907–914.18718632
Conde C, Maluenda C, Arrabal C. 1993. Organochlorine residues in human milk in Spain. Polychlorinated biphenyls (PCBs) from 1988 to 1991. Bull Environ Contam Toxicol 51:832–837.8257809
Connell DW, Bowman M, Hawker DW. 1988. Bioconcentration of chlorinated hydrocarbons from sediment by oligochaetes. Ecotoxicol Environ Saf 16:293–302.3229383
Cooney MA, Louis GMB, Hediger ML, . 2010. Organochlorine pesticides and endometriosis. Reprod Toxicol 30(3):365–369.20580667
Corsolini S, Focardi S, Leonzio C, . 1999. Heavy metals and chlorinated hydrocarbon concentrations in the red fox in relation to some biological parameters. Environ Monit Assess 54:87–100.
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110.14744240
Courtney KD, Andrews JE. 1985. Neonatal and maternal body burdens of hexachlorobenzene (HCB) in mice: Gestational exposure and lactational transfer. Fundam Appl Toxicol 5:265–277.3987998
Courtney KD, Andrews, JE, Svendsgaard DJ. 1979. Hexachlorobenzene (HCB) deposition in maternal and fetal tissues of rat and mouse: 1. Chemical quantification of HCB in tissues. Environ Res 19:1–13.510261
Courtney KD, Copeland MF, Robbins A. 1976. The effects of pentachloronitrobenzene, hexachlorobenzene, and related compounds on fetal development. Toxicol Appl Pharmacol 35:239–256.1265744
Cox S, Niskar AS, Narayan KM, . 2007. Prevalence of self-reported diabetes and exposure to organochlorine pesticides among Mexican Americans: Hispanic Health and Nutrition Examination Survey, 1982-1984. Environ Health Perspect 115(12):1747–1752.18087594
Craan A, Haines D. 1998. Twenty-five years of surveillance for contaminants in human breast milk. Arch Environ Contam Toxicol 35:702–710.9776790
Craig SA. 1998. Herbicides and fungicides. In: Viccellio P, ed. Emergency toxicology. 2^nd^ ed. Philadelphia, PA: Lippincott-Raven Publishers, 415–423.
Cripps DJ. 1990. Transplacental and mammary absorption of hexachlorobenzene: Experimental pembe yara porphyria in neonates. Mol Aspects Med 11(1–2):81–82.
Cripps DJ, Peters HA, Gocmen A, . 1984. Porphyria turcica due to hexachlorobenzene: A 20 to 30 year follow-up study on 204 patients. Br J Dermatol 111:413–422.6487543
Croes K, Den Hond E, Bruckers L, . 2014a. Endocrine actions of pesticides measured in the Flemish environment and health studies (FLEHS I and II). Environ Sci Pollut Res Int [epub ahead of print].
Croes K, Den Hond E, Bruckers L, . 2014b. Monitoring chlorinated persistent organic pollutants in adolescents in Flanders (Belgium): Concentrations, trends and dose-effect relationships (FLEHS II). Environ Int 71:20–28.24950161
Cuomo R, Rodino S, Rizzoli R, . 1991. Bile and biliary lipid secretion in rats with hexachlorobenzene-induced porphyria. Effect of S-adenosyl-L-methionine administration. J Hepatol 12:87–93.2007778
Cupul-Uicab LA, Klebanoff MA, Brock JW, . 2013. Prenatal exposure to persistent organochlorines and childhood obesity in the US collaborative perinatal project. Environ Health Perspect 121(9):1103–1109.23799652
Currier MF, McClimans CD, Barna-Lloyd G. 1980. Hexachlorobenzene blood levels and the health status of men employed in the manufacture of chlorinated solvents. J Toxicol Environ Health 6:367–377.7392098
Czaja K, Ludwicki JK, Goralczyk K, . 1997. Organochlorine pesticides, HCB, and PCBs in human milk in Poland. Bull Environ Contam Toxicol 58(5):769–775.9115141
Dallaire F, Dewailly E, Muckle G, . 2003. Time trends of persistent organic pollutants and heavy metals in umbilical cord blood of Inuit infants born in Nunavik (Quebec, Canada) between 1994 and 2001. Environ Health Perspect 111(13):1660–1664.14527847
Dallaire R, Dewailly E, Ayotte P, . 2008. Effects of prenatal exposure to organochlorines on thyroid hormone status in newborns from two remote coastal regions in Quebec, Canada. Environ Res 108(3):387–392.18814871
Dallaire R, Dewailly E, Pereg D, . 2009a. Thyroid function and plasma concentrations of polyhalogenated compounds in Inuit adults. Environ Health Perspect 117(9):1380–1386.19750101
Dallaire R, Muckle G, Dewailly E, . 2009b. Thyroid hormone levels of pregnant Inuit women and their infants exposed to environmental contaminants. Environ Health Perspect 117(6):1014–1020.19590699
D’Amour M, Charbonneau M. 1992. Sex-related difference in hepatic glutathione conjugation of hexachlorobenzene in the rat. Toxicol Appl Pharmacol 112:229–234.1539160
Daniel V, Huber W, Bauer K, . 2001. Associations of blood levels of PCB, HCHs, and HCB with numbers of lymphocyte subpopulations, in vitro lymphocyte response, plasma cytokine levels, and immunoglobulin autoantibodies. Environ Health Perspect 109(2):173–178.11266329
Darvill T, Lonky E, Reihman J, . 2000. Prenatal exposure to PCBs and infant performance on the Fagan Test of Infant Intelligence. Neurotoxicology 21(6):1029–1038.11233749
da Silva Augusto LG, Lieber SR, Ruiz MA, . 1997. Micronucleus monitoring to assess human occupational exposure to organochlorides. Environ Mol Mutagen 29:46–52.9020306
Davis BD, Morgan RC. 1986. Hexachlorobenzene in hazardous waste sites. IARC Sci Publ 77:23–30.
de Andrea MM, Papini S, Nakagawa LE. 2001. Optimizing microwave-assisted solvent extraction (MASE) of pesticides from soil. J Environ Sci Health B 36(1):87–93.11281258
*Debets FM, Hamers WJ, Strik JJ. 1980b. Metabolism as a prerequisite for the porphyrinogenic action of polyhalogenated aromatics, with special reference to hexachlorobenzene and polybrominated biphenyls (Firemaster BP-6). Int J Biochem 12:1019–1025.6256219
*Debets F, Reinders J-H, Koss G, . 1981. Effects of dietary antioxidants on the biotransformation and porphyrinogenic action of hexachlorobenzene in two strains of rats. Chem Biol Interact 37:77–94.7285248
Debets FM, Strik JJ, Olie K. 1980a. Effects of pentachlorophenol on rat liver changes induced by hexachlorobenzene, with special reference to porphyria, and alterations in mixed function oxygenases. Toxicology 15:181–195.7466831
De Felip E, di Domenico A, Miniero R, . 2004. Polychlorobiphenyls and other organochlorine compounds in human follicular fluid. Chemosphere 54(10):1445–1449.14659946
Dellinger B, Taylor PH, Tirey DA. 1989. Pathways of formation of chlorinated PICs from the thermal degradation of simple chlorinated hydrocarbons. J Hazard Mater 22:175–186.
De Matteis F, Prior BE, Rimington C. 1961. Nervous and biochemical disturbances following hexachlorobenzene intoxication. Nature 191:363–366.13720711
Den Besten C, Bennik MHJ, Bruggeman I, . 1993. The role of oxidative metabolism in hexachlorobenzene-induced porphyria and thyroid hormone homeostasis: A comparison with pentachlorobenzene in a 13-week feeding study. Toxicol Appl Pharmacol 119:181–194.8480328
Den Besten C, Bennik MHJ, van Iersel M, . 1994. Comparison of the urinary metabolite profiles of hexachlorobenzene and pentachlorobenzene in the rat. Chem Biol Interact 90:121–137.8156603
Denham M, Schell LM, Deane G, . 2005. Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115(2):e127–134.15653789
Den Hond E, Dhooge W, Bruckers L, . 2011. Internal exposure to pollutants and sexual maturation in Flemish adolescents. J Expo Sci Environ Epidemiol 21:224–233.20197795
Den Tonkelaar EM, Verschuuren HG, Bankovska J, . 1978. Hexachlorobenzene toxicity in pigs. Toxicol Appl Pharmacol 43:137–145.625756
Devanathan G, Subramanian A, Someya M, . 2009. Persistent organochlorines in human breast milk from major metropolitan cities in India. Environ Pollut 157(1):148–154.18775594
DeVault DS. 1985. Contaminants in fish from Great Lakes Harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
Dewailly E, Ayotte P, Bruneau S, . 1993. Inuit exposure to organochlorines through the aquatic food chain in arctic Quebec. Environ Health Perspect 101(7):618–620.8143594
Dewailly E, Ayotte P, Bruneau S, . 2000. Susceptibility to infections and immune status in Inuit infants exposed to organochlorines. Environ Health Perspect 108(3):205–211.10706525
Dewailly E, Dodin S, Verreault R, . 1994. High organochlorine body burden in women with estrogen receptor-positive breast cancer. J Natl Cancer Inst 86(3):232–234.8283497
Dewailly E, Mulvad G, Pedersen HS, . 1999. Concentration of organochlorines in human brain, liver, and adipose tissue autopsy samples from Greenland. Environ Health Perspect 107(10):823–828.
Djordjevic MV, Hoffmann D, Fan J, . 1994. Assessment of chlorinated pesticides and polychlorinated biphenyls in adipose breast tissue using a supercritical fluid extraction method. Carcinogenesis 15(11):2581–2585.7955109
Dmitrovic J, Chan SC, Chan SH. 2002. Analysis of pesticides and PCB congeners in serum by GC/MS with SPE sample cleanup. Toxicol Lett 134(1–3):253–258.12191885
DOE. 2012a. Table 3: PACs by CASRN (pdf). PAC Rev 27 Tables - PAC data and chemical properties presented in pdf and excel tables. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for Chemicals of Concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 4, 2015.
DOE. 2012b. Protective action criteria (PAC): Chemicals with AEGLs, ERPGs, & TEELs. Definition of PACs (AEGLs, ERPGs or TEELs). Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for Chemicals of Concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 24, 2015.
Dogramaci I. 1964. Porphyrias and porphyrin metabolism with special reference to porphyria in childhood. Adv Pediatr 13:11–63.14153771
Domingo JL, Schuhmacher M, Agramunt MC, . 2001. Levels of metals and organic substances in blood and urine of workers at a new hazardous waste incinerator. Int Arch Occup Environ Health 74:263–269.11401018
Dorgan JF, Brock JW, Rothman N, . 1999. Serum organochlorine pesticides and PCBs and breast cancer risk: Results from a prospective analysis (USA). Cancer Causes Control 10:1–11.10334636
Dowdle E, Mustard P, Eales L. 1967. δ-Aminolevulenic acid synthetase activity in normal and porphyric human livers. S Afr Med J 41:1093–1096.6061512
Dreisbach RH. 1983. Dermatitis due to contact with chemicals. In: Handbook of poisoning. Norwalk, Connecticut: Appleton & Lange, Lange Medical Publications, 88–89.
Driscoll MS, Hassett JP, Fish CL, . 1991. Extraction efficiencies of organochlorine compounds from Niagara River (New York, USA) water. Environ Sci Technol 25(8):1432–1439.
Drobacheff C, Derancourt C, Van Landuyt, . 1998. Porphyria cutanea tarda associated with human immunodeficiency virus infection. Eur J Dermatol 8(7):492–496.9854161
Dubois M, Grosse Y, Thome JP, . 1997. Metabolic activation and DNA-adducts detection as biomarkers of chlorinated pesticide exposures. Biomarkers 2:17–24.23899150
Ecker S, Horak O. 1994. Pathways of HCB contamination to oil pumpkin seeds. Chemosphere 29(9–11):2135–2145.
Egger NG, Goeger DE, Payne DA, . 2002. Porphyria cutanea tarda: Multiplicity of risk factors including HFE mutations, hepatitis C, and inherited uroporphyrinogen decarboxylase deficiency. Dig Dis Sci 47(2):419–426.11855561
Eggesbø M, Stigum H, Longnecker MP, . 2009. Levels of hexachlorobenzene (HCB) in breast milk in relation to birth weight in a Norwegian cohort. Environ Res 109(5):559–566.19410245
Eiceman GA, Clement RE, Karasek FW. 1981. Variations in concentrations of organic compounds including polychlorinated dibenzo-p-dioxins and polynuclear aromatic hydrocarbons in fly ash from a municipal incinerator. Anal Chem 53:955–959.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Tech 15(1):30–38.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
Elder GH, Urquhart AJ. 1986. Immunochemical studies of the uroporphyrinogen decarboxylase defect caused by hexachlorobenzene. In: Morris CR, Cabral JRP, eds. Hexachlorobenzene: Proceedings of an International Symposium. IARC Sci Publ 77:441–448.
Elder GH, Evans JO, Matlin S. 1976. The effect of the porphyrinogenic compound, hexachlorobenzene on the activity of hepatic uroporphyrinogen decarboxylase in rat liver. Clin Sci Mol Med 51:71–80.939068
Elder VA, Proctor BL, Hites RA. 1981. Organic compounds found near dump sites in Niagara Falls, New York. Environ Sci Technol 15:1237–1243.22299705
Elkin BT, Bethke RW. 1995. Environmental contaminants in caribou in the Northwest Territories, Canada. Sci Total Environ 160–161:307–321.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Press, 1078–1080.
Elliott JE. 2005. Chlorinated hydrocarbon contaminants and stable isotope ratios in pelagic seabirds from the north Pacific Ocean. Arch Environ Contam Toxicol 49(1):89–96.15959703
Elliott JE, Martin PA. 1994. Chlorinated hydrocarbons and shell thinning in eggs of (Accipiter) hawks in Ontario, 1986-1989. Environ Pollut 86(2):189–200.15091636
Engst R, Macholz RM, Kujawa M. 1976. The metabolism of hexachlorobenzene (HCB) in rats. Bull Environ Contam Toxicol 16:248–252.822909
Ennaceur S, Driss MR. 2013. Time course of organochlorine pesticides and polychlorinated biphenyls in breast-feeding mothers throughout the first 10 months of lactation in Tunisia. Environ Monit Assess 185(2):1977–1984.22644123
Ennaceur S, Gandoura N, Driss MR. 2007. Organochlorine pesticide residues in human milk of mothers living in northern Tunisia. Bull Environ Contam Toxicol 78(5):325–329.17619799
Ennaceur S, Gandoura N, Driss MR. 2008. Distribution of polychlorinated biphenyls and organochlorine pesticides in human breast milk from various locations in Tunisia: Levels of contamination, influencing factors, and infant risk assessment. Environ Res 108(1):86–93.18614165
EPA. 1975a. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.
EPA. 1975b. Survey of industrial process data. Task 1. Hexachlorobenzene and hexachlorobutadiene pollution from chlorocarbon processing. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. PB 243-641.
EPA. 1976a. An ecological study of hexachlorobenzene (HCB). Washington, DC: U.S. Environmental Protection Agency. EPA560676009. PB252651.
EPA. 1976b. Sampling and analysis of selected toxic substances. Task 1A- Hexachlorobenzene. Washington, DC: U.S. Environmental Protection Agency. EPA560676001.
EPA. 1980a. Ambient water quality criteria for chlorinated benzenes. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Regulations and Standards. EPA440580028.
EPA. 1980b. Manual of analytical methods for the analysis of pesticide residues in humans and environmental samples: A compilation of methods selected for use in pesticide monitoring programs. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Environmental Toxicology Division. EPA600880038.
EPA. 1981. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014.
EPA. 1984. Methods for organic chemical analysis of municipal and industrial wastewater. Base/neutral and acids (Method 625). Washington, DC: U.S. Environmental Protection Agency. PB83201798.
EPA. 1985. Standards for the management of specific hazardous wastes and specific types of hazardous waste management facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.
EPA. 1986a. Method 8410: Capillary column analysis of semivolatile organic compounds by gas chromatography/Fourier transform infrared (GC/FT-IR) spectrometry. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1986b. Exposure assessment for hexachlorobenzene. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. EPA560586019.
EPA. 1986c. Broad scan analysis of the FY82 national human adipose tissue survey specimens: Volume I - Executive summary. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560586035.
EPA. 1987. Measurement of hydrolysis rate constants for evaluation of hazardous waste land disposal. Vol 2. Washington, DC: U.S. Environmental Protection Agency. EPA-6005387019.
EPA. 1988a. Drinking water criteria document for hexachlorobenzene. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office, Office of Health and Environmental Assessment. ECAOCIN424.
EPA. 1988b. Compendium of methods for the determination of toxic organic compounds in ambient air. Research Triangle Park, NC: U.S. Environmental Protection Agency, Quality Assurance Division, Environmental Monitoring Systems Laboratory. EPA600489017.
EPA. 1988c. Method 508: Method for the determination of organic compounds in drinking water. Washington, DC: U.S. Environmental Protection Agency. EPA600488039.
EPA. 1989a. Land disposal restrictions for second third scheduled wastes; proposed rule. Part II. Fed Regist. 54(7):1056–1119.
EPA. 1989b. Method 505. Analysis of organohalide pesticides and commercial polychlorinated biphenyl (PCB) products in water by microextraction and gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency. http://water.epa.gov/scitech/methods/cwa/bioindicators/upload/2007_11_06_methods_method_505.pdf. October 12, 2012.
EPA. 1990a. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1990b. Nonoccupational pesticide exposure study (NOPES). Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600390003.
EPA. 1991. Method 525.1. Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. U.S. Environmental Protection Agency. http://water.epa.gov/scitech/methods/cwa/bioindicators/upload/2007_11_06_methods_-method_525_1.pdf. October 12, 2012.
EPA. 1992. National study of chemical residues in fish. Vol. 1. Washington, DC: U.S. Environmental Protection Agency, Office of Science and Technology. EPA823R92008a.
EPA. 1993. Guidance for assessing chemical contaminant data for use in fish advisories. Vol. 1. Fish sampling and analysis. Washington DC: U.S. Environmental Protection Agency, Office of Water. EPA823R93002.
EPA. 1994. Test methods for evaluating solid waste. Volume IB: Laboratory manual physical/chemical methods. Method 8270B. U.S. Environmental Protection Agency.
EPA. 1995a. Guidance for assessing chemical contaminant data for use in fish advisories. Vol 1: Fish sampling and analysis. Second Edition. Washington, DC: U.S. Environmental Protection Agency, Office of Science and Technology. EPA823R95007.
EPA. 1995b. Toxic chemical release inventory. Reporting form R and instructions. Washington DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA745K95051.
EPA. 1997a. Listing of fish and wildlife consumption advisories. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1997b. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2009a. Pentachloronitrobenzene (PCNB); Notice of receipt of request to amend registrations to terminate uses of certain pesticide registrations. Fed Regist 74(59):14122–14125.
EPA. 2009b. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2012a. Method 612-Chlorinated hydrocarbons. U.S. Environmental Protection Agency. Code of Federal Regulations Pt 136 App. A. http://www.gpo.gov/fdsys/pkg/CFR-2012-title40-vol24/pdf/CFR-2012-title40-vol24-chapI.pdf. October 12, 2012.
EPA. 2012b. 2012 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. March 4, 2015.
EPA. 2012c. National ambient air quality standards (NAAQS). Washington, DC: Office of Air and Radiation, U.S. Environmental Protection Agency. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2013a. Title 42 - The public health and welfare. Chapter 85 - Air pollution prevention and control. Subchapter I - programs and activities. Part A - Air quality and emission limitations. Hazardous air pollutants. United States Code 42 USC 7412. http://www.gpo.gov/fdsys/pkg/USCODE-2013-title42/pdf/USCODE-2013-title42-chap85-subchapI-partA-sec7412.pdf. April 9, 2015.
EPA. 2013b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec116-4.pdf. March 4, 2015.
EPA. 2013c. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. March 4, 2015.
EPA. 2013d. Determination of reportable quantities for hazardous substances. Subpart A - General provisions. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec117-3.pdf. March 4, 2015.
EPA. 2013e. Appendix VIII to Part 261-Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol27/pdf/CFR-2013-title40-vol27-part261-appVIII.pdf. September 10, 2014.
EPA. 2013f. Appendix A to Part 355—The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part355-appA.pdf. September 10, 2014.
EPA. 2014. Draft: Updated national recommended water quality criteria - human health. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://water.epa.gov/scitech/swguidance/standards/criteria/current/hhdraft.cfm. April 9, 2015.
EPA. 2014a. Final AEGLs (162). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_03oct2014.pdf. March 4, 2015.
EPA. 2014c. InertFinder. U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=101:1:. March 31, 2015.
EPA. 2014d. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec302-4.pdf. March 4, 2015.
EPA. 2014e. Chemicals and chemical categories to which this part applies. Subpart D - Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec372-65.pdf. March 4, 2015.
EPA. 2014f. Chemical lists and reporting periods. Subpart B - Manufacturers reporting - preliminary assessment information. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol31/pdf/CFR-2014-title40-vol31-sec712-30.pdf. April 9, 2015.
EPA. 2014g. Substances and listed mixtures to which this subpart applies. Subpart B - Specific chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol31/pdf/CFR-2014-title40-vol31-sec716-120.pdf. April 9, 2015.
Erdoğrul O, Covaci A, Kurtul N, . 2004. Levels of organohalogenated persistent pollutants in human milk from Kahramanmaras region, Turkey. Environ Int 30(5):659–666.15051242
Ertürk E, Lambrecht RW, Peters HA, . 1986. Oncogenicity of hexachlorobenzene. IARC Sci Publ 77:417–423.
Ezendam J, Hassing I, Bleumink R, . 2004a. Hexachlorobenzene-induced immunopathology in Brown Norway rats is partly mediated by T cells. Toxicol Sci 78(1):88–95.14657514
Ezendam J, Staedtler F, Pennings J, . 2004b. Toxicogenomics of subchronic hexachlorobenzene exposure in Brown Norway rats. Environ Health Perspect 112(7):782–791.15159207
Falck F, Ricci A, Wolff MS, . 1992. Pesticides and polychlorinated biphenyl residues in human breast lipids and their relation to breast cancer. Arch Environ Health 47(2):143–146.1567239
Farm Chemicals Handbook. 2001. Hexachlorobenzene. Vol. 87. Willoughby, OH: Meister Publishing Company, C218.
Farmer WT, Yank M, Letey J, . 1976. Land disposal of organic hazardous waste containing HCB. In: National conference of residues on land proceedings. St. Louis, MO: Environmental Protection Agency, 83–86.
Farrar NJ, Prevedouros K, Harner T, . 2006. Continental scale passive air sampling of persistent organic pollutants using rapidly equilibrating thin films (POGs). Environ Pollut 144(2):423–433.16631285
Fathepure BZ, Tiedje JM, Boyd SA. 1988. Reductive dechlorination of hexachlorobenzene to tri- and dichlorobenzenes in anaerobic sewage sludge. Appl Environ Microbiol 54:327–330.3355129
FDA. 1989. Food and Drug Administration pesticide program - residues in foods 1988. J AOAC Int 72(5):133A–152A.
FDA. 1990. Food and Drug Administration pesticide program - residues in foods 1989. J Assoc Off Anal Chem 73:127A–146A.
FDA. 1991. Food and Drug Administration pesticide program - residues in foods 1990. J Assoc Off Anal Chem 74(5):121A–140A.
FDA. 1992. Food and Drug Administration pesticide program - residues in foods 1991. J Assoc Off Anal Chem 75:135A–157A.
FDA. 1994. Food and Drug Administration pesticide program - residue monitoring. Residues in food-1993. J AOAC Int 77(5):161A–185A.
FDA. 1995. Residue monitoring, 1994 (8th annual FDA pesticide residue monitoring program report). J AOAC Int 78(5):119A–142A.
FDA. 2006a. US Food and Drug Administration - Total diet study. Market baskets 1991-3 through 2003-4. College Park, Maryland: U.S. Food and Drug Administration, Center for Food Safety and Applied Nutrition, Office of Food Safety. http:www.fda.gov/downloads/Food/FoodSafety/FoodContaminantsAdulteration/TotalDietStudy/UCM184304.pdf (http://www.fda.gov/downloads/Food/FoodSafety/FoodContaminantsAdulteration/TotalDietStudy/UCM184304.pdf). June 12, 2012.
FDA. 2006b. U.S. Food and Drug Administration - Total diet study. Market baskets 2004-1 through 2005-4. College Park, MD: U.S. Food and Drug Administration/Center for Food Safety and Applied Nutrition, Office of Food Safety. http:www.fda.gov/downloads/Food/FoodSafety/FoodContaminantsAdulteration/TotalDietStudy/UCM291686.pdf (http://www.fda.gov/downloads/Food/FoodSafety/FoodContaminantsAdulteration/TotalDietStudy/UCM291686.pdf). June 12, 2012.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Feldman ES, Bacon BR. 1989. Hepatic mitochondrial oxidative metabolism and lipid peroxidation in experimental hexachlorobenzene-induced porphyria with dietary carbonyl iron overload. Hepatology 9:686–692.2707735
Fenster L, Eskenazi B, Anderson M, . 2006. Association of in utero organochlorine pesticide exposure and fetal growth and length of gestation in an agricultural population. Environ Health Perspect 114(4):597–602.16581552
Ferguson KK, Hauser R, Altshul L, . 2012. Serum concentrations of p, p’-DDE, HCB, PCBs and reproductive hormones among men of reproductive age. Reprod Toxicol 34(3):429–435.22564984
Fernandez-Tome M, Billi de Catabbi SC, Aldonatti C, . 2000. Heme metabolism and lipid peroxidation in rat kidney hexachlorobenzene-induced porphyria: A compartmentalized study of biochemical pathogenic mechanisms. Kidney Blood Press Res 23:20–26.10567850
Fitzgerald EF, Hwang S, Deres DA, . 2001. The association between local fish consumption and DDE, mirex, and HCB concentrations in the breast milk of Mohawk women at Akwesasne. J Expo Anal Environ Epidemiol 11:381–388.11687911
Flores-Ramirez R, Ortiz-Perez MD, Batres-Esquivel L, . 2014. Rapid analysis of persistent organic pollutants by solid phase microextraction in serum samples. Talanta 123:169–178.24725880
Foley RE. 1992. Organochlorine residues in New York waterfowl harvested by hunters in 1983-1984. Environ Monit Assess 21:37–48.24234343
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Forns J, Lertxundi N, Aranbarri A, . 2012. Prenatal exposure to organochlorine compounds and neuropsychological development up to two years of life. Environ Int 45:72–77.22575806
Foster WG, McMahon A, Villeneuve DC, . 1992a. Hexachlorobenzene (HCB) suppresses circulating progesterone concentrations during the luteal phase in the cynomolgus monkey. J Appl Toxicol 12:13–17.1564247
Foster WG, McMahon A, Youngai EV, . 1995a. Alterations in circulating ovarian steroids in hexachlorobenzene-exposed monkeys. Reprod Toxicol 9(6):541–548.8597650
Foster WG, Mertineit C, Yagminas AL, . 1995b. The effects of hexachlorobenzene on circulating levels of adrenal steroids in the ovariectomized rat. J Biochem Toxicol 10(3):129–135.7473603
Foster WG, Pentick JA, McMahon A, . 1992b. Ovarian toxicity of hexachlorobenzene (HCB) in the superovulated female rat. J Biochem Toxicol 7:1–4.1588569
Foster WG, Pentick JA, McMahon A, . 1993. Body distribution and endocrine toxicity of hexachlorobenzene (HCB) in the female rat. J Appl Toxicol 13:79–83.8486915
Fracanzani AL, Taioli E, Sampietro M, . 2001. Liver cancer risk is increased in patients with porphyria cutanea tarda in comparison to matched control patients with chronic liver disease. J Hepatol 35:498–503.11682034
Frank R, Rasper J, Smout MS, . 1988. Organochlorine residues in adipose tissues, blood and milk from Ontario residents, 1976-1985. Can J Public Health 79:150–158.3135931
Freeman RA, Rozman KK, Wilson AG. 1989. Physiological pharmacokinetic model of hexachlorobenzene in the rat. Health Phys 57(Supp 1):139–147.2606677
Freire C, Koifman RJ, Sarcinelli P, . 2012. Long term exposure to organochlorine pesticides and thyroid function in children from Cidade dos Ameninos, Rio de Janeiro, Brazil. Environ Res 117:68–74.22776325
Freire C, Koifman RJ, Sarcinelli PN, . 2013. Long-term exposure to organochlorine pesticides and thyroid status in adults in a heavily contaminated area in Brazil. Environ Res 127:7–15.24183346
Freire C, Koifman RJ, Sarcinelli PN, . 2014. Association between serum levels of organochlorine pesticides and sex hormones in adults living in a heavily contaminated area in Brazil. Int J Hyg Environ Health 217(2–3):370–378.23972672
Freire C, Lopez-Espinosa MJ, Fernandez M, . 2011. Prenatal exposure to organochlorine pesticides and TSH status in newborns from southern Spain. Sci Total Environ 409(18):3281–3287.21683986
Fujii Y, Ito Y, Harada KH, . 2012. Comparative survey of levels of chlorinated cyclodiene pesticides in breast milk from some cities of China, Korea and Japan. Chemosphere 89(4):452–457.22743181
Gallo MV, Schell LM, DeCaprio AP, . 2011. Levels of persistent organic pollutants and their predictors among young adults. Chemosphere 83(10):1374–1382.21458024
García MA, Peña D, Alvarez L, . 2010. Hexachlorobenzene induces cell proliferation and IGF-1 signaling pathway in an estrogen receptor alpha-dependent manner in MCF-7 breast cancer cell line. Toxicol Lett 192(2):195–205.19879930
Garrison AW, Pellizzari ED. 1987. Application of the master analytical scheme to polar organic compounds in drinking water. In: Suffet IH, Malaiyandi M, eds. Organic pollutants in water: Sampling, analysis, and toxicity testing. Advances in Chemistry Series No. 214. American Chemical Society, 83–95.
Gartrell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980 -March 1982. J Assoc Off Anal Chem 69:123–145.3949685
Gascon M, Sunyer J, Martinez D, . 2014. Persistent organic pollutants and children’s respiratory health: The role of cytokines and inflammatory biomarkers. Environ Int 69:133–140.24837163
Gasull M, Pumarega J, Tellez-Plaza M, . 2012. Blood concentrations of persistent organic pollutants and prediabetes and diabetes in the general population of Catalonia. Environ Sci Technol 46(14):7799–7810.22681243
Gauthier JM, Metcalfe CD, Sears R. 1997. Chlorinated organic contaminants in blubber biopsies from northwestern Atlantic balaenopterid whales summering in the Gulf of St Lawrence. Mar Environ Res 44(2):201–223.
Gebuaer MB, Weseloh DV. 1993. Accumulation of organic contaminants in sentinel mallards utilizing confined disposal facilities at Hamilton Harbour, Lake Ontario, Canada. Arch Environ Contam Toxicol 25(2):234–243.
Gerhard I, Daniel V, Link S, . 1998. Chlorinated hydrocarbons in women with repeated miscarriages. Environ Health Perspect 106:675–681.9755145
Gerstenberger SL, Gallinat MP, Dellinger JA. 1997. Polychlorinated biphenyl congeners and selected organochlorines in Lake Superior fish, USA. Environ Toxicol Chem 16(11):2222–2228.
Giordano F, Abballe A, De Felip E, . 2010. Maternal exposures to endocrine disrupting chemicals and hypospadias in offspring. Birth Defects Res A Clin Mol Teratol 88(4):241–250.20196143
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gladen BC, Monaghan SC, Lukyanova EM, . 1999. Organochlorines in breast milk from two cities in Ukraine. Environ Health Perspect 107(6):459–462.10339445
Gladen BC, Shkiryak-Nyzhnyk ZA, Chyslovska N, . 2003. Persistent organochlorine compounds and birth weight. Ann Epidemiol 13(3):151–157.12604157
Glynn AW, Granath F, Aune M, . 2003. Organochlorines in Swedish women: Determinants of serum concentrations. Environ Health Perspect 111(3):349–355.12611665
Glynn AW, Wolk A, Aune M, . 2000. Serum concentrations of organochlorines in men: A search for markers of exposure. Sci Total Environ 263:197–208.11194153
Gocmen A, Peters HA, Cripps DJ, . 1989. Hexachlorobenzene episode in Turkey. Biomed Environ Sci 2:36–43.2590490
Goerz G, Bolsen K, Kalofoutis A, . 1994. Influence of oral isotretinoin on hepatic and cutaneous P-450-dependent isozyme activities. Arch Dermatol Res 286:104–106.8154922
*Goerz G, Bolsen K, Seuwen P, . 1986. Effects of chloroquine and hydroxychloroquine on the hexachlorobenzene-induced porphyria in rats. IARC Sci Publ 77:513–515.
Goerz G, Vizethum W, Bolsen K, . 1978. [Hexachlorobenzene (HCB) induced porphyria in rats. Influence of Hexachlorobenzene-metabolites on the biosynthesis of heme]. Arch Dermatol Res 263:189–196. (German)736603
Goldey ES, Taylor DH. 1992. Developmental neurotoxicity following premating maternal exposure to hexachlorobenzene in rats. Neurotoxicol Teratol 14:15–21.1593975
Goldey ES, Fisher JW, Taylor DH. 1990. Maternal transfer of hexachlorobenzene in the rat. Poster abstract-Methods in behavioral toxicology and teratology 12:562–563.
Goldstein JA, Freisen M, Linder RE, . 1977. Effects of pentachlorophenol on hepatic drug metabolism enzymes and porphyria related to contamination with chlorinated dibenzo-p-dioxins and dibenzofurans. Biochem Pharmacol 26:1549–1557.901575
Goldstein JA, Freisen M, Scotti TM, . 1978. Assessment of the contribution of chlorinated dibenzo-p-dioxins and dibenzofurans to hexachlorobenzene-induced toxicity, porphyria, changes in mixed function oxidases and histopathological changes. Toxicol Appl Pharmacol 46:633–649.106491
Goldstein JA, Linko P, Hahn ME, . 1986. Structure-activity relationships of chlorinated benzenes as inducers of hepatic cytochrome P-450 isozymes in the rat. IARC Sci Publ 77:519–526.
Goncharov A, Rej R, Negoita S, . 2009. Lower serum testosterone associated with elevated polychlorinated biphenyl concentrations in Native American men. Environ Health Perspect 117(9):1454–1460.19750113
Gopalaswamy UV, Aiyar AS. 1986. Biotransformation and toxicity of lindane and its metabolite hexachlorobenzene in mammals. IARC Sci Publ 77:267–276.
Gopalaswamy UV, Nair CKK. 1992. DNA binding and mutagenicity of lindane and its metabolites. Bull Environ Contam Toxicol 49:300–305.1377069
Gralla EJ, Fleischman RW, Luthra YK, . 1977. Toxic effects of hexachlorobenzene after daily administration to beagle dogs for one year. Toxicol Appl Pharmacol 40:227–239.877958
Grant DL, Phillips WE, Hatina GV. 1977. Effect of hexachlorobenzene on reproduction in the rat. Arch Environ Contam Toxicol 5:207–216.596941
*Green JA, Francis JE, Wolf CR, . 1989. Sexual dimorphism of cytochrome P-450 induction by hexachlorobenzene in rats. Biochem Soc Trans 17:1016–1017.2628050
Greizerstein HB, Stinson C, Mendola P, . 1999. Comparison of PCB congeners and pesticide levels between serum and milk from lactating women. Environ Res A80:280–286.
Grimalt JO, Sunyer J, Moreno V, . 1994. Risk excess of soft-tissue sarcoma and thyroid cancer in a community exposed to airborne organochlorinated compound mixtures with a high hexachlorobenzene content. Int J Cancer 56:200–203.8314301
Grinstein M. 1977. Simplified method for the determination of porphyrins in body fluids. Anal Biochem 77:577–580.842845
Guerranti C, Palmieri M, Mariottini M, . 2011. Persistent organic pollutants in human milk from central Italy: Levels and time trends. ISRN Toxicology 2011:107514.23724278
Guerzoni ME, Del Cupolo L, Ponti I. 1976. Mutagenic activity of pesticides. Riv Sci Tecnol Alimenti Nutr Um 6:161–165.
Gullett BK, Touati A, Hays MD. 2003. PCDD/F, PCB, HxCBz, PAH, and PM emission factors for fireplace and woodstove combustion in the San Francisco Bay region. Environ Sci Technol 37(9):1758–1765.12775046
Gunderson EL. 1988. FDA total diet study, April 1982-April 1984. Dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Guo H, Jin Y, Cheng Y, . 2014. Prenatal exposure to organochlorine pesticides and infant birth weight in China. Chemosphere 110:1–7.24880592
Gustafson DL, Long ME, Thomas RS, . 2000. Comparative hepatocarcinogenicity of hexachlorobenzene, pentachlorobenzene, 1,2.4,5-Tetrachlorobenzene, and 1,4-Dichlorobenzene: Application of a medium-term liver focus bioassay and molecular and cellular indices. Toxicol Sci 53:245–252.10696772
Guttes S, Failing K, Neumann K, . 1998. Chlororganic pesticides and polychlorinated biphenyls in breast tissue of women with benign and malignant breast disease. Arch Environ Contam Toxicol 35:140–147.9601932
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Winchester JF, eds. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Co., 1084–1085.
Hadjab S, Maurel D, Cazals Y, . 2004. Hexachlorobenzene, a dioxin-like compound, disrupts auditory function in rat. Hear Res 191(1–2):125–134.15109712
Hageman KJ, Simonich SL, Campbell DH, . 2006. Atmospheric deposition of current-use and historic-use pesticides in snow at national parks in the western United States. Environ Sci Technol 40(10):3174–3180.16749678
Hagmar L, Bjork J, Sjodin A, . 2001. Plasma levels of persistent organohalogens and hormone levels in adult male humans. Arch Environ Health 56(2):138–143.11339677
Hagmar L, Wallin E, Vessby B, . 2006. Intra-individual variations and time trends 1991-2001 in human serum levels of PCB, DDE and hexachlorobenzene. Chemosphere 64(9):1507–1513.16466768
Hahn ME, Gasiewicz TA, Linko P, . 1988. The role of the Ah locus in hexachlorobenzene-induced porphyria: Studies in congenic C57BL/6J mice. Biochem J 254:245–254.2845946
Hahn ME, Goldstein JA, Linko P, . 1989. Interaction of hexachlorobenzene with the receptor for 2,3,7,8-tetrachlorodibenzo-p-dioxin in vitro and in vivo. Arch Biochem Biophys 270:344–355.2539049
Hansch C, Leo A, Hoekman D. 1995. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 15.
Hansen LG, Simon J, Dorn SB, . 1979. Hexachlorobenzene distribution in tissues of swine. Toxicol Appl Pharmacol 51:1–7.524362
Hansen S, Strom M, Olsen SF, . 2014. Maternal concentrations of persistent organochlorine pollutants and the risk of asthma in offspring: Results from a prospective cohort with 20 years of follow-up. Environ Health Perspect 122(1):93–99.24162035
*Hanstein WG, Heitmann TD, Sandy A, . 1981. Effects of hexachlorobenzene and iron loading on rat liver mitochondria. Biochim Biophys Acta 678:293–299.7317454
Haraguchi K, Koizumi A, Inoue K, . 2009. Levels and regional trends of persistent organochlorines and polybrominated diphenyl ethers in Asian breast milk demonstrate POPs signatures unique to individual countries. Environ Int 35(7):1072–1079.19573925
Hardell L, Andersson SO, Carlberg M, . 2006a. Adipose tissue concentrations of persistent organic pollutants and the risk of prostate cancer. J Occup Environ Med 48(7):700–707.16832227
Hardell L, Van Bavel B, Lindstrom G, . 1997. Increased age-related concentrations of polychlorinated biphenyls in four male patients with Ewing’s sarcoma. Int J Environ Health Res 7:307–313.
Hardell L, van Bavel B, Lindstrom G, . 2003. Increased concentrations of polychlorinated biphenyls, hexachlorobenzene, and chlordanes in mothers of men with testicular cancer. Environ Health Perspect 111(7):930–934.12782494
Hardell L, van Bavel B, Lindstrom G, . 2006b. In utero exposure to persistent organic pollutants in relation to testicular cancer risk. Int J Androl 29(1):228–234.16371110
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen (suppl 1):3–142.
Haynes WM, Lide DR. 2010. CRC Handbook of chemistry and physics. 91st ed. Boca Raton, FL: CRC Press, 3-276–3-277.
HazDat. 2007. Hexachlorobenzene. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*Headley DB, Lambrecht RW, Erturk E, . 1981. Neuropathology and tissue levels of hexachlorobenzene (HCB) fed to rats, mice and hamsters. Proceedings Fed Am Soc Exp Bio 40(3P1):699. (Abstract)
Hebert CE, Weseloh DV, Kot L, . 1994. Organochlorine contaminants in a terrestrial foodweb on the Niagara Peninsula, Ontario Canada 1987-1989. Arch Environ Contam Toxicol 26:356–366.
Herrero C, Ozalla D, Sala M, . 1999. Urinary porphyrin excretion in a human population highly exposed to hexachlorobenzene. Arch Dermatol 135:400–404.10206046
Heyer NJ, Echeverria D, Woods JS. 2012. Disordered porphyrin metabolism: A potential biological marker for autism risk assessment. Autism Res 5:84–92.22298513
Hinck JE, Blazer VS, Denslow ND, . 2008. Chemical contaminants, health indicators, and reproductive biomarker responses in fish from rivers in the southeastern United States. Sci Total Environ 390(2–3):538–557.18036634
Hippelein M, Kaupp H, Doerr G, . 1993. Testing of a sampling system and analytical method for determination of semivolatile organic compounds in ambient air. Chemosphere 26(12):2255–2263.
Hirsch M, Hutzinger O. 1989. Naturally occurring proteins from pond water sensitize hexachlorobenzene photolysis. Environ Sci Technol 23(10):1306–1307.
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoff RM, Muir DCG, Grift NP. 1992. Annual cycle of polychlorinated biphenyls and organohalogen pesticides in air in Ontario. 2. Atmospheric transport and sources. Environ Sci Technol 26:276–283.
Hoff RM, Strachan MJ, Sweet CW, . 1996. Atmospheric deposition of toxic chemicals to the Great Lakes: A review of data through 1994. Atmos Environ 30(20):3505–3527.
Hoppin JA, Tolbert PE, Holly EA, . 2000. Pancreatic cancer and serum organochlorine levels. Cancer Epidemiol Biomarkers Prev 9:199–205.10698482
Hosie S, Loff S, Witt K, . 2000. Is there a correlation between organochlorine compounds and undescended testes? Eur J Pediatr Surg 10:304–309.11194541
Hou H, Zhao L, Zhang J, . 2013. Organochlorine pesticides and polychlorinated biphenyls in soils surrounding the Tanggu chemical industrial district of Tianjin, China. Environ Sci Pollut Res Int 20(5):3366–3380.23108756
Houde M, Muir DC, Kidd KA, . 2008. Influence of lake characteristics on the biomagnification of persistent organic pollutants in lake trout food webs. Environ Toxicol Chem 27(10):2169–2178.18444699
Howard PH, ed. 1990. Handbook of environmental fate and exposure data for organic chemicals. Chelsea, MI: Lewis Publishers Vol I: 351–359.
Howard PH, Boethling RS, Jarvis WF, ., eds. 1991. Handbook of environmental degradation rates. Chelsea, MI: Lewis Publishers, 452–453.
Howsam M, Grimalt JO, Guino E, . 2004. Organochlorine exposure and colorectal cancer risk. Environ Health Perspect 112(15):1460–1466.15531428
Høyer AP, Jorgensen T, Rank F, . 2001. Organochlorine exposures influence on breast cancer risk and survival according to estrogen receptor status: A Danish cohort-nested case-control study. BMC Cancer 1:8.11518544
HSDB. 2012. Hexachlorobenzene. Hazardous Substances Data Bank. National Library of Medicine. http:toxnet.nlm.nih.gov (http://toxnet.nlm.nih.gov). May 14, 2012.
Huang X, Wang S, Fan X. 1989. The effect of hexachlorobenzene and DDT on reproductive outcomes of rural women. Environ Mol Mutagen 14(Suppl. 15):92.
Huang Y, Li J, Xu Y, . 2014. Polychlorinated biphenyls (PCBs) and hexachlorobenzene (HCB) in the equatorial Indian Ocean: Temporal trend, continental outflow and air-water exchange. Mar Pollut Bull 80(1–2):194–199.24462236
IARC. 1979. International Agency for Research on Cancer (IARC) monograph on the evaluation of the carcinogenic risk of chemicals to humans: Some halogenated hydrocarbons. Vol. 20. International Agency for Research on Cancer, World Health Organization, Lyon, France, 155–178.
IARC. 2015. Agents classified by the IARC monographs. Volumes 1–112. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. March 31, 2015.
Iatropoulos MJ, Bailey J, Adams HP, . 1978. Response of nursing infant Rhesus to clophen A-30 or hexachlorobenzene given to their lactating mothers. Environ Res 16:38–47.98325
Iatropoulos MJ, Hobson W, Knauf V, . 1976. Morphological effects of hexachlorobenzene toxicity in female Rhesus monkeys. Toxicol Appl Pharmacol 37:433–444.823668
Iatropoulos MJ, Milling A, Muller WF, . 1975. Absorption, transport and organotropism of dichlorobiphenyl (DCB), dieldrin, and hexachlorobenzene (HCB) in rats. Environ Res 10:384–389.1213019
Ingebrigtsen K. 1986. Comparative studies on the distribution and excretion of ^14^C-hexachlorobenzene by whole-body autoradiography. IARC Sci Publ 77:277–285.
Ingebrigtsen K, Nafstad I. 1983. Distribution and elimination of ^14^C-hexachlorobenzene after single oral exposure in the male rat. Acta Pharmacol Toxicol 52:254–260.
Ingebrigtsen K, Skaare JU, Nafstad I, . 1981. Studies on the biliary excretion and metabolites of hexachlorobenzene in the rat. Xenobiotica 11:795–800.7336761
Ingebrigtsen K, Skaare JU, Nafstad I, . 1986. Metabolism of hexachlorobenzene (HCB) in the isolated perfused rat liver. Gen Pharmacol 17:19–24.3949147
IRIS. 2003. Hexachlorobenzene. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. April 10, 2015.
Isensee AR, Holden ER, Woolson EA, . 1976. Soil persistence and aquatic bioaccumulation potential of hexachlorobenzene (HCB). J Agric Food Chem 24:1210–1214.1036745
*Ito N, Tsuda H, Hasegawa R, . 1983. Comparison of the promoting effects of various agents in induction of preneoplastic lesions in rat liver. Environ Health Perspect 50:131–138.6191977
Itoh H, Iwasaki M, Hanaoka T, . 2009. Serum organochlorines and breast cancer risk in Japanese women: A case-control study. Cancer Causes Control 20(5):567–580.19031103
*Ivanov E, Savov G, Adjarov D. 1986. Changes in some intestinal enzyme activities in experimental hexachlorobenzene-induced porphyria and modifying effects of diet. IARC Sci Publ 77:611–618.
Iwasaki M, Inoue M, Sasazuki S, . 2008. Plasma organochlorine levels and subsequent risk of breast cancer among Japanese women: A nested case-control study. Sci Total Environ 402(2–3):176–183.18555519
Jackson MA, Stack HF, Waters MD. 1993. The genetic toxicology of putative nongenotoxic carcinogens. Mutat Res 296:241–277.7680106
Jandacek RJ, Anderson N, Liu M, . 2005. Effects of yo-yo diet, caloric restriction, and olestra on tissue distribution of hexachlorobenzene. Am J Physiol Gastrointest Liver Physiol 288(2):G292–G299.15513954
Jansson B, Bergman A. 1978. Sulfur-containing derivatives of hexachlorobenzene (HCB) -metabolites in the rat. Chemosphere 7(3):257–268.
Jantunen M, Jaakkola JJK, Kryzanowski M, eds. 1997. Pesticides. In: Assessment of exposure to indoor air pollutants. World Health Organization Regional Publications. European Series 78:96–98.
Jarman WM, Burns SA, Bacon CE, . 1996. High levels of HCB and DDE associated with reproductive failure in prairie falcons (Falco mexicanus) from California. Bull Environ Contam Toxicol 57:8–15.8661453
Jarrell JF, Gocmen A, Akyol D, . 2002. Hexachlorobenzene exposure and the proportion of male births in Turkey 1935-1990. Reprod Toxicol 16(1):65–70.11934533
Jarrell J, Gocmen A, Foster W, . 1998. Evaluation of reproductive outcomes in women inadvertently exposed to hexachlorobenzene in Southeastern Turkey in the 1950s. Reprod Toxicol 12(4):469–476.9717698
Jarrell JF, McMahon A, Villeneuve D, . 1993. Hexachlorobenzene toxicity in the monkey primordial germ cell without induced porphyria. Reprod Toxicol 7:41–47.8448415
Johansen HR, Becher G, Polder A, . 1994. Congener-specific determination of polychlorinated biphenyls and organochlorine pesticides in human milk from Norwegian mothers living in Oslo. J Toxicol Environ Health 42:157–171.8207752
Johnson-Restrepo B, Addink R, Wong C, . 2007. Polybrominated diphenyl ethers and organochlorine pesticides in human breast milk from Massachusetts, USA. J Environ Monit 9(11):1205–1212.17968447
Julvez J, Debes F, Weihe P, . 2011. Thyroid dysfunction as a mediator of organochlorine neurotoxicity in preschool children and supplemental information. Environ Health Perspect 119(10):1429–1435.21719373
Kamarianos A, Karamanlis X, Goulas P, . 2003. The presence of environmental pollutants in the follicular fluid of farm animals (cattle, sheep, goats, and pigs). Reprod Toxicol 17(2):185–190.12642151
Kan-DO Office and Pesticide Teams. 1995. Accumulated pesticide and industrial chemical findings from a ten-year study of ready to eat foods. J AOAC Int 78(3):614–630.7756874
Karlsson H, Muir DCG, Teixiera CF, . 2000. Persistent chlorinated pesticides in air, water, and precipitation from the Lake Malawi area, Southern Africa. Environ Sci Technol 34(6):4490–4495.
Karlsson N, Fangmark I, Haggqvist I, . 1991. Mutagenicity testing of condensates of smoke from titanium dioxide/hexachloroethane and zinc/hexachloroethane pyrotechnic mixtures. Mutat Res 260:39–46.2027339
Karmaus W, DeKoning EP, Kruse H, . 2001. Early childhood determinants of organochlorine concentrations in school-aged children. Pediatr Res 50(3):331–336.11518819
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167.13679531
Keczkes K, Barker DJ. 1976. Malignant hepatoma associated with acquired hepatic cutaneous porphyria. Arch Dermatol 112:125–129.
Kelly TJ, Czuczwa JM, Sticksel PR, . 1991. Atmospheric and tributary inputs of toxic substances to Lake Erie. J Great Lakes Res 17(4):504–516.
Kenaga EE, Goring GAI. 1978. Relationship between water solubility, soil sorption, octanol-water partitioning and concentration of chemicals in biota. In: Aquatic toxicology, 79–115.
Kennedy SW, Wigfield DC. 1990. Dose-response relationships in hexachlorobenzene-induced porphyria. Biochem Pharmacol 40:1381–1388.2403392
Khan F, Dhan P, Jain RK. 2011. Development of an HPLC method for determination of pentachloronitrobenzene, hexachlorobenzene and their possible metabolites. BMC Chem Biol 11(1):2.22112041
*Khanna RN, Smith AG. 1986. Distribution, excretion and in-vivo metabolism of ^14^C-hexachlorobenzene and the influence of iron overload in C57BL/10 mice. IARC Sci Publ 77:319–321.
Khera KS. 1974. Teratogenicity and dominant lethal studies on hexachlorobenzene in rats. Food Cosmet Toxicol 12:471–477.4459243
Kim D, Kim M, Jang J, . 2013. Monitoring of environmental contaminants in raw bovine milk and estimates of dietary intakes of children in South Korea. Chemosphere 93:561–566.23866173
Kimbrough RD, Linder RE. 1974. The toxicity of technical hexachlorobenzene in the Sherman strain rat: A preliminary study. Res Comm Chem Pathol Pharmacol 8:653–664.
Kimbrough RD, Linder RE. 1978. The effect of technical and purified pentachlorophenol on the rat liver. Toxicol Appl Pharmacol 46:151–162.725940
Kishima MO, Barbisan LF, Estevao D, . 2000. Promotion of heptocarcinogenesis by hexachlorobenzene in energy-restricted rats. Cancer Lett 152:37–44.10754204
Kitchin KT, Brown JL. 1989. Biochemical studies of promoters of carcinogenesis in rat liver. Teratog Carcinog Mutagen 9:273–285.2575289
Kitchin KT, Linder RE, Scotti TM, . 1982. Offspring mortality and maternal lung pathology in female rats fed hexachlorobenzene. Toxicology 23:33–39.7089983
Klaassen CD, Amdur MO, Doull J, eds. 1995. Biotransformation of xenobiotics. In: Casarett and Doull’s Toxicology: The Basic Science of Poisons. 5th Edition. New York, NY: McGraw Hill, 139–163.
Kleiman de Pisarev DL, Rios de Molina MC, San Martin de Viale LC. 1990. Thyroid function and thyroxine metabolism in hexachlorobenzene-induced porphyria. Biochem Pharmacol 39:817–825.2310407
Kleiman de Pisarev DL, Sancovich HA, Ferramola de Sancovich AM. 1989. Enhanced thyroxine metabolism in hexachlorobenzene-intoxicated rats. J Endocrinol Invest 12:767–772.2614013
Kleiman de Pisarev DL, Sancovich HA, Ferramola de Sancovich AM. 1995. Hepatic indices of thyroid status in rats treated with hexachlorobenzene. J Endocrinol Invest 18:271–276.7560808
Klinčić D, Romanic SH, Saric MM, . 2014. Polychlorinated biphenyls and organochlorine pesticides in human milk samples from two regions in Croatia. Environ Toxicol Pharmacol 37(2):543–552.24562053
Knauf V, Hobson W. 1979. Hexachlorobenzene ingestion by female Rhesus monkeys: Tissue distribution and clinical symptomatology. Bull Environ Contam Toxicol 21:243–248.109142
Koblizkova M, Genualdi S, Lee SC, . 2012. Application of sorbent impregnated polyurethane foam (SIP) disk passive air samplers for investigating organochlorine pesticides and polybrominated diphenyl ethers at the global scale. Environ Sci Technol 46(1):391–396.22103600
Koizumi A. 1991. Experimental evidence for the possible exposure of workers to hexachlorobenzene by skin contamination. Br J Ind Med 48:622–628.1911405
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Kosatsky T, Przybysz R, Shatenstein B, . 1999. Fish consumption and contaminant exposure among Montreal-area sportfishers: Pilot study. Environ Res A80:S150–S158.
Koss G, Koransky W. 1975. Studies on the toxicology of hexachlorobenzene: I. Pharmacokinetics. Arch Toxicol 34:203–212.1243620
Koss G, Koransky W, Steinbach K. 1976. Studies on the toxicology of hexachlorobenzene: II. Identification and determination of metabolites. Arch Toxicol 35:107–114.947309
Koss G, Koransky W, Steinbach K. 1979. Studies of the toxicology of hexachlorobenzene: IV. Sulfur-containing metabolites. Arch Toxicol 42:19–31.454182
Koss G, Reuter A, Koransky W. 1986. Excretion of metabolites of hexachlorobenzene in the rat and in man. IARC Sci Publ 77:261–266.
Koss G, Seubert S, Seubert A, . 1978. Studies on the toxicology of hexachlorobenzene: III. Observations in a long-term experiment. Arch Toxicol 40:285–294.581261
Koss G, Seubert S, Seubert A, . 1983. Studies on the toxicology of hexachlorobenzene: V. Different phases of porphyria during and after treatment. Arch Toxicol 52:13–22.6838374
Kozani RR, Assadi Y, Shemirani F, . 2007. Part-per-trillion determination of chlorobenzenes in water using dispersive liquid-liquid microextraction combined gas chromatography-electron capture detection. Talanta 72(2):387–393.19071629
Kraaij H, Connell DW. 1997. Bioconcentration and uptake kinetics of chlorobenzenes in soy-bean roots. Chemosphere 34(12):2607–2620.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krishnan K, Brodeur J, Charbonneau M. 1991. Development of an experimental model for the study of hexachlorobenzene-induced hepatic porphyria in the rat. Fundam Appl Toxicol 17:433–441.1794647
Krishnan K, Brodeur J, Plaa GL, . 1992. Modulation of hexachlorobenzene-induced hepatic porphyria by methyl isobutyl ketone in the rat. Toxicol Lett 61:167–174.1641864
Kucklick JR, Baker JE. 1998. Organochlorines in Lake Superior’s food web. Environ Sci Technol 32:1192–1198.
Kuiper-Goodman T, Grant DL, Moodie CA, . 1977. Subacute toxicity of hexachlorobenzene in the rat. Toxicol Appl Pharmacol 40:529–549.882985
Kutz FW, Wood PH, Bottimore DP. 1991. Organochlorine pesticides and polychlorinated biphenyls in human adipose tissue. Rev Environ Contam Toxicol 120:1–82.1899728
Kwok ESC, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29:1685–1695.
Lackmann GM. 2002. Polychlorinated biphenyls and hexachlorobenzene in full-term neonates. Reference values updated. Biol Neonate 81(2):82–85.11844874
Lackmann GM. 2004. Organochlorine compounds in breast-fed vs. bottle-fed I\infants: Preliminary results at six weeks of age. Pediatr Res 56(3):488.
Lackmann GM, Angerer J, Salzberger U, . 1999. Influence of maternal age and duration of pregnancy on serum concentrations of polychlorinated biphenyls and hexachlorobenzene in full-term neonates. Biol Neonate 76:214–219.10473895
Lackmann GM, Angerer J, Tollner U. 2000. Parental smoking and neonatal serum levels of polychlorinated biphenyls and hexachlorobenzene. Pediatr Res 47(5):598–601.10813583
Lackmann GM, Goen T, Tollner U, . 1996. PCBs and HCB in serum full-term German neonates. Lancet 348:1035.
Lahaniatis ES, Bergheim W, Kettrup A. 1992. Thermal degradation of polychlorinated bornanes. In: Proceeding International Symposium on Ecological Approaches of Environmental Chemicals. Institut fur Okologische Chemie. Debrecen, Hungary, 262–267.
Lam T, Williams PL, Lee MM, . 2014. Prepubertal organochlorine pesticide concentrations and age of pubertal onset among Russian boys. Environ Int 73:135–142 25118086
Lamb CW, Miller FM, Dellinger RA, . 1994. Detailed determination of organic emissions from a preheater cement kiln co-fired with liquid hazardous wastes. Hazard Waste Hazard Mater 11(1):201–216.
*Lambrecht RW, Erturk E, Grunden EE, . 1982a. Hepatotoxicity and tumorigenicity of hexachlorobenzene (HCB) in Syrian golden hamsters (H) after subchronic administration. Fed Proc 41:329. (Abstract)
*Lambrecht RW, Erturk E, Grunden EE, . 1982b. Renal toxicity and tumorigenicity of hexachlorobenzene (HCB) in rats (R). AACR Abstracts 23:54. (Abstract)
Lambrecht RW, Erturk E, Grunden EE, . 1983. Hepatocarcinogenicity of chronically administered hexachlorobenzene in rats. Fed Proc 42:786. (Abstract)
*Lambrecht RW, Erturk E, Peters HA, . 1986. Effects of ethylenediaminetetraacetic acid on hexachlorobenzene-induced changes in rats. IARC Sci Publ 77:505–506.
Lane DA, Johnson ND, Hanely MJ, . 1992. Gas-and particle-phase concentrations of alpha-hexachlorocyclohexane, gamma-hexachlorocyclohexane, and hexachlorobenzene in Ontario air. Environ Sci Technol 26(1):126–133.
Langer P, Kocan A, Tajtakova M, . 2003. Possible effects of polychlorinated biphenyls and organochlorinated pesticides on the thyroid after long-term exposure to heavy environmental pollution. J Occup Environ Med 45(5):526–532.12762077
Langer P, Tajtakova M, Kocan A, . 2007. Thyroid ultrasound volume, structure and function after long-term high exposure of large population to polychlorinated biphenyls, pesticides and dioxin. Chemosphere 69(1):118–127.17537484
Langhorst ML, Nestrick TJ. 1979. Determination of chlorobenzenes in air and biological samples by gas chromatography with photoionization detection. Anal Chem 51:2018–2025.539657
Langlois C, Langis R. 1995. Presence of airborne contaminants in the wildlife of northern Quebec. Sci Total Environ (160–161), 391–402.7892577
Larsen BR, Turrio-Baldassarri L, Nilsson T, . 1994. Toxic PCB congeners and organochlorine pesticides in Italian human milk. Ecotoxicol Environ Saf 28:1–13.7523063
Laska AL, Baretell CK, Laseter JL. 1976. Distribution of hexachlorobenzene and hexachlorobutadiene in water, soil, and selected aquatic organisms along the lower Mississippi River, Louisiana. Bull Environ Contam Toxicol 15:535–542.1268359
Lecavalier PR, Chu I, Villeneuve D, . 1994. Combined effects of mercury and hexachlorobenzene in the rat. J Environ Sci Health B29(5):951–961.
Lee CL, Song HJ, Fang MD. 2000a. Concentrations of chlorobenzenes, hexachlorobutadiene and heavy metals in surficial sediments of Kaohsiung coast, Taiwan. Chemosphere 41:889–899.10864162
Lee DH, Steffes MW, Sjodin A, . 2010. Low dose of some persistent organic pollutants predicts type 2 diabetes: A nested case-control study. Environ Health Perspect 118(9):1235–1242.20444671
Lee DH, Steffes MW, Sjodin A, . 2010. Low dose of some persistent organic pollutants predicts type 2 diabetes: A nested case-control study. Environ Health Perspect 118(9):1235–1242.20444671
Lee DH, Steffes MW, Sjodin A, . 2011. Low dose organochlorine pesticides and polychlorinated biphenyls predict obesity, dyslipidemia, and insulin resistance among people free of diabetes. PLoS ONE 6(1):e15977.21298090
Lee RGM, Burnett V, Harner T, . 2000b. Short-term temperature-dependent air-surface exchange and atmospheric concentrations of polychlorinated naphthalenes and organochlorine pesticides. Environ Sci Technol 34:393–398.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Legault N, Sabik H, Cooper SF, . 1997. Effect of estradiol on the induction of porphyria by hexachlorobenzene in the rat. Biochem Pharmacol 54:19–25.9296347
Leger DA. 1992. Environmental concentrations of hexachlorobenzene in Atlantic Canada. Moncton, New Brunswick: Environment Canada, Conservation and Protection, Inland Waters Directorate, Water Quality Branch. IWD-AR-WQB-91-170.
Leikin JB, Paloucek FP. 2002. Hexachlorobenzene. In: Leikin JB, Paloucek FP, eds. Poisoning and toxicology handbook. 3^rd^ ed. Hudson, OH: Lexi-Comp, Inc., 647–648.
Lelli SM, Ceballos NR, Mazzetti MB, . 2007. Hexachlorobenzene as hormonal disruptor-studies about glucocorticoids: Their hepatic receptors, adrenal synthesis and plasma levels in relation to impaired gluconeogenesis. Biochem Pharmacol 73(6):873–879.17182006
Leoni V, Fabiani L, Marinelli G, . 1986. Spontaneous abortion in relation to the presence of hexachlorobenzene in the Italian environment. IARC Sci Publ 77:143–146.
Leoni V, Fabiani L, Marinelli G, . 1989. PCB and other organochlorine compounds in blood of women with or without miscarriage: A hypothesis of correlation. Ecotoxicol Environ Saf 17(1):1–11.2496968
Leung HW. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Li J, Li N, Ma M, . 2008. In vitro profiling of the endocrine disrupting potency of organochlorine pesticides. Toxicol Lett 183(1–3):65–71.18992306
Li SM, Deuomme MA, Leece B, . 1989. Hexachlorobenzene: Biochemical effects and synergistic toxic interactions with 2,3,7,8-tetrachlorodibenzo-p-dioxin. Toxicol Environ Chem 22:215–227.
Li Y, Lin T, Qin Y, . 2013. Distribution and sources of organochlorine pesticides in sediments of the Xiangjiang River, south-central China. Environ Monit Assess 185(11):8861–8871.23636501
Lilienthal H, Benthe C, Heinzow B, . 1996. Impairment of schedule-controlled behavior by pre- and postnatal exposure to hexachlorobenzene in rats. Arch Toxicol 70:174–181.8825674
Liljegren G, Hardell L, Lindstrom G, . 1998. Case-control study on breast cancer and adipose tissue concentrations of congener specific polychlorinated biphenyls, DDE and hexachlorobenzene. Eur J Cancer Prev 7:135–140.9818775
Lim HW. 1989. Mechanisms of phototoxicity in porphyria cutanea tarda and erythropoietic protoporphyria. Immunol Ser 46:671–685.2488874
Lim HW, Cohen JL. 1999. The cutaneous porphyrias. Semin Cutan Med Surg 18 (4):285–292.10604794
Linder RE, Edgerton TR, Svendsgaard DJ, . 1983. Long-term accumulation of hexachlorobenzene in adipose tissue of parent and filial rats. Toxicol Lett 15:237–243.6829047
Lindqvist R, Enfield CG. 1992. Biosorption of dichloro-diphenyltrichlorethane and hexachlorobenzene in groundwater and its implications for facilitated transport. Appl Environ Microbiol 58(7):2211–2218.1637158
Linet MS, Gridley G, Nyren O, . 1999. Primary liver cancer, other malignancies, and mortality risks following porphyria: A cohort study in Denmark and Sweden. Am J Epidemiol 149 (11):1010–1015.10355376
Link B, Gabrio T, Zoellner I, . 2005. Biomonitoring of persistent organochlorine pesticides, PCDD/PCDFs and dioxin-like PCBs in blood of children from southwest Germany (Baden-Wuerttemberg) from 1993 to 2003. Chemosphere 58(9):1185–1201.15667840
Linko P, Yeowell HN, Gasiewicz TA, . 1986. Induction of cytochrome P-450 isozymes by hexachlorobenzene in rats and aromatic hydrocarbon (Ah)-responsive mice. J Biochem Toxicol 1:95–107.2856071
Lissner R, Goerz G, Eichenauer MG, . 1975. Hexachlorobenzene-induced porphyria in rats--relationship between porphyrin excretion and induction of drug metabolizing liver enzymes. Biochem Pharmacol 24:1729–1731.
Liu W, Tao F, Zhang W, . 2012. Contamination and emission factors of PCDD/Fs, unintentional PCBs, HxCBz, PeCBz and polychlorophenols in chloranil in China. Chemosphere 86(3):248–251.22018590
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Long PH, Herbert RA, Nyska A. 2004. Hexachlorobenzene-induced incisor degeneration in Sprague-Dawley rats. Toxicol Pathol 32(1):35–40.14713546
Loose LD, Pittman KA, Benitz KF, . 1977. Polychlorinated biphenyl and hexachlorobenzene induced humoral immunosuppression. J Reticuloendothel Soc 22(3):253–267.411925
Loose LD, Silkworth JB, Charbonneau T, . 1981. Environmental chemical-induced macrophage dysfunction. Environ Health Perspect 39:79–91.7238456
Loose LD, Silkworth JB, Pittman KA, . 1978. Impaired host resistance to endotoxin and malaria in polychlorinated biphenyl- and hexachlorobenzene-treated mice. Infect Immun 20:30–35.97225
López-Carrillo L, Lopez-Cervantes M, Torres-Sanchez L, . 2002. Serum levels of β-hexachlorocyclohexane, hexachlorobenzene and polychlorinated biphenyls and breast cancer in Mexican women. Eur J Cancer Prev 11(2):129–135.11984130
Lopez-Espinosa MJ, Murcia M, Iniguez C, . 2011. Prenatal exposure to organochlorine compounds and birth size. Pediatrics 128(1):E127–E134.21669889
Lordo RA, Dinh KT, Schwemberger JG. 1996. Semivolatile organic compounds in adipose tissue: Estimated averages for the US population and selected subpopulations. Am J Public Health 86:1253–1259.8806377
Lovecka P, Pacovska I, Stursa P, . 2014. Organochlorinated pesticide degrading microorganisms isolated from contaminated soil. New Biotechnol 32(1):26–31.
Lovell RA, McChesney DG, Price WD. 1996. Organohalogen and organophosphorous pesticides in mixed feed rations: Findings from FDA’s domestic surveillance during fiscal years 1989-1994. J AOAC Int 79(2):544–548.8920144
Lu Y, Lohitnavy M, Reddy MB, . 2006. An updated physiologically based pharmacokinetic model for hexachlorobenzene: Incorporation of pathophysiological states following partial hepatectomy and hexachlorobenzene treatment. Toxicol Sci 91(1):29–41.16481338
Lui H, Sweeney GD. 1975. Hepatic metabolism of hexachlorobenzene in rats. FEBS Lett 51(1):137–138.1123043
Lui H, Sampson R, Sweeney GD. 1976. Session X. Experimental chronic hepatic porphyria. Hexachlorobenzene porphyria: Purity and metabolic fate of hexachlorobenzene. In: Doss M, Ed. Porphyrins in human diseases, 1st International Porphyrin Meeting Freiburg/Br 1975. Basel: S. Karger.
Lunden A, Noren K. 1998. Polychlorinated naphthalenes and other organochlorine contaminants in Swedish human milk, 1972-1992. Arch Environ Contam Toxicol 34(4):414–423.9543513
MacBean C. 2010. Hexachlorobenzene. The e-pesticide manual. British Crop Protection Council. 15^th^ ed. Version 5.1.
MacPhee IJ, Singh A, Wright GM, . 1993. Ultrastructure of granulosa lutein cells from rats fed hexachlorobenzene. Histol Histopathol 8:35–40.8443433
Maervoet J, Vermeir G, Covaci A, . 2007. Association of thyroid hormone concentrations with levels of organochlorine compounds in cord blood of neonates. Environ Health Perspect 115(12):1780–1786.18087600
Mahalingaiah S, Missmer SA, Maity A, . 2012. Association of hexachlorobenzene (HCB), dichlorodiphenyltrichloroethane (DDT), and dichlorodiphenyldichloroethylene (DDE) with in vitro fertilization (IVF) outcomes. Environ Health Perspect 120(2):316–320.22204795
Majoros LI, Lava R, Ricci M, . 2013. Full method validation for the determination of hexachlorobenzene and hexachlorobutadiene in fish tissue by GC-IDMS. Talanta 116:251–258.24148401
Malarvannan G, Dirinck E, Dirtu AC, . 2013. Distribution of persistent organic pollutants in two different fat compartments from obese individuals. Environ Int 55:33–42.23518385
Malarvannan G, Kunisue T, Isobe T, . 2009. Organohalogen compounds in human breast milk from mothers living in Payatas and Malate, the Philippines: Levels, accumulation kinetics and infant health risk. Environ Pollut 157(6):1924–1932.19232797
Manes J, Font G, Pico Y. 1993. Evaluation of a solid-phase extraction system for determining pesticide residues in milk. J Chromatogr 642:195–204.8366165
Mann JB, Enos HF, Gonzalez J, . 1974. Development of sampling and analytical procedure for determining hexachlorobenzene and hexochloro-1,3-butadiene in air. Environ Sci Technol 8(6):584–585.
Mannetje A, Coakley J, Bridgen P, . 2013. Current concentrations, temporal trends and determinants of persistent organic pollutants in breast milk of New Zealand women. Sci Total Environ 458–460:399–407.
Mannetje A, Coakley J, Bridgen P, . 2014. Estimated infant intake of persistent organic pollutants through breast milk in New Zealand. N Z Med J 127(1401):56–68.
Martens D, Balta-Brouma K, Brotsack R, . 1998. Chemical impact of uncontrolled solid waste combustion to the vicinity of the Kouroupitos Ravine, Crete, Greece. Chemosphere 36(14):2855–2866.
Marvin CH, Painter S, Charlton MN, . 2004. Trends in spatial and temporal levels of persistent organic pollutants in Lake Erie sediments. Chemosphere 54(1):33–40.14559255
Masini A, Trenti T, Ceccarelli, D, . 1988. The effect of iron overload on the mitochondrial porphyrin level in the hexachlorobenzene induced experimental porphyria. Biochem Biophys Res Comm 151:320–326.3348779
Masunaga S, Susarla S, Yonezawa Y. 1996. Dechlorination of chlorobenzenes in anaerobic estuarine sediment. Water Sci Technol 33(6):173–180.
Mattison DR, Wohlleb J, To T, . 1992. Pesticide concentrations in Arkansas breast milk. Med Soc 88(11):553–557.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCready D, Aronson Kristan J, Chu W, . 2004. Breast tissue organochlorine levels and metabolic genotypes in relation to breast cancer risk Canada. Cancer Causes Control 15(4):399–418.15141140
Meeker JD, Altshul L, Hauser R. 2007. Serum PCBs, p,p’-DDE and HCB predict thyroid hormone levels in men. Environ Res 104(2):296–304.17189629
Mehendale HM, Fields M, Matthews HB. 1975. Metabolism and effects of hexachlorobenzene on hepatic microsomal enzymes in the rat. J Agric Food Chem 23:261–265.1133299
Mehmood Z, Williamson MP, Kelly DE, . 1996. Metabolism of organochlorine pesticides: The role of human cytochrome P450 3A4. Chemosphere 33(4):759–769.8759309
Meijer SN, Ockenden WA, Steinnes E, . 2003a. Spatial and temporal trends of POPs in Norwegian and UK background air: Implications for global cycling. Environ Sci Technol 37(3):454–461.12630458
Meijer SN, Ockenden WA, Sweetman A, . 2003b. Global distribution and budget of PCBs and HCB in background surface soils: Implications for sources and environmental processes. Environ Sci Technol 37(4):667–672.12636263
Mendez MA, Garcia-Esteban R, Guxens M, . 2011. Prenatal organochlorine compound exposure, rapid weight gain, and overweight in infancy. Environ Health Perspect 119(2):272–278.20923745
Mendonca GAS, Eluf-Neto J, Andrada-Serpa MJ, . 1999. Organochlorines and breast cancer: A case-control study in Brazil. Int J Cancer 83:596–600.10521792
Mendoza CE, Shields JB. 1976. Effects of hexachlorobenzene on malathion LD50 and on cholinesterase and carboxylesterase activities in organs of the suckling albino rat. Toxicol Appl Pharmacol 35:447–453.1265759
Meola T, Lim HW. 1993. The porphyrias. Dermatol Clin 3(11):583–596.
Mes J. 1992. Organochlorine residues in human blood and biopsy fat and their relationship. Bull Environ Contam Toxicol 48:815–820.1568057
Mes J, Davies DJ, Doucet J, . 1993. Levels of chlorinated hydrocarbon residues in Canadian human breast milk and their relationship to some characteristics of the donors. Food Addit Contam 10(4):429–441.8405582
Mes J, Davies DJ, Turton D. 1982. Polychlorinated biphenyl and other chlorinated hydrocarbon residues in adipose tissue of Canadians. Bull Environ Contam Toxicol 28:97–104.6802207
Michalowicz J, Mokra K, Rosiak K, . 2013. Chlorobenzenes, lindane and dieldrin induce apoptotic alterations in human peripheral blood lymphocytes (in vitro study). Environ Toxicol Pharmacol 36(3):979–988.24077485
Michielsen C, Boeren S, Rietjens I, . 2000. The mercapturic acid biotransformation pathway of hexachlorobenzene is not involved in the induction of splenomegaly, of skin and lung lesions in the Brown Norway rat. Arch Toxicol 74:609–617.11201668
Michielsen C, van Loveren H, Vos JG. 1999. The role of the immune system in hexachlorobenzene-induced toxicity. Environ Health Perspect Suppl 107(5):783–792.
Michielsen C, Zeamari S, Leusink-Muis A, . 2002. The environmental pollutant hexachlorobenzene causes eosinophilic and granulomatous inflammation and in vitro airways hyperreactivity in the Brown Norway rat. Arch Toxicol 76(4):236–247.12029387
Michielsen CPPC, Bloksma N, Ultee A, . 1997. Hexachlorobenzene-induced immunomodulation and skin and lung lesions: A comparison between Brown Norway, Lewis, and Wistar rats. Toxicol Appl Pharmacol 144:12–26.9169065
Michielsen CPPC, Leusink-Muis A, Vos JG, . 2001. Hexachlorobenzene-induced eosinophilic and granulomatous lung inflammation is associated with in vivo airways hyperresponsiveness in the brown Norway rat. Toxicol Appl Pharmacol 172:11–20.11264018
Mikeš O, Čupr P, Kohút L, . 2012. Fifteen years of monitoring of POPs in the breast milk, Czech Republic, 1994-2009: Trends and factors. Environ Sci Pollut Res Int 19(6):1936–1943.22767291
Mill T, Haag W. 1986. The environmental fate of hexachlorobenzene. IARC Sci Pub 77:61–66
Miskiewicz AG, Gibbs PJ. 1994. Organochlorine pesticides and hexachlorobenzene in tissues of fish and invertebrates caught near a sewage outfall. Environ Pollut 84:269–277.15091698
Miura T, Torinuki W. 1977. Thin layer chromatography and fluorescent scanning analysis of porphyrins. Tohoku J Exp Med 121:37–61.
Miyagawa M, Takasawa H, Sugiyama A, . 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) mouse hepatocarcinogens. Mutat Res 343(2–3):157–183.7791810
Mollenhauer HH, Johnson JH, Younger RL, . 1975. Ultrastructural changes in liver of the rat fed hexachlorobenzene. Am J Vet Res 36:1777–1781.1200447
Monheit BM, Luke BG. 1990. Pesticides in breast milk- A public health perspective. Community Health Stud 14(3):269–273.2253462
Morley A, Geary D, Harben F. 1973. Hexachlorobenzene pesticides and porphyria. Med J Aust 1:565.4699734
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Moysich KB, Ambrosone CB, Vena JE. 1998. Environmental organochlorine exposure and postmenopausal breast cancer risk. Cancer Epidemiol Biomark Prev 7:181–188.
Muir DCG, Segstro MD, Welbourn PM, . 1993. Patterns of accumulation of airborne organochlorine contaminants in lichens from the upper Great Lakes region of Ontario. Environ Sci Technol 27(6):1201–1210.
Muller WF, Hobson W, Fuller GB, . 1978. Endocrine effects of chlorinated hydrocarbons in Rhesus monkeys. Ecotoxicol Environ Saf 2:161–172.103705
Munch DJ, Maxey RA, Engel TM. 1990. Methods development and implementation for the National Pesticide Survey. Environ Sci Technol 24(10):1446–1451.
Mundy LJ, Jones SP, Crump D, . 2010. Highly purified hexachlorobenzene induces cytochrome P4501A in primary cultures of chicken embryo hepatocytes. Toxicol Appl Pharmacol 248:185–193.20682327
Murphy R, Harvey C. 1985. Residues and metabolites of selected persistent halogenated hydrocarbons in blood specimens from a general population survey. Environ Health Perspect 60:115–120.2411534
Murray HE, Neff GS, Hrung Y, . 1980. Determination of benzo(a)pyrene, hexachlorobenzene and pentachlorophenol in oysters from Galveston Bay, Texas. Bull Environ Contam Toxicol 25:663–667.7437572
Murray HE, Ray LE, Giam CS. 1981. Analysis of marine sediment, water and biota for selected organic pollutants. Chemosphere 10:1327–1334.
Mussalo-Rauhamaa H, Hasanen E, Pyysalo H, . 1990. Occurrence of beta-hexachlorocyclohexane in breast cancer patients. Cancer 66(10):2124–2128.1699651
*Mylchreest E, Charbonneau M. 1994. Ultrasound-induced epileptiform activity in rats treated with hexachlorobenzene. Neurotoxicology 15(2):149–155.8090354
Mylchreest E, Charbonneau M. 1997. Studies on the mechanism of uroporphyrinogen decarboxylase inhibition in hexachlorobenzene-induced porphyria in the female rat. Toxicol Appl Pharmacol 145:23–33.9221820
Nakashima Y, Ikegami S. 2000. Hexachlorobenzene and Pentachlorobenzene accumulated during pregnancy is transferred to pups at the accumulation ratio in dams. J Health Sci 46(2):89–97.
Nakashima Y, Ohsawa S, Ikegami S. 1999. High-fat diet enhances accumulation of hexachlorobenzene in rat dams and delays its transfer from rat dams to suckling pups through milk. J Agric Food Chem 47:1587–1592.10564021
Nakashima Y, Ohsawa S, Umegaki K, . 1997. Hexachlorobenzene accumulated by dams during pregnancy is transferred to suckling rats during early lactation. J Nutr 127:648–654.9109618
Nakata H, Kannan K, Jing L, . 1998. Accumulation pattern of organochlorine pesticides and polychlorinated biphenyls in southern sea otters (Enhydra lutris nereis) found stranded along coastal California, USA. Environ Pollut 103:45–53.
Nam KS, King JW. 1994. Coupled SFE/SFC/GC for the trace analysis of pesticide residues in fatty food samples. J High Resolut Chromatogr 17:577–582.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nash RG, Gish TJ. 1989. Halogenated pesticide volatilization and dissipation from soil under controlled conditions. Chemosphere 18(11/12):2353–2362.
Nasir K, Bilto YY, Al-Shuraiki Y. 1998. Residues of chlorinated hydrocarbon insecticides in human milk of Jordanian women. Environ Pollut 99:141–148.15093308
Newsome WH, Andrews P. 1993. Organochlorine pesticides and polychlorinated biphenyl congener in commercial fish from the Great Lakes. J AOAC Int 76(4):707–710.8374320
Newsome WH, Ryan JJ. 1999. Toxaphene and other chlorinated compounds in human milk from northern and southern Canada: A comparison. Chemosphere 39(3):519–526.10399849
Newsome WH, Davies D, Doucet J. 1995. PCB and organochlorine pesticides in Canadian human milk-1992. Chemosphere 30(11):2143–2153.7620848
Newsome WH, Doucet J, Davies D, . 2000. Pesticide residues in the Canadian market basket survey-1992 to 1996. Food Addit Contam 17(10):847–854.11103268
Nikolaev V, Naydenova E, Kerimova M, . 1986. Rat liver plasma membrane damage in hexachlorobenzene intoxication and its potential by ethanol. Toxicol Lett 32:269–273.3022430
NIOSH. 2005. NIOSH Health Hazard Evaluation Report: HETA No. 2004-0169-2982, U.S. Magnesium, Rowley, Utah, October 2005. National Institute of Occupational Safety and Health, 70.
NIOSH. 2015. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdcas.html. April 10, 2015.
NITE. 2010. Hexachlorobenzene. National Institute of Technology and Evaluation. http://www.safe.nite.go.jp/english/kizon/KIZON_start_hazkizon.html. June 26, 2012.
NOES. 1990. National Occupational Exposure Survey 1981-1983. Cincinnati OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/noes1/a1753sic.html. June 19, 2012
Norén K, Meironyté D. 2000. Certain organochlorine and organobromine contaminants in Swedish human milk in perspective of past 20-30 years. Chemosphere 40:1111–1123.10739053
Noren K, Weistrand C, Karpe F. 1999. Distribution of PCB congeners, DDE, hexachlorobenzene, and methylsulfonyl metabolites of PCB and DDE among various fractions of human blood plasma. Arch Environ Contam Toxicol 37:408–414.10473799
NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
Ntow WJ. 2001. Organochlorine pesticides in water, sediment, crops, and human fluids in a farming community in Ghana. Bull Environ Contam Toxicol 40:557–563.
Ntow WJ, Tagoe LM, Drechsel P, . 2008. Accumulation of persistent organochlorine contaminants in milk and serum of farmers from Ghana. Environ Res 106(1):17–26.17931619
NTP. 2002. Tox-77. Toxicity report tables and curves. Pathology tables, survival and growth curves from NTP toxicity studies. TDMS study 98004-01 pathology tables. Pathology tables for peer review. National Toxicology Program. http://ntp.niehs.nih.gov/results/path/tablelistings/shortterm/tox099/tox077/index.html. February 2, 2015.
NTP. 2014. Hexachlorobenzene. Report on Carcinogens, Thirteenth Edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/content/profiles/hexachlorobenzene.pdf. April 10, 2015.
Nuhu AA, Basheer C, Abu-Thabit NY, . 2011. Analytical method development using functionalized polysulfone membranes for the determination of chlorinated hydrocarbons in water. Talanta 87:284–289.22099680
Oberg T, Bergstrom JGT. 1985. Hexachlorobenzene as an indicator of dioxin production from combustion. Chemosphere 14:1081–1086.
Ockner RK, Schmid R. 1961. Acquired porphyria in man and rat due to hexachlorobenzene intoxication. Nature 4763:499.
Oehme M, Mano S, Mikalsen A. 1987. Formation and presence of polyhalogenated and polycyclic compounds in the emissions of small and large scale municipal waste incinerators. Chemosphere 16:143–153.
Offenberg JH, Eisenreich SJ, Gigliotti CL, . 2004. Persistent organic pollutants in dusts that settled indoors in lower Manhattan after September 11, 2001. J Expo Anal Environ Epidemiol 14(2):164–172.15014547
Ojala M. 1993. Simultaneous separation and determination of chlorobenzenes, PCBs, and chlorophenols using silica gel fractionation and GC-ECD analysis. J High Resolut Chromatogr 16:679–682.
Oliver BG, Nicol KD. 1982a. Chlorobenzenes in sediments, water, and selected fish from Lakes Superior, Huron, Erie, and Ontario. Environ Sci Technol 16:532–536.
Oliver BG, Nicol KD. 1982b. Gas chromatographic determination of chlorobenzenes and other chlorinated hydrocarbons in environmental samples using fused silica capillary columns. Chromatographia 16:336–340.
Oliver BG, Niimi AJ. 1983. Bioconcentration of chlorobenzenes from water by rainbow trout: Correlations with partition coefficients and environmental residues. Environ Sci Technol 17:287–291.
O’Neil MJ, Heckelman PE, Koch CB, . 2006. Hexachlorobenzene. In: The Merck Index. Whitehouse Station, NJ: Merck & Co., Inc., 808–809.
Onuska FI, Terry KA. 1993. Extraction of pesticides from sediments using a microwave technique. Chromatographia 36:101–104.
OSHA. 2013. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910-1000.pdf. March 4, 2015.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Ozalla D, Herrero C, Ribas-Fito N, . 2002. Evaluation of urinary porphyrin excretion in neonates born to mothers exposed to airborne hexachlorobenzene. Environ Health Perspect 110(2):205–209.11836151
Park J, Wade TL, Sweet S. 2001. Atmospheric deposition of organochlorine contaminants to Galveston Bay, Texas. Atmos Environ 35:3315–3324.
Parlar H. 1978. Organochlorine compounds and their reactions in the atmosphere. Ecotoxicol Environ Saf 2:219–232.729519
Pavuk M, Cerhan JR, Lynch CF, . 2003. Case-control study of PCBs, other organochlorines and breast cancer in eastern Slovakia. J Expo Anal Environ Epidemiol 13(4):267–275.12923553
Peña D, Pontillo C, García MA, . 2012. Alterations in cSrc/HER1 and estrogen receptor α signaling pathways in mammary gland and tumors of hexachlorobenzene-treated rats. Toxicology 293:68–77.22245120
Pereira MA, Herren SL, Britt AL, . 1982. Sex difference in enhancement of GGTase- positive foci by hexachlorobenzene and lindane in rat liver. Cancer Lett 15:95–101.6174209
Pereria WE, Rostad CE, Chiou CT, . 1988. Contamination of estuarine water, biota and sediment by halogenated organic compounds: A field study. Environ Sci Technol 22:772–778.22195660
Peters HA. 1956. Therapy of acute porphyria with BAL and other agents (a report of 19 additional cases). Dis Nerv Syst 17(6):351–357.
Peters HA. 1993. Acute hepatic porphyria. In: RT Johnson, JW Griffin, eds. Current therapy in neurologic disease, 4th ed. Mosby-Year Book, Inc., 317–322.
Peters H, Cripps DJ. 1985. Chelation therapy of acute, chronic, and mixed porphyria. Plzen Lek Sborn, suppl 49:261–264.
Peters H, Cripps D, Gocmen A, . 1987. Turkish epidemic hexachlorobenzene porphyria: A 30-year study. Ann NY Acad Sci 514:183–190.3442383
Peters HA, Gocmen A, Cripps DJ, . 1982. Epidemiology of hexachlorobenzene-induced porphyria in Turkey: Clinical and laboratory follow-up after 25 years. Arch Neurol 39:744–749.7138315
Peters HA, Gocmen A, Cripps DJ, . 1986. Porphyria turcica: Hexachlorobenzene-induced porphyria. Neurological manifestations and therapeutic trials of ethylenediaminetetraacetic acid in the acute syndrome. IARC Scientific Publ 77:581–583.
Peters HA, Johnson SA, Cam S, . 1966. Hexachlorobenzene induced porphyria: Effect of chelation on the disease, porphyrin and metal metabolism. Am J Med Sci 251:314–322.4159563
Peters HA, Woods S, Eichman PL, . 1957. The treatment of acute porphyria with chelating agents: A report of 21 cases. Ann Intern Med 47(5):889–899.13470715
Petreas M, She J, Visita P, . 1998. Levels of PCDD/PCDFs, PCBs and OC pesticides in breast adipose of women enrolled in a California breast cancer study. Organohalogen Compounds 38:37–40.
Petzold G, Schafer M, Benthe C, . 1999. Dietary exposure and human body burden to organochlorine pesticides and PCBs in children and women in northern Germany. Organohalogen Compounds 44:119–122.
Pierik FH, Klebanoff MA, Brock JW, . 2007. Maternal pregnancy serum level of heptachlor epoxide, hexachlorobenzene, and β-hexachlorocyclohexane and risk of cryptorchidism in offspring. Environ Res 105(3):364–369.17532317
Pimstone NR. 1982. Porphyria cutanea tarda. Semin Liver Dis 2(2):132–142.6753163
Poissant L, Koprivnjak JF, Mattieu R. 1997. Some persistent organic pollutants and heavy metals in the atmosphere over a St. Lawrence River Valley site (Villeroy) in 1992. Chemosphere 34(3):567–585.
Polder A, Thomsen C, Lindstrom G, . 2008. Levels and temporal trends of chlorinated pesticides, polychlorinated biphenyls and brominated flame retardants in individual human breast milk samples from northern and southern Norway. Chemosphere 73(1):14–23.18653208
Poli A, Biasi D, Diani F, . 1999. Presence of organic chlorine pesticides in the adipose tissue of the pregnant woman, in the placenta, and in the maternal milk. Ig Mod 112:861–871.
Pontillo CA, García MA, Peña D, . 2011. Activation of c-Src/HER/STAT5b and HER1/ERK1/2 signaling pathways and cell migration by hexachlorobenzene in MDA-MB-231 human breast cancer cell line. Toxicol Sci 120(2):284–296.21205633
Pontillo CA, Rojas P, Chiappini F, . 2013. Action of hexachlorobenzene on tumor growth and metastasis in different experimental models. Toxicol Appl Pharmacol 268(3):331–342.23462309
Poole KG, Elkin BT, Bethke RW. 1998. Organochlorine and heavy metal contaminants in wild mink in western Northwest Territories, Canada. Arch Environ Contam Toxicol 34:406–413.9543512
Porpora MG, Medda E, Abballe A, . 2009. Endometriosis and organochlorinated environmental pollutants: A case-control study on Italian women of reproductive age. Environ Health Perspect 117(7):1070–1075.19654915
Porta M, Lopez T, Gasull M, . 2012. Distribution of blood concentrations of persistent organic pollutants in a representative sample of the population of Barcelona in 2006, and comparison with levels in 2002. Sci Total Environ 423:151–161.22397902
Pozo K, Urrutia R, Mariottini M, . 2014. Levels of persistent organic pollutants (POPs) in sediments from Lenga Estuary, central Chile. Mar Pollut Bull 79(1–2):338–341.24373669
Prachar V, Veningerova M, Uhnak J, . 1993. Levels of polychlorinated biphenyls and some other organochlorine compounds in breast milk samples in Bratislava. Sci Total Environ (Suppl Pt 1):237–242.
Purdue MP, Engel LS, Langseth H, . 2009. Prediagnostic serum concentrations of organochlorine compounds and risk of testicular germ cell tumors. Environ Health Perspect 117(10):1514–1519.20019899
Pylypiw HM Jr., 1993. Rapid gas chromatographic method for the multiresidue screening of fruits and vegetables for organochlorine and organophosphate pesticides. J AOAC Int 76(6):1369–1373.8286976
Queiroz MLS, Bincoletto C, Perlingeiro RCR, . 1997. Defective neutrophil function in workers occupationally exposed to hexachlorobenzene. Human Exp Toxicol 16(6):322–326.
Queiroz MLS, Bincoletto C, Perlingeiro RCR, . 1998a. Immunoglobulin levels in workers exposed to hexachlorobenzene. Human Exp Toxicol 17:172–175.
Queiroz MLS, Quadros MR, Valadares MC, . 1998b. Polymorphonuclear phagocytosis and killing in workers occupationally exposed to hexachlorobenzene. Immunopharmacol Immunotoxicol 20(3):447–454.9736448
Quemerais B, Lemieux C, Lum KR. 1994. Concentrations and sources of PCBs and organochlorine pesticides in the St. Lawrence River (Canada) and its tributaries. Chemosphere 29(3):591–610.
Quinsey PM, Donohue DC, Ahokas JT. 1995. Persistence of organochlorines in breast milk of women in Victoria, Australia. Food Chem Toxicol 33(1):49–56.7821877
Quintana PJE, Delfino RJ, Korrick S, . 2004. Adipose tissue levels of organochlorine pesticides and polychlorinated biphenyls and risk of non-Hodgkin’s lymphoma. Environ Health Perspect 112(8):854–861.15175172
Raab U, Albrecht M, Preiss U, . 2013. Organochlorine compounds, nitro musks and perfluorinated substances in breast milk - results from Bavarian monitoring of breast milk 2007/8. Chemosphere 93(3):461–467.23856469
Rahman MS, Bowadt S, Larsen B. 1993. Dual-column GC analysis of Mediterranean fish for ten organochlorine pesticides and sixty two chlorobiphenyls. J High Resolut Chromatogr 16:731–735.
Rajamanickam C, Padmanaban G. 1974. Biochemical effects of hexachlorobenzene. Indian J Biochem Biophys 11:119–122.4448459
Rajamanickam C, Amrutavalli J, Rao MR, . 1972. Effect of hexachlorobenzene on haem synthesis. Biochem J 129:381–387.4643324
Randi AS, Cocca C, Carbone V, . 2006. Hexachlorobenzene is a tumor co-carcinogen and induces alterations in insulin-growth factors signaling pathway in the rat mammary gland. Toxicol Sci 89(1):83–92.16237195
Ray LE, Murray HE, Giam CS. 1983. Organic pollutants in marine samples from Portland, Maine. Chemosphere 12:1031–1038.
Reid A, Callan A, Stasinska A, . 2013. Maternal exposure to organochlorine pesticides in Western Australia. Sci Total Environ 449:208–213.23428750
Renner G. 1988. Hexachlorobenzene and its metabolism. Toxicol Environ Chem 18:51–78.
RePORTER. 2015. Hexachlorobenzene. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 09, 2015.
Rhainds M, Levallois P, Ayotte P. 1999. Lead, mercury, and organochlorine compound levels in cord blood in Quebec, Canada. Arch Environ Health 54(1):40–47.10025415
Ribas-Fitó N, Cardo E, Sala M, . 2003a. Breastfeeding, exposure to organochlorine compounds, and neurodevelopment in infants. Pediatrics 111(5 Pt 1):e580–585.12728113
Ribas-Fitó N, Grimalt JO, Marco E, . 2005. Breastfeeding and concentrations of HCB and p,p’-DDE at the age of 1 year. Environ Res 98(1):8–13.15721878
Ribas-Fitó N, Sala M, Cardo E, . 2002. Association of hexachlorobenzene and other organochlorine compounds with anthropometric measures at birth. Pediatr Res 52(2):163–167.12149491
Ribas-Fitó N, Sala M, Cardo E, . 2003b. Organochlorine compounds and concentrations of thyroid stimulating hormone in newborns. Occup Environ Med 60(4):301–303.12660379
Ribas-Fitó N, Torrent M, Carrizo D, . 2007. Exposure to hexachlorobenzene during pregnancy and children’s social behavior at 4 years of age. Environ Health Perspect 115(3):447–450.17431497
Richter E, Schafer SG. 1981. Intestinal excretion of hexachlorobenzene. Arch Toxicol 47:233–239.7271449
Richter E, Renner G, Bayerl J, . 1981. Differences in the biotransformation of hexachlorobenzene (HCB) in male and female rats. Chemosphere 10:779–785.
Richter J, Landa K, Reznicek J. 1994. [Immune response in persons occupationally exposed to hexachlorobenzene]. Pracovni Lekarstvi 46(4):151–154. (Czech)
Rietjens IMCM, Steensma A, Den Besten C, . 1995. Comparative biotransformation of hexachlorobenzene and hexafluorobenzene in relation to the induction of porphyria. Eur J Pharmacol 293:293–299.8748681
Rignell-Hydbom A, Lindh CH, Dillner J, . 2012. A nested case-control study of intrauterine exposure to persistent organochlorine pollutants and the risk of hypospadias. PLoS ONE 7(9):e44767.23028613
*Rios de Molina MC, Billi de Catabbi S, San Martin de Viale LC. 1991. Liver ferrochelatase from normal and hexachlorobenzene porphyric rats. Mechanism of drug action. Int J Biochem 23:669–673.1864443
Rios de Molina MC, Wainstok e Calmanovici R, San Martin de Viale LC. 1980. Investigations on the presence of porphyrinogen carboxylase inhibitors in the liver of rats intoxicated with hexachlorobenzene. Int J Biochem 12:1027–1032.7450112
Ristola T, Pellinen J, Van Hoof PL, . 1996. Characterization of Lake Ladoga sediments. II. Toxic chemicals. Chemosphere 32(6):1179–1192.
Rizzardini M, Smith AG. 1982. Sex differences in the metabolism of hexachlorobenzene by rats and the development of porphyria in females. Biochem Pharmacol 31:3543–3548.7181936
*Rizzardini M, Cantoni L, Villa P, . 1990. Biochemical, morphological and flow-cytometric evaluation of the effects of hexachlorobenzene on rat liver. Cell Biol Toxicol 6:185–203.2361191
Robinson PE, Mack GA, Remmers J, . 1990. Trends of PCB, hexachlorobenzene, and β-benzene hexachloride levels in the adipose tissue of the U.S. population. Environ Res 53:175–192.1701383
Roche P, Prados M. 1995. Removal of pesticides by use of ozone or hydrogen peroxide/ozone. Ozone Sci Eng 17:657–672.
Rodrigues MA, Sanchez-Negrette M, Mantovani MS, . 1991. Liver response to low-hexachlorobenzene exposure in protein- or energy-restricted rats. Food Chem Toxicol 29: 757–764.1761255
Romaníc SH, Krauthacker B. 2000. Organochlorine pesticides and polychlorinated biphenyls in ambient air collected in Zagreb, Croatia. Bull Environ Contam Toxicol 64:811–816.10856337
Roos V, Ronn M, Salihovic S, . 2013. Circulating levels of persistent organic pollutants in relation to visceral and subcutaneous adipose tissue by abdominal MRI. Obesity 21(2):413–418.23532994
Rostad CE, Pereira WE, Leiker TJ. 1988. Distribution and transport of selected anthropogenic organic compounds in Mississippi River suspended sediment USA May-June 1988. J Contam Hydrol 16(2):175–199.
Rostad CE, Pereira WE, Leiker TJ. 1999. Distribution and transport of selected anthropogenic lipophilic organic compounds associated with Mississippi River suspended sediment, 1989-1990. Arch Environ Contam Toxicol 36:248–255.10047591
Rostad CE, Pereira WF, Leiker TJ. 1993. Distribution and transport of selected anthropogenic organic compounds on Mississippi River suspended sediment (U.S.A.), May/June 1988. J Contam Hydrol 16:175–199.
Roth WL, Freeman RA, Wilson AGE. 1993. A physiologically based model for gastrointestinal absorption and excretion of chemicals carried by lipids. Risk Anal 13:531–543.8259443
Roy RR, Wilson P, Laski RR, . 1997. Monitoring of domestic and imported apples and rice by the U.S. Food and Drug Administration Pesticide Program. J AOAC Int 80(4):883–894.9241850
Rozman K, Mueller W, Coulston F, . 1977a. Long-term feeding study of hexachlorobenzene in Rhesus monkeys. Chemosphere 2/3:81–84.
Rozman K, Mueller W, Coulston F, . 1977b. Long-term feeding study of hexachlorobenzene in Rhesus monkeys. Toxicol Appl Pharmacol 41:217.
Rozman K, Mueller WF, Coulston F, . 1978. Chronic low dose exposure of Rhesus monkeys to hexachlorobenzene (HCB). Chemosphere 2:177–184.
Rozman K, Rozman T, Greim H. 1981. Enhanced fecal elimination of stored hexachlorobenzene from rats and Rhesus monkeys by hexadecane or mineral oil. Toxicology 22:33–44.7336436
Rumack BH, Lovejoy FH Jr. 1991. Clinical toxicology. In: Amdur MO, Doull J, Klaasen CD, eds. Casarett and Doull’s toxicology: The basic science of poisons, 4th ed. New York, NY: Pergamon Press, 924–946.
*Rumsby PC, Evans JG, Phillimore HE, . 1992. Search for Ha-ras codon 61 mutations in liver tumours caused by hexachlorobenzene and aroclor 1254 in C57BL/10ScSn mice with iron overload. Carcinogenesis 13:1917–1920.1423854
Russell RW, Lazar R, Haffner GD. 1995. Biomagnification of Organochlorines in Lake Erie White Bass. Environ Toxicol Chem 14(4):719–724.
Rutten GA, Schoots AC, Vanholder R, . 1988. Hexachlorobenzene and 1,1-di(4-chlorophenyl)-2,2-dichloroethene in serum of uremic patients and healthy persons: Determination by capillary gas chromatography and electron capture detection. Nephron 48:217–221.3352849
Sagiv SK, Tolbert PE, Altshul LM, . 2007. Organochlorine exposures during pregnancy and infant size at birth. Epidemiology 18(1):120–129.17179760
Sala M, Ribas-Fito N, Cardo E, . 2001a. Levels of hexachlorobenzene and other organochlorine compounds in cord blood: Exposure across placenta. Chemosphere 43:895–901.11372882
Sala M, Ribas-Fito N, de Muga ME, . 1999a. Hexachlorobenzene and other organochlorine compounds incorporation to the new-borns and its effects on neonatal neurological development at 6-8 weeks of life. Organohalogen Compounds 44:241–242.
Sala M, Sunyer J, Herrero C, . 2001b. Association between serum concentrations of hexachlorobenzene and polychlorobiphenyls with thyroid hormone and liver enzymes in a sample of the general population. Occup Environ Med 58:172–177.11171930
Sala M, Sunyer J, Otero R, . 1999b. Health effects of chronic high exposure to hexachlorobenzene in a general population sample. Arch Environ Health 54(2):102–109.10094287
Sala M, Sunyer J, Otero R, . 1999c. Organochlorine in the serum of inhabitants living near an electrochemical factory. Occup Environ Med 56:152–158.10448322
Salata H, Cortes JM, Enriquez de Salamanca R, . 1985. Porphyria cutanea tarda and hepatocellular carcinoma: Frequency of occurrence and related factors. J Hepatol 1:477–487.2997323
Salihovic S, Mattioli L, Lindstrom G, . 2012. A rapid method for screening of the Stockholm Convention POPs in small amounts of human plasma using SPE and HRGC/HRMS. Chemosphere 86:747–753.22153485
Sandberg S, Romslo I, Hovding G, . 1982. Porphyrin-induced photodamage as related to the subcellular localization of the porphyrins. Acta Derm Venereol (Stockh) 100:75–80.
Saoudi A, Frery N, Zeghnoun A, . 2014. Serum levels of organochlorine pesticides in the French adult population: The French National Nutrition and Health Study (ENNS), 2006-2007. Sci Total Environ 472:1089–1099.24361744
Sasaki YF, Izumiyama F, Nishidate E, . 1997. Detection of rodent liver carcinogen genotoxicity by the alkaline single-cell gel electrophoresis (Comet) assay in multiple mouse organs (liver, lung, spleen, kidney, and bone marrow). Mutat Res 391:201–214.9268046
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3:Article 46. 10.3389/fphar.2012.00046.
Sawada N, Iwasaki M, Inoue, M, . 2010. Plasma organochlorines and subsequent risk of prostate cancer in Japanese men: A nested case-control study. Environ Health Perspect 18(5):659–665.
Schauerte W, Lay JP, Klein W, . 1982. Long-term fate of organochlorine xenobiotics in aquatic ecosystems. Distribution, residual behavior, and metabolism of hexachlorobenzene, pentachloronitrobenzene, and 4-chloroaniline in small experimental ponds. Ecotox Environ Saf 6:560–569.
Schecter A, Ryan JJ, Papke O. 1998. Decrease in levels and body burden of dioxins, dibenzofurans, PCBs, DDE, and HCB in blood and milk in a mother nursing twins over a thirty-eight month period. Chemosphere 37(9–12):1807–1816.9828309
Scheele J, Teufel M, Niessen KH. 1995. A comparison of the concentrations of certain chlorinated hydrocarbons and polychlorinated biphenyls in bone marrow and fat tissue of children and their concentrations in breast milk. J Environ Pathol Toxicol Oncol 14:11–14.7473068
Scheele J, Teufel M, Niessen K-H. 1996. Chlorinated hydrocarbons in human bone marrow of healthy individuals and leukemia patients. Arch Environ Health 51(1):22–25.8629858
Schell LM, Gallo MV. 2010. Relationships of putative endocrine disruptors to human sexual maturation and thyroid activity in youth. Physiol Behav 99(2):246–253.19800354
Schell LM, Gallo MV, Decaprio AP, . 2004. Thyroid function in relation to burden of PCBs, p,p’-DDE, HCB, mirex and lead among Akwesasne Mohawk youth: A preliminary study. Environ Toxicol Pharmacol 18(2):91–99.21782738
Schell LM, Gallo MV, Denham M, . 2008. Relationship of thyroid hormone levels to levels of polychlorinated biphenyls, lead, p,p’- DDE, and other toxicants in Akwesasne Mohawk youth. Environ Health Perspect 116(6):806–813.18560538
Schell LM, Gallo MV, Ravenscroft J, . 2009. Persistent organic pollutants and anti-thyroid peroxidase levels in Akwesasne Mohawk young adults. Environ Res 109(1):86–92.18995849
Schettgen T, Gube M, Alt A, . 2011. Pilot study on the exposure of German general population to non-dioxin-like and dioxin-like PCBs. Int J Hyg Environ Health 214:319–325.21616713
Scheufler E, Rozman K. 1984a. Comparative decontamination of hexachlorobenzene exposed rats and rabbits by hexadecane. J Toxicol Environ Health 14:353–362.6502739
Scheufler E, Rozman K. 1984b. Effect of hexadecane on the pharmacokinetics of hexachlorobenzene. Toxicol Appl Pharmacol 75:190–197.6474457
Scheunert I, Marra C, Viswanathan R, . 1983. Fate of hexachlorobenzene-^14^C in wheat plants and soils under outdoor conditions. Chemosphere 12(6):843–858.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schielen P, Den Besten C, Vos JG, . 1995a. Immune effects of hexachlorobenzene in the rat: Role of metabolism in a 13-week feeding study. Toxicol Appl Pharmacol 131:37–43.7878676
Schielen P, Schoo W, Tekstra J, . 1993. Autoimmune effects of hexachlorobenzene in the rat. Toxicol Appl Pharmacol 122:233–243.8212005
Schielen P, Van Rodijnen W, Pieters RHH, . 1995b. Hexachlorobenzene treatment increases the number of splenic B-1 like cells and serum autoantibody levels in the rat. Immunology 86:568–574.8567023
Schlummer M, Moser GA, McLachlan MS. 1998. Digestive tract absorption of PCDD/Fs, PCBs, and HCB in humans: Mass balances and mechanistic considerations. Toxicol Appl Pharmacol 152:128–137.9772208
Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in U.S. freshwater fish, 1976-1984. Arch Environ Contam Toxicol 19:748–781.21318506
Schoula R, Hajslova J, Bencko V, . 1996. Occurrence of persistent organochlorine contaminants in human milk collected in several regions of Czech Republic. Chemosphere 33(8):1485–1494.8856955
Schrank CS, Cormier SM, Blazer VS. 1997. Contaminant exposure, biochemical, and histopathological biomarkers in white suckers from contaminated and reference sites in the Sheboygan River, Wisconsin. J Great Lakes Res 23(2):119–130.
Schroll R, Bierling B, Cao B, . 1994. Uptake pathways of organic chemicals from soil by agricultural plants. Chemosphere 28(2):297–303.
Schuhmacher M, Domingo JL, Agramunt MC, . 2002. Biological monitoring of metals and organic substances in hazardous-waste incineration workers. Int Arch Occup Environ Health 75(7):500–506.12172897
Seidel V, Linder W. 1993. Universal sample enrichment technique for organochlorine pesticides in environmental and biological samples using a redesigned simultaneous steam distillation- solvent extraction apparatus. Anal Chem 65:3677–3683.
Selden AI, Floderus Y, Bodin LS, . 1999. Porphyrin status in aluminum foundry workers exposed to hexachlorobenzene and octachlorostyrene. Arch Environ Health 54(4):248–253.10433183
Selden A, Jacobson G, Berg P, . 1989. Hepatocellular carcinoma and exposure to hexachlorobenzene: A case report. Br J Ind Med 46:138–140.2538141
Selden AS, Westberg HB, Hanberg A, . 1997. Congener-specific monitoring of PCB and hexachlorobenzene in hazardous waste incineration workers. Organohalogen Compounds 33:398–401.
Shan TH, Hopple JA, Foster GD. 1994. Alternative tissue analysis method developed for organochlorine contaminants in aquatic organisms. Bull Environ Contam Toxicol 53:382–389.7919715
Shaw SD, Berger ML, Harris JH, . 2013. Persistent organic pollutants including polychlorinated and polybrominated dibenzo-p-dioxins and dibenzofurans in firefighters from Northern California. Chemosphere 91(10):1386–1394.23395527
Shen H, Main KM, Virtanen HE, . 2007. From mother to child: Investigation of prenatal and postnatal exposure to persistent bioaccumulating toxicants using breast milk and placenta biomonitoring. Chemosphere 67(9):S256–262.17207515
Sherwood RL, Thomas PT, O’Shea WJ, . 1989. Effects of inhaled hexachlorobenzene aerosols on rat pulmonary host defenses. Toxicol Ind Health 5:451–461.2788323
Shirai T, Miyata Y, Nakanishi K, . 1978. Hepatocarcinogenicity of polychlorinated terphenyl (PCT) in ICR mice and its enhancement by hexachlorobenzene (HCB). Cancer Lett 4:271–275.207412
Siekel P, Chalupa I, Beno J, . 1991. A genotoxicological study of hexachlorobenzene and pentachloroanisole. Teratog Carcinog Mutagen 11:55–60.1677498
Siersema PD, ten Kate FJW, Mulder PGH, . 1992. Hepatocellular carcinoma in porphyria cutanea tarda: Frequency and factors related to its occurrence. Liver 12:56–61.1320175
Siersema PD, Van Helvoirt RP, Ketelaars DAM, . 1991. Iron and uroporphyrin in hepatocytes of inbred mice in experimental porphyria: A biochemical and morphological study. Hepatology 14:1179–1188.1959868
Silkworth JB, Loose LD. 1981. Assessment of environmental contaminant-induced lymphocyte dysfunction. Environ Health Perspect 39:105–128.7016518
Simon GS, Tardiff RG, Borzelleca JF. 1979. Failure of hexachlorobenzene to induce dominant lethal mutations in the rat. Toxicol Appl Pharmacol 47:415–419.452032
Simonich SL, Hites RA. 1995. Organic pollutant accumulation in vegetation. Environ Sci Technol 29(12):2905–2914.22148195
Sims DE, Singh A, Donald A, . 1991. Alteration of primate ovary surface epithelium by exposure to hexachlorobenzene: A quantitative study. Histol Histopathol 6:525–529.1804430
Sinclair PR, Gorman N, Sinclair JF, . 1995. Ascorbic acid inhibits chemically induced uroporphyria in ascorbate requiring rats. Hepatology 22(2):565–572.7635426
Sinkkonen S, Rantio T, Vattulainen A, . 1995. Chlorohydrocarbons, PCB congeners, polychlorodioxins, furans and dibenzothiophenes in pine needles in the vicinity of a metal reclamation plant. Chemosphere 30(12):2227–2239.
Sinkkonen S, Welling L, Vattulainen A, . 1996. Short chain aliphatic halocarbons and polychlorinated biphenyls in pine needles: Effects of metal scrap plant emissions. Chemosphere 32(10):1971–1982.
Sioen I, Den Hond E, Nelen V, . 2013. Prenatal exposure to environmental contaminants and behavioural problems at age 7-8 years. Environ Int 59:225–231.23845936
Sitarska E, Klucinski W, Faundez R, . 1995. Concentration of PCBs, HCB, DDT, and HCH isomers in the ovaries, mammary gland, and liver of cows. Bull Environ Contam Toxicol 55:865–869.8601066
Siyali DS. 1972. Hexachlorobenzene and other organochloride pesticides in human blood. Med J Aust 2:1063–1066.4642422
Skaare JU, Bernhoft A, Wiig O, . 2001. Relationships between plasma levels of organochlorines, retinol and thyroid hormones from polar bears (Ursus maritimus) at Svalbard. J Toxicol Environ Health 62(part A):227–241.
Smelt JH, Leistra M. 1974. Hexachlorobenzene in soils and crops after soil treatment with pentachloronitrobenzene. Agric Environ 1:65–71.
Smink A, Ribas-Fito N, Garcia R, . 2008. Exposure to hexachlorobenzene during pregnancy increases the risk of overweight in children aged 6 years. Acta Paediatr 97(10):1465–1469.18665907
Smith AG. 1989. Iron-mediated mechanisms of liver injury by polyhalogenated aromatic chemicals. Human Toxicol 8:149–150. (Abstract)
Smith AG. 1991. Chlorinated hydrocarbon insecticides. In: Hayes Jr WJ, Laws Jr ER, eds. Handbook of pesticide toxicology. Vol. 2: Classes of pesticides. San Diego, CA: Academic Press, 731–915.
Smith AG, Cabral JR. 1980. Liver-cell tumors in rats fed hexachlorobenzene. Cancer Lett 11:169–172.7459845
Smith AG, De Matteis F. 1990. Oxidative injury mediated by the hepatic cytochrome P-450 system in conjunction with cellular iron: Effects on the pathway of haem biosynthesis. Xenobiotica 20:865–877.2238708
Smith AG, Francis JE. 1983. Synergism of iron and hexachlorobenzene inhibits hepatic uroporphyrinogen decarboxylase in inbred mice. Biochem J 214:909–913.6626162
Smith AG, Francis JE. 1987. Chemically-induced formation of an inhibitor of hepatic uroporphyrinogen decarboxylase in inbred mice with iron overload. Biochem J 246:221–226.3675556
Smith AG, Cabral JR, Carthew P, . 1989. Carcinogenicity of iron in conjunction with a chlorinated environmental chemical, hexachlorobenzene, in C57BL/10ScSn mice. Int J Cancer 43:492–496.2925279
Smith AG, Cabral JRP, De Matteis F. 1979. A difference between two strains of rats in their liver non-haem iron content and in their response to the porphyrogenic effect of hexachlorobenzene. Chem Biol Interact 27:353–363.498361
Smith AG, Carthew P, Francis JE, . 1993. Enhancement by iron of hepatic neoplasia in rats caused by hexachlorobenzene. Carcinogenesis 14(7):1381–1387.8330354
Smith AG, Dinsdale D, Cabral JR, . 1987. Goitre and wasting induced in hamsters by hexachlorobenzene. Arch Toxicol 60:343–349.3662806
Smith AG, Francis JE, Bird I. 1986d. Distinction between octachlorostyrene and hexachlorobenzene in their potential to induce ethoxyphenoxazone deethylase and cause porphyria in rats and mice. J Biochem Toxicol 1:105–117.3271868
Smith AG, Francis JE, Dinsdale D, . 1985. Hepatocarcinogenicity of hexachlorobenzene in rats and the sex difference in hepatic iron status and development of porphyria. Carcinogenesis 6(4):631–636.3986965
Smith AG, Francis JE, Green JA, . 1990. Sex-linked hepatic uroporphyria and the induction of cytochromes P450IA in rats caused by hexachlorobenzene and polyhalogenated biphenyls. Biochem Pharmacol 40:2059–2068.2173599
Smith AG, Francis JE, Kay SJE, . 1986a. Mechanistic studies of the inhibition of hepatic uroporphyrinogen decarboxylase in C57BL/10 mice by iron-hexachlorobenzene synergism. Biochem J 238:871–878.3800966
*Smith AG, Stewart FP, Francis JE. 1986c. Genetic, iron status and sex factors of porphyria induced by hexachlorobenzene. IARC Sci Publ 77:433–439.
Smith AG, Wright AL, Cabral JRP. 1986b. Influence of hexachlorobenzene on thyroids of male hamsters. IARC Sci Publ 77:357–359.
Somers JD, Goski BC, Barbeau JM, . 1993. Accumulation of organochlorine contaminants in double-crested cormorants. Environ Pollut 80(1):17–23.15091867
Son HK, Kim SA, Kang JH, . 2010. Strong associations between low-dose organochlorine pesticides and type 2 diabetes in Korea. Environ Int 36(5):410–414.20381150
Song S, Ma J, Tian Q, . 2013. Hexachlorobenzene in human milk collected from Beijing, China. Chemosphere 91(2):145–149.23336922
Sopena de Kracoff YE, Ferramola de Sancovich AM, Sancovich HA, . 1994. Effect of thyroidectomy and thyroxine on hexachlorobenzene induced porphyria. J Endocrinol Invest 17:301–305.8077613
Sopena de Kracoff YE, Ferramola de Sancovich AM, Sancovich HA. 2008. Hexachlorobenzene treatment on hepatic mitochondrial function parameters and intracellular coproporphyrinogen oxidase location. Int J Toxicol 27(6):455–465.19482825
Spinelli JJ, Ng CH, Weber JP, . 2007. Organochlorines and risk of non-Hodgkin lymphoma. Int J Cancer 121(12):2767–2775.17722095
Stachel B, Dougherty RC, Lahl U, . 1989. Toxic environmental chemicals in human semen: Analytical method and case studies. Andrologia 21:282–291.2774220
Stewart FP, Smith AG. 1986. Metabolism of hexachlorobenzene by rat-liver microsomes. IARC Sci Publ 77:325–327.
*Stewart FP, Manson MM, Cabral JR, . 1989. Hexachlorobenzene as a promoter of diethylnitrosamine-initiated hepatocarcinogenesis in rats and comparison with induction of porphyria. Carcinogenesis 10:1225–1230.2736716
Strandberg B, Bandh C, van Bavel R, . 2000. Organochlorine compounds in the Gulf of Bothnia: Sediment and benthic species. Chemosphere 40:1205–1211.10739063
Strøm M, Hansen S, Olsen SF, . 2014. Persistent organic pollutants measured in maternal serum and offspring neurodevelopmental outcomes. A prospective study with long-term follow-up. Environ Int 68:41–48.24704638
Stuetz W, Prapamontol T, Erhardt JG, . 2001. Organochlorine pesticide residues in human milk of a Hmong hill tribe living in Northern Thailand. Sci Total Environ 273:53–60.11419602
Sufit RL, Hodach R, Arends R, . 1986. Decreased conduction velocity and pseudomyotonia in hexachlorobenzene-fed rats. IARC Sci Publ 77:379–380.
Sugiura-Ogasawara M, Ozaki Y, Sonta S, . 2003. PCBs, hexachlorobenzene and DDE are not associated with recurrent miscarriage. Am J Reprod Immunol 50(6):485–489.14750556
Sundlof SF, Hansen LG, Koritz GD, . 1982. The pharmacokinetics of hexachlorobenzene in male beagles: Distribution, excretion, and pharmacokinetics model. Drug Metab Dispos 10:371–381.6126337
Sundlof SM, Parker AJ, Simon J, . 1981. Sub-acute toxicity of hexachlorobenzene in female beagles, including electroencephalographic changes. Vet Hum Toxicol 23:92–96.7292956
Sunyer J, Alvarez-Pedrerol M, To-Figueras J, . 2008. Urinary porphyrin excretion in children is associated with exposure to organochlorine compounds. Environ Health Perspect 116(10):1407–1410.18941586
Sunyer J, Herrero C, Ozalla D, . 2002. Serum organochlorines and urinary porphyrin pattern in a population highly exposed to hexachlorobenzene. Environ Health 1(1):1.12495451
Susarla S, Yonezawa Y, Masunaga S. 1997. Transformation kinetics and pathways of chlorophenols and hexachlorobenzene in fresh water lake sediment under anaerobic conditions. Environ Technol 18:903–911.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Sweeney GD, Basford D, Drestynski F. 1986. The role of contaminants in hexachlorobenzene toxicity. IARC Sci Publ 77:363–370.
Swift BL, Foley RE, Batcheller GR. 1993. Organochlorines in common Goldeneyes wintering in New York. Wildl Soc Bull 21(1):52–56.
Szymczynski GA, Waliszewski SM. 1981. Comparison of the content of chlorinated pesticide residues in human semen, testicles and fat tissues. Andrologia 13:250–252.6168217
Szyrwinska K, Lulek J. 2007. Exposure to specific polychlorinated biphenyls and some chlorinated pesticides via breast milk in Poland. Chemosphere 66(10):1895–1903.17023022
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Takei GH, Kauahikaua SM, Leong GH. 1983. Analyses of human milk samples collected in Hawaii for residues of organochlorine pesticides and polychlorobiphenyls. Bull Environ Contam Toxicol 30:606–613.6407553
Takser L, Mergler D, Baldwin M, . 2005. Thyroid hormones in pregnancy in relation to environmental exposure to organochlorine compounds and mercury. Environ Health Perspect 113(8):1039–1045.16079076
Tate CM, Heiny JS. 1996. Organochlorine compounds in bed sediment and fish tissue in the South Platte River Basin, USA, 1992-1993. Arch Environ Contam Toxicol 30:62–78.
Taylor DH, Goldey E. 1990. Assessment of the behavioral and neurotoxic effects of hexachlorobenzene (HCB) in the developing rat. Wright Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory. AAMRL-TR-90-076. ADA243658.
Tchounwou PB, Abdelghani AA, Pramar YV, . 1998. Health risk assessment of hexachlorobenzene and hexachlorobutadiene residues in fish collected from a hazardous waste contaminated wetland in Louisiana, USA. In: Little EE, Greenberg BM, DeLonay AJ, eds. Environmental toxicology and risk assessment. 7th Vol., 368–382.
ten Hulscher TEM, Van Der Velde LE, Bruggeman WA. 1992. Temperature dependence of Henry’s law constants for selected chlorobenzenes, polychlorinated biphenyls and polycyclic aromatic hydrocarbons. Environ Toxicol Chem 11:1595–1603.
Teufel M, Niessen KH, Sartoris J, . 1990. Chlorinated hydrocarbons in fat tissue: Analyses of residues in healthy children, tumor patients, and malformed children. Arch Environ Contam Toxicol 19(5):646–652.2241236
Thier H-P, Zeumer H. 1987a. Organochlorine, organophosphorus nitrogen-containing and other pesticides. Deutsche Forschungsgemeinschaft: Manual of pesticide residue analysis. Vol. 1. Weinheim, Germany: VCH, 383–400.
Thier H-P, Zeumer H. 1987b. Organochlorine and organophosphorus pesticides. Deutsche Forschungsgemeinschaft: Manual of pesticide residue analysis. Vol. 1. Weinheim, Germany:VCH, 298–307.
Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds., Handbook of chemical property estimation methods. Environmental behavior of organic compounds. Washington DC: American Chemical Society, 15-1–15-34.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomsen C, Liane VH, Becher G. 2007. Automated solid-phase extraction for the determination of polybrominated diphenyl ethers and polychlorinated biphenyls in serum--application on archived Norwegian samples from 1977 to 2003. J Chromatogr B Analyt Technol Biomed Life Sci 846(1–2):252–263.
Tiernan TO, Solch JG, Garrett JG, . 1990. A concerted analytical method for determination of various halogenated and related bioaccumulating compounds in fish and sediments. Organohalogen Compounds 2:225–228.
Tiernan TO, Taylor ML, Garrett JH, . 1985. Sources and fate of polychlorinated dibenzodioxins, dibenzofurans and related compounds in human environments. Environ Health Perspect 59:145–158.3921357
Tobin P. 1986. Known and potential sources of hexachlorobenzene. IARC Sci Publ 77:3–11.
To-Figueras J, Barrot C, Sala M, . 2000. Excretion of hexachlorobenzene and metabolites in feces in a highly exposed human population. Environ Health Perspect 108(7):595–598.
To-Figueras J, Gomez-Catalan J, Rodamilans M, . 1991. Studies on sex differences in excretion of sulphur derivatives of hexachlorobenzene and pentachloronitrobenzene by rats. Toxicol Lett 56:87–94.2017788
To-Figueras J, Gomez-Catalan J, Rodamilans M, . 1992. Sulphur derivative of hexachlorobenzene in human urine. Human Exp Toxicol 11:271–273.
To-Figueras J, Sala M, Otero R, . 1997. Metabolism of hexachlorobenzene in humans: Association between serum levels and urinary metabolites in a highly exposed population. Environ Health Perspect 105(1):78–83.9074885
Tong M, Youn S. 2012. Physiochemical technologies for HCB remediation and disposal: A review. J Hazard Mater 229–230:1–14.
Topi GC, D’Alessandro Gandolfo L, Griso D, . 1980. Porphyria cutanea tarda and hepatocellular carcinoma. Int J Biochem 12:883–885.6161035
Torinuki W, Kumai N, Miura T. 1981. Histopathological studies on sun-exposed hexachlorobenzene-induced porphyric rat skin. Tohoku J Exp Med 134:425–430.7324041
Torres-Arreola L, Berkowitz G, Torres-Sanchez L, . 2003. Preterm birth in relation to maternal organochlorine serum levels. Ann Epidemiol 13(3):158–162.12604158
*Trenti T, Ventura E, Ceccarelli D, . 1986. Functional derangement of liver mitochondria from hexachlorobenzene-treated rats. IARC Sci Publ 77:329–331.
TRI13. 2014. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. httpwww.epa.gov/triexplorer/ (http://www.epa.gov/triexplorer/). November 12, 2014.
Trotter WJ, Dickerson R. 1993. Pesticide residues in composited milk collected through the U.S. Pasteurized Milk Network. J AOAC Int 76(6):1220–1225.8286959
Tsuda H, Matsumoto K, Ogino H, . 1993. Demonstration of initiation potential of carcinogens by induction of preneoplastic glutathione S transferase P-form-positive liver cell foci: Possible in vivo assay system for environmental carcinogens. Jpn J Cancer Res 84:230–236.7683635
Tsydenova OV, Sudaryanto A, Kajiwara N, . 2007. Organohalogen compounds in human breast milk from Republic of Buryatia, Russia. Environ Pollut 146(1):225–232.16891045
Uhlik O, Strejcek M, Vondracek J, . 2014. Bacterial acquisition of hexachlorobenzene-derived carbon in contaminated soil. Chemosphere 113:141–145.25065801
Umegaki K, Ikegami S. 1998. Feeding fish oil to rats accelerates the metabolism of hexachlorobenzene. J Nutr Sci Vitaminol 44:301–311.9675710
UNEP. 1996. UNEP survey on sources of POPs: A report prepared for an IFCS expert meeting on persistent organic pollutants: Manila, the Philippines, 17-19 June 1996. United Nations Environment Programme. http://www.chem.unep.ch/pops/indxhtms/manexp3.html.
Vafeiadi M, Vrijheid M, Fthenou E, . 2014. Persistent organic pollutants exposure during pregnancy, maternal gestational weight gain, and birth outcomes in the mother-child cohort in Crete, Greece (RHEA study). Environ Int 64:116–123.24389008
Valvi D, Mendez MA, Garcia-Esteban R, . 2014. Prenatal exposure to persistent organic pollutants and rapid weight gain and overweight in infancy. Obesity 22(2):488–496.23963708
Vampre TM, Fuccillo R, deAndrea MM. 2010. Oligoqueta eisenai andrei como bioindicador de contaminacao de solo por hexaclorobenzeno. Revista Brasileira de Ciencia do Solo 34:59–66.
Van Den Berg KJ. 1990. Interaction of chlorinated phenols with thyroxine binding sites of human transthyretin, albumin and thyroid binding globulin. Chem Biol Interact 76:63–75.2393944
Van Loveren H, Kranjnc EI, Rombout PJA, . 1990. Effects of ozone, hexachlorobenzene, and bis(tri-n-butyltin)oxide on natural killer activity in the rat lung. Toxicol Appl Pharmacol 102:21–33.2136961
van Ommen B, Hendriks W, Bessems JGM, . 1989. The relation between the oxidative biotransformation of hexachlorobenzene and its porphyrinogenic activity. Toxicol Appl Pharmacol 100:517–528.2789443
van Ommen B, Van Bladeren PJ, Temmink JHM, . 1985. Formation of pentachlorophenol as the major product of microsomal oxidation of hexachlorobenzene. Biochem Biophys Res Comm 126:25–32.3970692
van Raaij JAGM, Frijters CMG, van den Berg KJ. 1993a. Hexachlorobenzene-induced hypothyroidism: Involvement of different mechanism by parent compound and metabolite. Biochem Pharmacol 46(8):1385–1391.8240387
van Raaij JAGM, Frijters CMG, Wong Yen kong L, . 1994. Reduction of thyroxine uptake into cerebrospinal fluid and rat brain by hexachlorobenzene and pentachlorophenol. Toxicology 94:197–208.7801323
van Raaij JAGM, Kaptein E, Visser TJ, . 1993b. Increased glucuronidation of thyroid hormone in hexachlorobenzene-treated rat. Biochem Pharmacol 45(3):627–631.8442763
van Raaij JA, van den Berg KJ, Engel R, . 1991a. Effects of hexachlorobenzene and its metabolites pentachlorophenol and tetrachlorohydroquinone on serum thyroid hormone levels in rats. Toxicology 67:107–116.2017761
*van Raaij JA, van den Berg KJ, Notten WR. 1991b. Hexachlorobenzene and its metabolites pentachlorophenol and tetrachlorohydroquinone: Interaction with thyroxine binding sites of rat thyroid hormone carriers ex vivo and in vitro. Toxicol Lett 59:101–107.1755017
Veith GD, DeFoe DL, Bergstedt BV, . 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048.
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 712–717.
Verschueren K. 1996. Handbook of environmental data on organic chemicals. 3rd ed. New York, NY: Van Nostrand Reinhold Company, 1064–1069.
Verschueren K. 2001. Hexachlorobenzene. In: Handbook of environmental data on organic chemicals. Vol. 2. New York, NY: John Wiley & Sons, Inc., 1226–1231.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vilanova R, Fernandez P, Martinez C, . 2001. Organochlorine pollutants in remote mountain lake waters. J Environ Qual 30:1286–1295.11476507
Villeneuve DC, Hierlihy SL. 1975. Placental transfer of hexachlorobenzene in the rat. Bull Environ Contam Toxicol 13:489–491.1131453
*Villeneuve DC, Newsome WH. 1975. Toxicity and tissue levels in the rat and guinea pig following acute hexachlorobenzene administration. Bull Environ Contam Toxicol 14:297–300.1174742
Villeneuve DC, Panopio LG, Grant DL. 1974a. Placental transfer of hexachlorobenzene in the rabbit. Environ Physiol Biochem 4:112–115.4457339
*Villeneuve DC, Phillips WEJ, Panopio LG, . 1974b. The effects of phenobarbital and carbon tetrachloride on the rate of decline of body burdens of hexachlorobenzene in the rat. Arch Environ Contam Toxicol 2:243–252.4419585
Villeneuve DC, Van Logten MJ, Den Tonkelaar EM, . 1977. Effect of food deprivation on low level hexachlorobenzene exposure in rats. Sci Total Environ 8:179–186.905821
Vincent SH, Smith AG, Muller-Eberhard U. 1989. Modulation of hepatic heme-binding Z protein in mice by the porphyrogenic carcinogens griseofulvin and hexachlorobenzene. Cancer Lett 45:109–114.2731154
Visser O, Van den Berg JW, Edixhoven-Bosdisk A, . 1989. Development of hexachlorobenzene porphyrin in rats: Time sequence and relationship with lipid peroxidation. Food Chem Toxicol 27:317–321.2744662
Vos JG, Brouwer GMJ, van Leeuwen FXR, . 1983. Toxicity of hexachlorobenzene in the rat following combined pre- and post-natal exposure: Comparison of effects on immune system, liver and lung. In: Gibson GG, Hubbard R, Parke DV, eds. Immunotoxicology. London, England: Academic Press, 219–235.
Vos JG, van Logten MJ, Kreeftenberg JG, . 1979a. Effect of hexachlorobenzene on the immune system of rats following combined pre- and postnatal exposure. Drug Chem Toxicol 2:61–76.398252
Vos JG, van Logten MJ, Kreeftenberg JG, . 1979b. Hexachlorobenzene-induced stimulation of the humoral immune response in rats. Ann NY Acad Sci 320:535–550.378061
Vos RME, Snoek MC, Van Berkel WJH, . 1988. Differential induction of rat hepatic glutathione S-transferase isoenzymes by hexachlorobenzene and benzyl isothiocyanate: Comparison with induction by phenobarbital and 3-methylcholanthrene. Bio Chem Pharmacol 37:1077–1082.
Wada O, Yano Y, Urata G, . 1968. Behavior of hepatic microsomal cytochromes after treatment of mice with drugs known to disturb porphyrin metabolism in liver. Biochem Pharmacol 17:595–603.4172063
Waddington RT. 1972. Short notes of rare or obscure cases. A case of primary liver tumour associated with porphyria. Brit J Surg 59:653–654.5069208
*Wagner U, Schlebusch H, Van der Ven H, . 1990. Accumulation of pollutants in the genital tract of sterility patients. J Clin Chem Clin Biochem 28:683–688.2283496
Wainstok de Calmanovici R, San Martin de Viale LC. 1980. Effect of chlorophenols on porphyrin metabolism in rats and chicken embryo. Int J Biochem 12:1039–1044.7450113
*Wainstok de Calmanovici R, Billi de Catabbi SC, Aldonatti CA. 1989. Influence of the strain of rats on the induction of hexachlorobenzene induced porphyria. Int J Biochem 21:377–381.2744208
*Wainstok de Calmanovici R, Cochon AC, Aldonatti C, . 1990. Synergistic effect of mammary tumors on hexachlorobenzene-induced porphyria in rats. Cancer Lett 55:67–73.2245412
Wainstok de Calmanovici R, Cochon AC, Aldonatti C, . 1991. Sex comparison of heme pathway in rats bearing hepatic tumors. Tumori 77:379–384.1781034
*Wainstok de Calmanovici R, Rios de Molina MDC, Taira de Yamasato MC, . 1984. Mechanism of hexachlorobenzene-induced porphyria in rats: Effect of phenobarbitone pretreatment. Biochem J 218:753–763.6721832
Waliszewski SM, Szymczynski GA. 1985. Inexpensive, precise method for the determination of chlorinated pesticide residues in soil. J Chromatogr 321:480–483.
Waliszewski SM, Aguirre AA, Benitez A, . 1999a. Organochlorine pesticide residues in human blood serum of inhabitants of Veracruz, Mexico. Bull Environ Contam Toxicol 62(4):397–402.10094720
Waliszewski SM, Aguirre AA, Infanzon RM, . 1998. Time trend of organochlorine pesticide residues in human adipose tissue in Veracruz, Mexico: 1988-1997 survey. Sci Total Environ 221:201–204.9842747
Waliszewski SM, Aguirre AA, Infanzon RM, . 1999b. Comparison of organochlorine pesticide levels in adipose tissue and human milk of mothers living in Veracruz, Mexico. Bull Environ Contam Toxicol 62(6):685–690.10353993
Waliszewski SM, Aguirre AA, Infanzon RM. 1999c. Levels of organochlorine pesticides in blood serum and umbilical blood serum of mothers living in Veracruz, Mexico. Fresenius Environ Bull 8:171–178.
Waliszewski SM, Aguirre AA, Infanzon RM, . 2000a. Comparison of organochlorine pesticide levels in adipose tissue and blood serum from mothers living in Veracruz, Mexico. Bull Environ Contam Toxicol 64:8–15.10606686
Waliszewski SM, Aguirre AA, Infanzon RM, . 2000b. Partitioning coefficients of organochlorine pesticides between mother blood serum and umbilical blood serum. Bull Environ Contam Toxicol 65:293–299.10903351
Waliszewski SM, Aguirre AA, Infanzon RM, . 2001. Organochlorine pesticide levels in maternal adipose tissue, maternal blood serum, umbilical blood serum, and milk from inhabitants of Veracruz, Mexico. Arch Environ Contam Toxicol 40:432–438.11443377
Waliszewski SM, Meza Hernandez MV, Infanzon RM, . 2003. [Persistent organochlorine pesticide levels in women with breast cancer in Veracruz, Mexico]. Revista Internacional de Contaminacion Ambiental 19(2):59–65. (Spanish)
Waliszewski SM, Pardio Sedas VT, Chantiri JN, . 1996. Organochlorine pesticide residues in human breast milk from tropical areas in Mexico. Bull Environ Contam Toxicol 57:22–28.8661455
Wania F, Mackay D. 1993. Global fractionation and cold condensation of low volatility organochlorine compounds in polar regions. Ambio 22(1):10–18.
Wania F, Mackay D. 1995. A global distribution model for persistent organic chemicals. Sci Total Environ 160/161:211–232.
Wegiel M, Chrzaszcz R, Maslanka A, . 2011. Study on the determination of PCDDs/Fs and HCB in exhaust gas. Chemosphere 85:481–486.21925704
Weiderpass E, Adami HO, Baron JA, . 2000. Organochlorines and endometrial cancer risk. Cancer Epidemiol Biomarkers Prev 9:487–493.10815693
Weisenberg E. 1986. Hexachlorobenzene in human milk: A polyhalogenated risk. IARC Sci Publ 77:193–200.
Weisenberg E, Arad I, Grauer F, . 1985. Polychlorinated biphenyls and organochlorine insecticides in human milk in Israel. Arch Environ Contam Toxicol 14:517–521.3931568
Weistrand C, Noren K. 1998. Polychlorinated naphthalenes and other organochlorine contaminants in human adipose and liver tissue. J Toxicol Environ Health 53:293–311.
Weldon RH, Barr DB, Trujillo C, . 2011. A pilot study of pesticides and PCBs in the breast milk of women residing in urban and agricultural communities of California. J Environ Monit 13(11):3136–3144.22009134
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whitmore RW, Immerman FW, Camann DE, . 1994. Non occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contam Toxicol 26(1):47–59.8110023
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Wickstrom K, Pyysalo H, Siimes MA. 1983. Levels of chlordane, hexachlorobenzene, PCB and DDT compounds in Finnish human milk in 1982. Bull Environ Contam Toxicol 31:251–256.6414557
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Williams PL, Burson JL. 1985. Biotransformation: A basic liver action upon exogenous chemicals. In: Industrial toxicology safety and health applications in the workplace. New York, NY: Van Nostrand Reinhold Company, 83–88.
Wolfe GW, Pepperl SG. 2005. Hexachlorobenzene: Reproductive assessment by continuous breeding when administered to Sprague-Dawley rats by oral gavage. Gaithersburg, MD: TherImmune Research Corporation.
Woods JS, Armel SE, Fulton DI, . 2010. Urinary porphyrin excretion in neurotypical and autistic children. Environ Health Perspect 118(10):1450–1457.20576582
Wu C, Luo Y, Gui T, . 2014. Concentrations and potential health hazards of organochlorine pesticides in (shallow) groundwater of Taihu Lake region, China. Sci Total Environ 470–471:1047–1055.
Wu H, Bertrand KA, Choi AL, . 2013. Persistent organic pollutants and type 2 diabetes: A prospective analysis in the Nurses’ Health Study and meta-analysis. Environ Health Perspect 121(2):153–161.23131992
Yalkowsky SH. 1992. Aquasol database of aqueous solubility. 5th edition. Tucson, AR: University of Arizona, College of Pharmacy.
Yamaguchi Y, Kawano M, Tatsukawa R. 1986. Tissue distribution and excretion of hexabromobenzene (HBB) and hexachlorobenzene (HCB) administered to rats. Chemosphere 15(4):453–459.
Yamashita N, Tanabe S, Ludwig JP, . 1992. Embryonic abnormalities and organochlorine contamination in double crested Cormorants (Phalacrocorax auritus) and Caspian terns (Hydroprogne caspia) from the upper Great Lakes in 1988. Environ Pollut 79(2):163–173.
Yang RSH, Pittman KA, Rourke DR, . 1978. Pharmacokinetics and metabolism of hexachlorobenzene in the rat and the Rhesus monkey. J Agric Food Chem 26:1076–1083.100539
Yasuhara A, Shiraishi H, Nishikawa M, . 1999. Organic components in leachates from hazardous waste disposal sites. Waste Manage Res 17:186–197.
Yesair DW, Feder PI, Chin AE, . 1986. Development, evaluation and use of a pharmocokinetic model for hexachlorobenzene. IARC Sci Publ 77:297–318.
Yess NJ, Gunderson EL, Roy RR. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J AOAC Int 76:492–507.8318840
Youn S, Jin S, Kim S, . 2010. Porphyrinuria in Korean children with autism: Correlation with oxidative stress. J Toxicol Environ Health A 73:701–710.20391113
Yu B, Zeng J, Gong L, . 2007. Investigation of the photocatalytic degradation of organochlorine pesticides on a nano-TiO2 coated film. Talanta 72(5):1667–1674.19071814
Yuan GL, Qin JX, Li J, . 2014. Persistent organic pollutants in soil near the Changwengluozha glacier of the Central Tibetan Plateau, China: Their sorption to clays and implication. Sci Total Environ 472:309–315.24295748
Yuan SY, Su CJ, Chang BV. 1999. Microbial dechlorination of hexachlorobenzene in anaerobic sewage sludge. Chemosphere 38(5):1015–1023.
Zabik ME, Schemmel R. 1980. Influence of diet on hexachlorobenzene accumulation in Osborne Mendel rats. J Environ Pathol Toxicol 4:97–103.
Zabik ME, Zabik MJ, Booren AM, . 1995. Pesticides and total polychlorinated biphenyls in Chinook salmon and carp harvested from the Great Lakes effects of skin on and skin off processing and selected cooking methods. J Agric Food Chem 43(4):993–1001.
Zhang L, Huang Y, Dong L, . 2011. Levels, seasonal patterns, and potential sources of organochlorine pesticides in the urban atmosphere of Beijing, China. Arch Environ Contam Toxicol 61(2):159–165.20953782
Zhang L, Zhang T, Dong L, . 2013. Assessment of halogenated POPs and PAHs in three cities in the Yangtze River Delta using high-volume samplers. Sci Total Environ 454–455:619–626.
Zheng T, Holford TR, Mayne ST, . 1999. Environmental exposure to hexachlorobenzene (HCB) and risk of female breast cancer in Connecticut. Cancer Epidemiol Biomarkers Prev 8:407–411.10350435
Zhong G, Tang J, Zhao Z, . 2011. Organochlorine pesticides in sediments of Laizhou Bay and its adjacent rivers, North China. Mar Pollut Bull 62(11):2543–2547.21924439
Zhou J, Zeng X, Zheng K, . 2012. Musks and organochlorine pesticides in breast milk from Shanghai, China: Levels, temporal trends and exposure assessment. Ecotoxicol Environ Saf 84:325–333.22921253
Zhou P, Wu Y, Yin S, . 2011. National survey of the levels of persistent organochlorine pesticides in the breast milk of mothers in China. Environ Pollut 159(2):524–531.21093969
Zhou Q, Wang J, Meng B, . 2013. Distribution and sources of organochlorine pesticides in agricultural soils from central China. Ecotoxicol Environ Saf 93:163–170.23680394
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zietz BP, Hoopmann M, Funcke M, . 2008. Long-term biomonitoring of polychlorinated biphenyls and organochlorine pesticides in human milk from mothers living in northern Germany. Int J Hyg Environ Health 211(5–6):624–638.18550430