# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

ATSDR has derived an acute-duration oral MRL of 8x10^-3^ mg/kg/day based on a LOAEL of 2.5 mg/kg/day for hyperactivity in rat offspring whose mothers were exposed to hexachlorobenzene for 4 days prior to mating (Goldey and Taylor 1992).

ATSDR has derived an intermediate-duration oral MRL of 1x10^-4^ mg/kg/day based on degenerative changes in the ovaries of female monkeys exposed to hexachlorobenzene doses ≥0.01 mg/kg/day for 90 days (Babineau et al. 1991; Bourque et al. 1995; Jarrell et al. 1993).

ATSDR has derived a chronic-duration oral MRL of 7x10^-5^ mg/kg/day based on a LOAEL of 0.022 mg/kg/day for peribiliary lymphocytosis and fibrosis of the liver in adult F_1_ generation male rats fed hexachlorobenzene for 130 weeks in a 2-generation study (Arnold et al. 1985).

The EPA (IRIS 2003) has derived an oral reference dose (RfD) of 8x10^-4^ mg/kg/day for hexachlorobenzene based on a NOAEL of 0.08 mg/kg/day for liver effects in the Arnold et al. (1985) rat chronic feeding study. An uncertainty factor of 100 was used (10 for intraspecies variability and 10 for interspecies extrapolation). No reference concentration (RfC) for chronic inhalation exposures to hexachlorobenzene was reported.

The International Agency for Research on Cancer (IARC) classifies hexachlorobenzene as Group 2B carcinogen (possibly carcinogenic to humans) (IARC 2015). The National Toxicology Program (NTP) concluded that hexachlorobenzene is reasonably anticipated to be a human carcinogen (NTP 2014). EPA has classified hexachlorobenzene in weight-of-evidence Group B2 (probable human carcinogen) (IRIS 2003). EPA derived an oral slope factor of 1.6 per (mg/kg)/day and an inhalation unit risk of 4.6x10^-4^ per (μg/m^3^) based on hepatocellular carcinoma in female Sprague-Dawley rats exposed orally. The American Conference of Governmental Industrial Hygienists (ACGIH) has classified hexachlorobenzene as an A3 carcinogen (confirmed animal carcinogen with unknown relevance to humans) (ACGIH 2014).

Although no Occupational Safety and Health Administration (OSHA) standards exist for hexachlorobenzene, the ACGIH (2014) has set a threshold limit value (8-hour time-weighted average) of 0.002 mg/m^3^, based on a route-to-route extrapolation from an oral study in Rhesus monkeys (Rozman et al. 1978).

Hexachlorobenzene is on the list of chemicals designated Hazardous Air Pollutants (HAPs) under Section 112 of the Clean Air Act (EPA 2013a). Hexachlorobenzene also appears on the list of chemicals in “The Emergency Planning and Community Right-to-Know Act of 1986” (EPCRA) and has been assigned a reportable quantity (RQ) limit of 10 pounds (EPA 2014d). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media.

The international and national regulations, advisories, and guidelines regarding hexachlorobenzene in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Hexachlorobenzene

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | 2B^a^ | IARC 2015
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | No guideline value^b^ | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 0.002 mg/m^3c^ | ACGIH 2014
AIHA | ERPGs | No data | AIHA 2014
DOE | PAC-1^d^ | 0.006 mg/m^3^ | DOE 2012a
DOE | PAC-2^d^ | 8.9 mg/m^3^
DOE | PAC-3^d^ | 160 mg/m^3^
EPA | AEGLs | No data | EPA 2014a
EPA | Hazardous air pollutant | Yes | EPA 2013a; 42 USC 7412
EPA | NAAQS | No data | EPA 2012c
NIOSH | REL (10-hour TWA) | No data | NIOSH 2015
NIOSH | IDLH | No data
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013; 29 CFR 1910.1000, Table Z-1
b. Water
EPA | Designated as hazardous substances in accordance with Section 311 (b)(2)(A) of the Clean Water Act | No data | EPA 2013b; 40 CFR 116.4
EPA | Drinking water standards and health advisories | | EPA 2012b
EPA | 1-day health advisory for a 10-kg child | 0.05 mg/L
EPA | 10-day health advisory for a 10-kg child | 0.05 mg/L
EPA | DWEL | 0.03 mg/L
EPA | 10^−4^ Cancer risk | 0.002 mg/L
EPA | National primary drinking water standards | No data | EPA 2009b
EPA | MCL | 0.001 mg/L
EPA | Potential health effects from long-term exposure above the MCL | Liver or kidney problems; reproductive difficulties; increased risk of cancer
EPA | Common sources of contaminant in drinking water | Discharge from metal refineries and agricultural chemical factories
EPA | Public Health Goal | Zero
EPA | National recommended water quality criteria: human health for the consumption of | | EPA 2013c
EPA | Water plus organism | 0.28 mg/L^e,f^
EPA | Organism only | 0.29 mg/L^e,f^
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2013d; 40 CFR 117.3
c. Food
FDA | EAFUS | No data^g^ | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | A3^h^ | ACGIH 2014
EPA | Carcinogenicity classification | B2^i^ | IRIS 2003
EPA | RfC | No data
EPA | RfD | 8×10^−4^ mg/kg/day
EPA | Inhalation unit risk | 4.6×10^−4^ per μg/m^3^
EPA | Oral slope factor | 1.6 per mg/kg/day
EPA | Identification and listing of hazardous waste | U127 | EPA 2013e; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products | No data | EPA 2014c
EPA | Superfund, emergency planning, and community right-to-know | | EPA 2014d; 40 CFR 302.4
EPA | Designated CERCLA hazardous substance and reportable quantity | 10 pounds^j^
EPA | Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2014e; 40 CFR 372.65
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2013f; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2014f; 40 CFR 712.30
EPA | TSCA health and safety data reporting | No data | EPA 2014g; 40 CFR 716.120
NTP | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2014

a Group 2B: possibly carcinogenic to humans.

b The WHO noted that when hexachlorobenzene is detected in drinking water, it occurs at concentrations well below those at which toxic effects might be expected, and considered it unnecessary to establish a guideline value. PAC-1: mild, transient health effects. PAC-2: irreversible or other serious health effects that could impair the ability to take protective action. PAC-3: life-threatening health effects.

c Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2012b).

e This criterion based on carcinogenicity of 10~^6^ risk and has been revised to reflect the EPA’s q1 * or RfD, as contained in IRIS as of May 17, 2002. The fish tissue bioconcentration factor (BCF) from the 1980 Ambient Water Quality Criteria document was retained in each case.

f EPA has updated its national recommended water quality criteria for human health. The comment period for the draft water quality criteria ended August 13, 2014. A final update has not been issued yet, but the proposed criteria for hexachlorobenzene is 0.0064 mg/L for water + organism and 0.0064 mg/L for organism only (EPA 2014b).

g The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

h A3: confirmed animal carcinogen with unknown relevance to humans

i B2: probable human carcinogen

j Designated CERCLA hazardous substance pursuant to Section 307(a)of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization