# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Hexachlorobenzene is a fully chlorinated hydrocarbon industrial chemical. Although hexachlorobenzene is not currently manufactured as a commercial end product in the United States, it is formed as a waste product in the production of several chlorinated hydrocarbons such as tetrachloroethylene and trichloroethylene, and is a contaminant in some pesticides such as pentachloronitrobenzene and pentachlorophenol. Its presence in the environment is also due to its previous use as a fungicide. Hexachlorobenzene is a very persistent environmental chemical due to its chemical stability and resistance to biodegradation. Information regarding the chemical identity of hexachlorobenzene is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Hexachloro¬benzene is a white, crystalline solid (Verschueren 2001) that is practically insoluble in water (Haynes and Lide 2010). When heated to decomposition, hexachlorobenzene emits highly toxic fumes of hydrochloric acid, other chlorinated compounds, carbon monoxide, and carbon dioxide (NTP 2014). Dimethyl formamide and hexachloro¬benzene react violently above 65 °C (HSBD 2012). Information regarding the physical and chemical properties of hexachloro¬benzene is located in Table 4-2.

Table 4-1 Chemical Identity of Hexachlorobenzene

Characteristics | Information^a^
Chemical name | Hexachlorobenzene^b^
Synonyms | Perchlorobenzene^b^; HCB^c^; pentachlorophenyl chloride
Trade names | AntiCarie; Ceku C. B.; No Bunt^c^
Chemical formula | C_6_Cl_6_^b^
Chemical structure | [image]
Identification numbers:
CAS Registry | 118-74-1^c^
NIOSH RTECs | DA2975000
EPA Hazardous Waste | U127^d^
OHM/TADS | 8100010
DOT/UN/NA/IMDG shipping | UN2729
HSDB | 1724^e^
NCI | No data

a All information obtained from HSDB 2012, except where noted

b O’Neil et al. 2006

c Farm Chemicals Handbook 2001

d EPA 1999

e HSDB 2012

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Hexachlorobenzene

Property | Information | Reference
Molecular weight | 284.78 | O’Neil et al. 2006
Color | White | Verschueren 2001
Physical state | Crystalline solid | Verschueren 2001
Melting point | 231 °C | O’Neil et al. 2006
Boiling point | 325 °C | Haynes and Lide 2010
Boiling point | 323–326 °C | O’Neil et al. 2006
Density
at 23 °C | 2.044 | O’Neil et al. 2006
Odor | No data
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 25 °C | 0.0062 mg/L | Farmer et al. 1976
Water at 25 °C | 0.0047 mg/L
Water at 20 °C | 0.006 mg/L | Yalkowsky 1992
Organic solvents | Insoluble in water, slightly soluble in ethanol, soluble in diethyl ether and chloroform, and very soluble in benzene | Verschueren 2001; Haynes and Lide 2010
Partition coefficients:
Log octanol/water | 5.73 | Hansch et al. 1995
Log K_oc_ | 6.08 | EPA 1981
Log K_oc_ | 5.22 | Kenaga and Goring 1978
Log K_oc_ | 3.59
Vapor pressure at 20 °C | 1.09x10^-5^ mmHg | O’Neil et al. 2006
Henry’s law constant | 5.8x10^-4^ atm-m^3^/mol | ten Hulscher et al. 1992
Hydroxyl radical constant at 25 °C | 2.7x10^-14^ cm^3^/molecule-second | Brubaker and Hites 1998
Autoignition temperature | No data
Flashpoint | 242 °C | O’Neil et al. 2006
Flammability limits | No data
Conversion factors | 1 ppm = 11.8 mg/m^3^ | Verschueren 2001
Conversion factors | 1 mg/m^3^ = 0.08 ppm
Explosive limits | No data