# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Hexachlorobenzene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobenzene
CAS Numbers: | 118-74-1
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 31
Species: | Rat

[underlined: Minimal Risk Level]: 0.008 [X] mg/kg/day [ ] ppm (LOAEL = 2.5 mg/kg/day; total uncertainty factors = 300)

[underlined: Reference]: Goldey ES, Taylor DH. 1992. Developmental neurotoxicity following premating maternal exposure to hexachlorobenzene in rats. Neurotoxicol Teratol 14:15–21.1593975

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): Groups of 30 virgin female Sprague-Dawley rats were dosed by gastric intubation for 4 days with 0, 2.5, or 25 mg/kg/day hexachlorobenzene to achieve a total dose of 0, 10, or 100 mg/kg for the 4-day period. Dosing was completed 2 weeks before breeding. The developmental neurotoxicity of hexachlorobenzene was assessed using a battery of behavioral tests. Negative geotaxic response was assessed in two male and two female pups from each litter on postnatal day (PND) 6, 8, and 10. Olfactory discrimination/homing was assessed in two male and two female pups from each litter on PND 9, 10, and 11. This test simultaneously measures sensory discrimination, motivation, and locomotor ability. The development of exploration and locomotion was assessed in whole litters between PND 15 and 20. Acoustic startle response (ASR) was assessed on PND 23 and 90. Visual discrimination learning, as measured in the water-filled T-maze, was assessed in offspring on PND 40. Motor activity in mature offspring (PND 60) was measured in an open area. These adult animals were again tested for exploratory activity on PND 100.

[underlined: Effect noted in study and corresponding doses]: Hexachlorobenzene affected multiple pathways throughout the developing nervous system, manifested as slight hyperactivity, at a LOAEL of 2.5 mg/kg/day. The offspring rats showed faster response times in negative geotaxis and olfactory discrimination/homing tests at the 2.5 or 25 mg/kg/day maternal dose level. Offspring exposed to maternal doses of 2.5 or 25 mg/kg/day showed either significantly increased exploratory behavior, slight hyperactivity, or both during the early life (19–20 days of age). Hexachlorobenzene-exposed offspring at the 25 mg/kg/day dose level exhibited significantly decreased ASR (23-day-old pups). When rats were tested later as adults (90 days old), response amplitude was significantly elevated in males in both groups exposed in utero to 2.5 and 25 mg/kg/day, compared to controls. Maternal exposure of rats to hexachlorobenzene did not result in any significant changes in learning ability, locomotor activity (60-day-old offspring), or exploratory activity (100-day-old offspring).

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

2.5 mg/kg/day; hyperactivity in offspring.

The data for mean exploratory activity (on a per litter basis) on postnatal days 19 and 20 were fit to available continuous models in the EPA Benchmark Dose Software (Version 2.1.2); however, the models did not provide adequate fit to the data. Therefore, a NOAEL/LOAEL approach was employed to identify a point of departure (POD) for deriving an acute-duration oral MRL for hexachlorobenzene.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 1 [X] 3 [ ] 10 for use of a LOAEL
- [ ] 1 [ ] 3 [X] 10 for extrapolation from animals to humans
- [ ] 1 [ ] 3 [X] 10 for human variability
- Total uncertainty factors: 3 × 10 × 10 = 300

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Review of the located human and animal oral acute toxicity data for hexachlorobenzene indicate that the 4-day developmental study by Goldey and Taylor (1992) provides the most appropriate data for use deriving oral acute MRL for hexachlorobenzene. The LOAEL of 2.5 mg/kg/day is the most refined LOAEL for the acute toxicity of hexachlorobenzene.

Adverse neurological signs and symptoms have also been observed in human offspring of maternally exposed to hexachlorobenzene. Children of mothers who had eaten hexachlorobenzene-contaminated bread (estimated hexachlorobenzene intake of 0.05–0.2 g/day) in Turkey exhibited muscle weakness, pinched facies, cogwheel rigidity, and sensory shading. Hexachlorobenzene was detected in the breast milk of the mothers, indicating lactational transfer (Cam and Nigogosyan 1963; Peters et al. 1982, 1987). Since hexachlorobenzene crosses the placenta and accumulates in fetal tissues in several animal species including the rat (Cripps 1990; Villeneuve and Hierlihy 1975), rabbit (Villeneuve et al. 1974a), and mouse (Courtney and Andrews 1985; Courtney et al. 1979), it is likely that the human offspring were also exposed to hexachlorobenzene during gestation. Development of neurotoxic signs has also been reported in other neonatal animals. These signs included convulsions, tremors, and progressive weakness in rats (Cripps 1990). Oral hexachlorobenzene has also been shown to interfere with the function of the nervous system in adult animals, inducing tremors, ataxia, and paralysis in unspecified strain of rats (Ockner and Schmid 1961); clonic convulsions, tremors, hyper-excitability, reversible muscle fasciculations, and lethargy in adult Wistar rats (Kennedy and Wigfield 1990; Koss et al. 1978; Nikolaev et al. 1986); mild reduction in conduction velocity of sciatic nerve, denervation, fibrillations, and chronic repetitive discharges in adult Sprague-Dawley rats (Sufit et al. 1986); tremor and hyperexcitability in adult Sherman rats (Kimbrough and Linder 1974); dysrhythmic electroencephalogram in adult Beagle dogs (Sundlof et al. 1981); tremor in adult C57B1/6J mice (Hahn et al. 1988); severe tremors and muscular weakness in adult Rhesus monkeys (Knauf and Hobson 1979); and tremors, panting, and unsteady gait in adult SPF pigs (Den Tonkelaar et al. 1978).

[underlined: Agency Contact (Chemical Manager)]: Robert Williams

## Hexachlorobenzene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobenzene
CAS Numbers: | 118-74-1
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 165
Species: | Monkey

[underlined: Minimal Risk Level]: 0.0001 [X] mg/kg/day [ ] ppm (LOAEL = 0.01 mg/kg/day; total uncertainty factors = 90)

[underlined: References]: Bourque AC, Singh A, Lakhanpal N, . 1995. Ultrastructural changes in ovarian follicles of monkeys administered hexachlorobenzene. Am J Vet Res 56: 1673–1677.8599532

Jarrell JF, MacMahon A, Villeneuve D, . 1993. Hexachlorobenzene toxicity in the monkey primordial germ cell without induced porphyria. Reproductive Toxicology 7:41–47.8448415

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): In the Jarrell et al. (1993) study, groups of four female Cynomolgus monkeys were administered 0, 0.1, 1, or 10 mg/kg/day hexachlorobenzene in gelatin capsules for 90 days. No systemic toxicity was noted in any of the animals. After treatment, the animals were sacrificed and one ovary was removed from each animal from each dose group (including controls) and examined by transmission electron microscopy for alterations to surface epithelium. A cycle of in vitro fertilization with oocytes removed from exposed females during the menstrual cycle was performed to evaluate fertility. Induction of ovarian hyperstimulation (performed with human menopausal gonadotropin) was conducted to evaluate oocyte function. In the follow-up Bourque et al. (1995) study, groups of four female Cynomolgus monkeys were administered 0, 0.01, 0.1, 1, or 10 mg/kg/day hexachlorobenzene in gelatin capsules for 90 days. Monkeys were then given a preparation containing follicle-stimulating and luteinizing hormones on days 2–7 of the next menstrual cycle to stimulate follicle development, and human chorionic gonadotropin was administered on day 8 of the cycle. Oophorectomy was performed on day 10 of the cycle via laparotomy. The ovary was examined by transmission electron microscopy.

[underlined: Effect noted in study and corresponding doses]: In the Jarrell et al. (1993) study, in vitro fertilization and ovarian hyperstimulation in terms of percent fertilization, estradiol response to gonadotropin, follicular development, oocyte recovery rates and maturation, and early embryo development were not significantly different from control animals. Hexachlorobenzene treatment caused a decrease in the total number of oocytes and primordial follicles. Ultrastructural changes in ovarian epithelium included a decrease in nuclear membrane distinction, an increase in density and granularity of oocyte nuclei, an increase in vacuoles, aggregated lysosomes in ooplasm of follicular cells, and pyknotic granulosa cells. The ooplasm of some follicles was necrotic, and some follicles had mild to moderate degenerative changes. These changes were observed in all exposed animals; the severity of symptoms increased in a dose-dependent manner. The follow-up study by Bourque et al. (1995) extended the observation of ultrastructural effects in the ovary to 0.01 mg/kg/day. At this dose, mitochondria in developing follicles were condensed and deformed. At higher doses, the mitochondria were progressively more damaged and additional changes, such as indentation of nuclear membranes and abnormal accumulation of lipid in the cytoplasm of follicular cells, were noted.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

0.01 mg/kg/day; degenerative lesions in ovarian follicles.

Benchmark dose analysis was not attempted because the principal study (Bourque et al. 1995) did not include quantitative data (incidence, severity) for the critical effect of hexachlorobenzene-induced ultrastructural changes in developing follicles. The intermediate-duration oral MRL for hexachlorobenzene is based on the identified LOAEL of 0.01 mg/kg/day for mitochondrial changes in developing follicles.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 1 [X] 3 [ ] 10 for use of a LOAEL
- [ ] 1 [X] 3 [ ] 10 for extrapolation from animals to humans
- [ ] 1 [ ] 3 [X] 10 for human variability
- Total uncertainty factors: 3 × 3 × 10 = 90

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Review of the located human and animal oral intermediate toxicity data for hexachlorobenzene indicate that the 90-day studies by Bourque et al. (1995) and Jarrell et al. (1993) provide the most appropriate data for use in deriving an oral intermediate MRL for hexachlorobenzene.

In humans, 15 fetal deaths (comprising 13 miscarriages and 2 stillbirths) and 173 live births occurred in 42 females in a 4-year period (1977–1981) several years after the widespread accidental ingestion of hexachlorobenzene-treated seed grain in Turkey (Peters et al. 1982, 1987). These mothers also had 0.51 ppm hexachlorobenzene in their breast milk as compared to 0.07 ppm in unexposed controls (Gocmen et al. 1989). It has also been demonstrated that hexachlorobenzene in human milk can readily cross to the child during lactation and accumulate in the offspring (Ando et al. 1985; Weisenberg 1986; Weisenberg et al. 1985).

Animal studies provide additional evidence that hexachlorobenzene is toxic to the mammalian ovary and may interfere with mechanisms regulating ovarian steroidogenesis. Female Cynomolgus monkeys exhibited a dose-dependent decrease in serum progesterone levels during the luteal phase of the menstrual cycle when administered hexachlorobenzene doses of ≥0.1 (0.1, 1, 10) mg/kg/day as capsules for 90 days; the decrease in levels of progesterone was not observed during the follicular and periovulatory phases. Lengthening of the menstrual cycle was also observed, as well as dose-dependent ultrastructural changes in surface epithelium of the ovary (indicative of cellular degeneration) and changes in ovary surface epithelial cell shape (length to width ratio), in all treatment groups, the severity of which was increased in a dose-dependent manner (Foster et al. 1992a; Sims et al. 1991). Increased serum progesterone levels and elevated ovarian weights were observed in superovulated female Sprague-Dawley rats orally administered ≥1 mg/kg/day hexachlorobenzene by gavage (in corn oil) for 21 days (Foster et al. 1992b). Serum levels of estradiol and progesterone of female Sprague-Dawley rats receiving daily doses of 50 mg/kg/day hexachlorobenzene by gavage in corn oil for 5 days were not significantly affected, although super-ovulated rats (dosed with pregnant mare serum gonadotropin and human chorionic gonadotropin) exposed to hexachlorobenzene in this study exhibited significant elevation of serum levels of progesterone (Foster et al. 1993). In a subsequent study with ovariectomized female Sprague-Dawley rats administered daily oral doses of 1, 10, or 100 mg/kg/day hexachlorobenzene in corn oil by gavage for 30 days, circulating levels of corticosterone levels were reduced by 25 and 51% at the 1 and 10 mg/kg/day hexachlorobenzene dose levels, respectively. Circulating cortisol levels were also significantly reduced (p<0.05). Hexachlorobenzene treatment had no effect on the levels of circulating aldosterone and progesterone levels, or on absolute and relative weights of the adrenal glands. The investigators concluded that hexachlorobenzene exposure induces alterations in steroidogenesis of cells of the adrenal cortex inner zone (Foster et al. 1995b).

A study conducted with female Rhesus monkeys given gavage doses of 8, 32, 64, or 128 mg/kg/day hexachlorobenzene in methylcellulose for 60 days found degenerative changes of the ovarian follicle, stroma, and germinal epithelium at dose levels of 64 mg/kg/day (Iatropoulos et al. 1976). In another monkey study, adult female Rhesus monkeys given oral doses of 8, 16, 32, 64, or 128 mg/kg/day hexachlorobenzene for 60 days showed significantly depressed (29%, p<0.01) whole serum cholesterol levels in weeks 3, 5, and 8. On day 60, depressed serum potassium and elevated SGOT were seen at the 128 mg/kg/day dose level. The authors suggested that the changes in potassium and cholesterol levels may be due to liver histopathology. The authors suggested that the changes in potassium levels may be due to unusual steroidogenic activity associated with changes in ovarian morphology (Knauf and Hobson 1979).

[underlined: Agency Contact (Chemical Manager)]: Robert Williams

## Hexachlorobenzene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hexachlorobenzene
CAS Numbers: | 118-74-1
Date: | June 2015
Profile Status: | Final, Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 196
Species: | Rat

[underlined: Minimal Risk Level]: 0.00007 [X] mg/kg/day [ ] ppm (LOAEL = 0.022 mg/kg/day; total uncertainty factors = 300)

[underlined: Reference]: Arnold DL, Moodie CA, Charbonneau SM, Grice HC, . 1985. Long-term toxicity of hexachlorobenzene in the rat and the effect of dietary vitamin A. Food Chem Toxicol 23(9): 779–793.4043882

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): Groups of Sprague-Dawley rats (50 per sex) of the F_1_ generation were exposed to dietary hexachlorobenzene at 0, 0.32, 1.6, 8, or 40 ppm (approximate doses of 0, 0.022, 0.11, 0.55, and 2.8 mg/kg/day, respectively, for the F_1_ males and 0, 0.026, 0.13, 0.64, and 3.2 mg/kg/day, respectively, for the F_1_ females) from weaning for life (130 weeks). The groups of F_1_ rats had also been exposed via their mothers during gestation and lactation. The F_1_ rats in this study were sacrificed after the animals had been on test for 130 weeks. A total of 35 tissues and organs (including brain, heart, liver, extrahepatic bile duct, lungs, spleen, pancreas, small intestine, adrenals, kidneys, bladder, ovaries, uterus, skin, pituitary, thyroid, parathyroid, thymus, prostate, testes, and bone) were histopathologically examined.

[underlined: Effect noted in study and corresponding doses]: Significant dose-response trends were observed in both sexes for hepatic basophilic chromogenesis at >0.55 mg/kg/day, and in males for peribiliary lymphocytosis and fibrosis at or greater than the lowest dose tested (0.022 mg/kg/day). Chronic nephrosis, severe in males, and reduced pup viability were observed at the high dose (2.8 mg/kg/day for males and 3.2 mg/kg/day for females). Tumors were also increased at the high dose, including neoplastic liver nodules in females, parathyroid adenoma in males, and adrenal pheochromocytoma in both males and females. No treatment related effects in the rat offspring were observed with respect to feed consumption or body weight.

For derivation of the MRL, the increased incidences of peribiliary lymphocytosis and fibrosis in treated males were considered to represent a minimal effect. These are common spontaneous lesions in aging rats and occurred in approximately 30% of controls in this study. For peribiliary fibrosis, incidence was increased in all treated groups (statistically significant in the 0.022 and 2.8 mg/kg/day groups), but there was no clear evidence of a dose-response (13/48, 23/48, 21/48, 21/49, and 23/49 in the control, 0.022, 0.11, 0.55, and 2.8 mg/kg/day groups, respectively). For peribiliary lymphocytosis, the incidence was increased in all treated groups (statistically significant in the 0.022, 0.11, and 2.8 mg/kg/day groups), and while the trend with dose was not very impressive, it was statistically significant (16/48, 27/48, 26/48, 21/49, and 32/49, respectively). Incidences of these lesions in the control and treated females were similar to the control males (ranging from 6/49 to 14/49), suggesting that the incidence levels in control males were not unusually low. Overall, these findings suggest that hexachlorobenzene produced a minimal hepatic effect in male rats at the lowest doses administered by increasing the incidence of age-related hepatic lesions.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [X] LOAEL

0.022 mg/kg/day; peribiliary lymphocytosis and fibrosis of the liver.

The incidence data for peribiliary lymphocytosis and peribiliary fibrosis in the F_1_ male rats were fit to available dichotomous models in the EPA Benchmark Dose Software (Version 2.1.2); however, the models did not provide adequate fit to the data. Therefore, a NOAEL/LOAEL approach was employed to identify a POD (LOAEL of 0.022 mg/kg/day) for deriving a chronic-duration oral MRL for hexachlorobenzene.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 1 [X] 3 [ ] 10 for use of a LOAEL
- [ ] 1 [ ] 3 [X] 10 for extrapolation from animals to humans
- [ ] 1 [ ] 3 [X] 10 for human variability
- Total uncertainty factors: 3 × 10 × 10 = 300

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Yes. U.S. EPA (1988) chronic reference body weight (male: 0.523 kg; female: 0.338 kg) and food consumption (male: 0.036 kg/day; female 0.027 kg/day) for Sprague-Dawley rats were used to calculate hexachlorobenzene dose from concentration in food. Sample calculation for males: (0.32 mg hexachlorobenzene/kg food [0.32 ppm] × 0.036 kg food consumed/day) / 0.523 kg body weight = 0.022 mg hexachlorobenzene/kg/day.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The liver appears to be a target organ of hexachlorobenzene; therefore, using hepatic effects (peribiliary lymphocytosis and fibrosis) to calculate the MRL is appropriate. Also, review of the located human and animal oral chronic toxicity data for hexachlorobenzene indicate that the 130-week rat study by Arnold et al. (1985) provide the most appropriate data to derive a chronic MRL because the study provides the most refined LOAEL for the characteristic chronic toxicity (hepatic effects) of hexachlorobenzene.

Other studies in several animal species have demonstrated that the liver is the major target organ of hexachlorobenzene exposure. Typical signs included microscopic lesions, increased porphyrin levels, and interference with hepatic enzymes involved in the heme biosynthesis pathway. Hexachlorobenzene doses as low as 5–51 mg/kg/day have been reported to produce porphyrinogenic effects, such as increased liver weight, inhibition of hepatic uroporphyrinogen decarboxylase, accumulation of porphyrins in liver, excretion of porphyrins in urine, and increased hepatic δ-aminolevulinic acid synthestase activity, in female rats exposed for intermediate durations (Alvarez et al. 2000; Den Besten et al. 1993; Goldstein et al. 1978; Kennedy and Wigfield 1990; Kuiper-Goodman et al. 1977; Michielsen et al. 2001, 2002; Smith et al. 1979, 1985; Sweeney et al. 1986; Wolfe and Pepperl 2005). In studies of chronic exposure duration, hexachlorobenzene doses of 7–18 mg/kg/day from the feed produced complete inhibition of uroporphyrinogen decarboxylase and high levels of porphyrins in the liver and urine in both male and female rats (Smith and Cabral 1980; Smith et al. 1985, 1993).

Uroporphyria and hepatic porphyrin accumulation were reported in a 13-week study in female Wistar rats receiving 9.5 or 19 mg/kg/day hexachlorobenzene from the feed. Rats in the 9.5 and 19 mg/kg/day dose group exhibited elevated d-ALA synthase levels (94 and 483%, respectively). At the low dose (9.5 mg/kg/day), relative liver weight increased by 31%, and at the highest dose tested (19 mg/kg/day), relative liver weight increased by 103%. Hypertrophic hepatocytes with eosinophilic cytoplasm with thready basophilic structures, as well as inflammatory cell infiltrates, were observed in the livers of animals dosed with 19 mg/kg/day hexachlorobenzene. By the end of the study, uroporphyria in the 19 mg/kg/day dose group was 1,400% that of control animals. Liver accumulations of porphyrins were 1,054 and 15,104%, respectively, for the 9.5 and 19 mg/kg/day dose group animals compared to undosed controls. Liver retinoid and plasma retinol were decreased by 70 and 53%, respectively, at the 19 mg/kg/day dose level (den Besten et al. 1993).

Female Sprague-Dawley rats exhibited elevated urinary and hepatic porphyrins following administration of 50 mg/kg/day hexachlorobenzene for 12 consecutive days (cumulative dose of 600 mg/kg), and 10 days (5 days/week for 2 weeks, cumulative dose of 500 mg/kg), or 100 mg/kg/day for 5 consecutive days (cumulative dose of 500 mg/kg). The porphyria seen was reported to be similar in severity to that observed in female rats receiving a cumulative dose of 1,500 mg/kg over a 6-week period. Porphyria induced by a cumulative dose of 500 mg/kg (either protocol) persisted for >500–600 days after exposure (Krishnan et al. 1991). Similarly, female Wistar rats receiving hexachlorobenzene from the diet at an estimated dose of 308 mg/kg/day for 107 days exhibited a 91% decrease in uroporphyrinogen decarboxylase activity and a 2,888-fold increase in hepatic porphyrin concentration (Elder and Urquhart 1986).

Oral exposure to hexachlorobenzene induced liver histopathology and altered liver histochemistry in rats. The relative liver weights of male rats were increased by 46% while those of females were increased by 23% in a study in which both sexes of Sprague-Dawley rats were given oral hexachlorobenzene doses of 27.5 mg/kg/day for 4 weeks (Richter et al. 1981). Cytoplasmic vacuolation, anisokaryosis, and pyknotic hepatocytes were seen in the liver of female Sprague-Dawley rats administered single gavage doses of 400 or 600 mg/kg hexachlorobenzene in corn oil and observed for 14 days. Relative liver weights were increased by 16–18 and 13–18% in the 400 and 600 mg/kg dose group animals, respectively. Serum cholesterol levels were increased by 13–30 and 7–31% in the 400 and 600 mg/kg dose group animals, respectively. No changes in serum sodium, potassium, inorganic phosphorus, total bilirubin, alkaline phosphatase, aspartate aminotransferase, total protein, calcium, glucose, and lactate dehydrogenase content were found. Liver microsomal aminopyrine demethylase, aniline hydroxylase, and EROD activities were unchanged by hexachlorobenzene exposure (Lecavalier et al. 1994). Liver weight was significantly increased by nearly 45% in animals treated with 1,000 mg/kg/day for 7 days. Liver porphyrin carboxylase activity was significantly decreased in animals receiving 1,000 mg/kg/day (Kleiman de Pisarev et al. 1990). In rats receiving hexachlorobenzene from the diet at an estimated dose level of 172 mg/kg/day for 60 days, treatment-related effects included enlarged, degenerative liver lesions and increased hepatic porphyrins (Ockner and Schmid 1961). Male Wistar (WAG/MBL) rats given oral doses of 1,000 mg/kg hexachlorobenzene, 3 times a week for 4 weeks (van Raaij et al. 1993b) exhibited 67% increased liver weight. Similarly, liver weight was increased by 81% in a group of Fischer 344 rats administered hexachlorobenzene by gavage at 10 mg/kg/day for 15 weeks (Andrews et al. 1989).

Oral exposure to hexachlorobenzene resulted in altered liver function and histology in: adult female Rhesus monkeys given oral doses of 8, 16, 32, 64, or 128 mg/kg/day hexachlorobenzene for 60 days (Knauf and Hobson 1979); female Wistar rats exposed to 50 mg/kg/day hexachlorobenzene by gavage for 15 weeks (Koss et al. 1978, 1983); female Agus Wistar rats receiving hexachlorobenzene at 7 mg/kg/day (with 2% arachis oil) from the diet for 90 weeks (Smith and Cabral 1980); female Wistar rats receiving 12.95 or 129 mg/kg hexachlorobenzene from the diet for 56 days (Kennedy and Wigfield 1990); both sexes of Charles River rats receiving hexachlorobenzene from the diet at doses of 0.5, 2, 8, or 32 mg/kg/day (Kuiper-Goodman et al. 1977); monkeys given doses of 8 mg/kg/day for 60 days (Iatropoulos et al. 1976); and adult female Beagle dogs administered ≥25 mg/kg/day hexachlorobenzene in gelatin capsules for 21 days (Sundlof et al. 1981). Induction of liver microsomal enzymes, increased liver weight, and microscopic lesions were demonstrated at a hexachlorobenzene dose of 5 mg/kg/day, while centrilobular hypertrophy, elevated urinary coproporphyrinogen, and depressed glucose-6-phosphatase activity were observed at a lower dose level (0.5 mg/kg/day) in pigs treated for 90 days (Den Tonkelaar et al. 1978).

Several animal studies also found increased induction of P-450 isozymes and other hepatic enzymes, usually accompanied by hepatic or uroporphyria, as an index of adverse effects in the liver (Adjarov et al. 1982; Hahn et al. 1988, 1989; Kitchin and Brown 1989; Kleiman de Pisarev et al. 1995; Li et al. 1989; Linko et al. 1986; Lissner et al. 1975; Mehendale et al. 1975; Rajamanickam and Padmanaban 1974; Smith et al. 1985; Wada et al. 1968).

[underlined: Agency Contact (Chemical Manager)]: Robert Williams