# VERSION HISTORY

Date | Description
March 2024 | Final toxicological profile released
January 2023 | Draft for public comment toxicological profile released
August 2005 | Final toxicological profile released
July 1999 | Final toxicological profile released
May 1994 | Final toxicological profile released
December 1989 | Final toxicological profile released