# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding HCH in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for HCH.

Table 7-1 Regulations and Guidelines Applicable to Hexachlorocyclohexane (HCH)

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 1987a, IRIS 1987b, IRIS 1987c, IRIS 1987d, IRIS 1987f
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | γ-HCH
EPA | 1-Day health advisory (10-kg child) | 1 mg/L
EPA | 10-Day health advisory (10-kg child) | 1 mg/L
EPA | DWEL | 0.2 mg/L
EPA | National primary drinking water regulations | | EPA 2009
EPA | γ-HCH
EPA | MCL and MCLG | 0.0002 mg/L
EPA | RfD
EPA | β-HCH | 0.00006 mg/kg/day | EPA 2006c
EPA | γ-HCH | 3×10^−4^ mg/kg/day | IRIS 1987c
WHO | Drinking water quality guidelines | | WHO 2022
WHO | γ-HCH
WHO | Guideline value | 0.002 mg/L
WHO | ADI | 0–0.005 mg/kg body weight
FDA | Substances added to food^a^ | Not listed | FDA 2023
FDA | Allowable level in bottled water | | FDA 2017
FDA | γ-HCH | 0.0002 mg/L
Cancer
HHS | Carcinogenicity classification | | NTP 2021
HHS | γ-HCH, technical HCH and other HCH isomers | Reasonably anticipated to be human carcinogens
EPA | Carcinogenicity classification
EPA | α-HCH | Group B2^b^ | IRIS 1987a
EPA | β-HCH | Group C^c^ | IRIS 1987b
EPA | γ-HCH | Suggestive evidence of carcinogenicity, but not sufficient to assess human carcinogenic potential | EPA 2002
EPA | δ-HCH | Group D^d^ | IRIS 1987d
EPA | Technical HCH | Group B2^b^ | IRIS 1987f
EPA | Inhalation unit risk
EPA | α-HCH | 1.8×10^−3^ per µg/m^3^ | IRIS 1987a
EPA | β-HCH | 5.3×10^−4^ per µg/m^3^ | IRIS 1987b
EPA | Technical HCH | 5.1×10^−4^ per µg/m^3^ | IRIS 1987f
EPA | Oral slope factor
EPA | α-HCH | 6.3 per mg/kg/day | IRIS 1987a
EPA | β-HCH | 1.8 per mg/kg/day | IRIS 1987b
EPA | Technical HCH | 1.8 per mg/kg/day | IRIS 1987f
IARC | Carcinogenicity classification
IARC | γ-HCH | Group 1^e^ | IARC 2018
IARC | HCH | Group 2B^f^ | IARC 1987
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | | OSHA 2021a, OSHA 2021b, OSHA 2021c
OSHA | γ-HCH | 0.5 mg/m^3^ ^g^ | OSHA 2021a, OSHA 2021b, OSHA 2021c
NIOSH | REL (up to 10-hour TWA) | | NIOSH 2019
NIOSH | γ-HCH | 0.5 mg/m^3^ ^g^
NIOSH | IDLH | | NIOSH 1994
NIOSH | γ-HCH | 50 mg/m^3^
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2016
DOE | γ-HCH
DOE | TEEL-1^h^ | 9.1 mg/m^3^
DOE | TEEL-2^h^ | 100 mg/m^3^
DOE | TEEL-3^h^ | 1,000 mg/m^3^

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group B2: probable human carcinogen.

c Group C: possible human carcinogen.

d Group D: not classifiable as to human carcinogenicity.

e Group 1: carcinogenic to humans.

f Group 2B: possibly carcinogenic to humans.

g Skin notation.

h Definitions of PAC terminology are available from DOE (2022).

ADI = acceptable daily intake; AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FAO = Food and Agriculture Organization; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TEEL = temporary emergency exposure limit; TWA = time-weighted average; WHO = World Health Organization