# CHAPTER 5 POTENTIAL FOR HUMAN EXPOSURE

## 5.1 OVERVIEW

HCH isomers have been identified in at least 312 of the 1,868 hazardous waste sites that have been proposed for inclusion on the EPA National Priorities List (NPL) (ATSDR 2022). However, the number of sites in which HCH isomers have been evaluated is not known. The number of sites in each state is shown in Figure 5-1. Of these sites, 308 are located within the United States, 1 is located in the Virgin Islands, 1 is in Guam, and 2 are in Puerto Rico (not shown).

Figure 5-1 Number of NPL Sites with Hexachlorocyclohexane Contamination

Figure 5-1 description

Source: ATSDR 2022

- Registrations of γ-HCH agricultural products have been cancelled since 2006, significantly reducing most consumer exposure routes. The primary route of exposure is through dermal contact from medicinal use. One percent γ-HCH shampoos or lotions are registered with the FDA and are used for prescription treatment of lice and scabies.
- Individuals who are at risk of higher exposures to γ-HCH include those who live near contaminated sites and anyone who improperly uses γ-HCH prescription medications.
- Historically, HCH has been released to the environment during its formulation process and through its use. HCH isomers are persistent and have been recently detected in air, water, and soil. The general public may be exposed to low levels of HCH through inhalation of contaminated ambient air, consumption of contaminated drinking water, or incidental ingestion of or dermal contact with contaminated soils. HCH has not been found to be a major contaminant of drinking water supplies.
- Once released to the environment, HCH can partition to all environmental media. HCH can exist in the vapor and particulate phase in the atmosphere. HCH can volatilize from soils but is not expected to volatilize significantly from water. HCH has low to moderate mobility in soils and may leach to groundwater. HCH has low to moderate potential to bioaccumulate and has been detected in aquatic organisms in the United States.
- HCH has a long atmospheric lifetime but can be removed by photodegradation with hydroxyl radicals or wet and dry deposition. Biodegradation is believed to be the dominant decomposition process for HCH in soil and water, although hydrolysis and photolysis may occur to a lesser extent. The rates of degradation depend on the ambient environmental conditions.

## 5.2 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

### 5.2.1 Production

Table 5-1 summarizes information on companies that reported the production, import, or use of γ-HCH for the Toxics Release Inventory (TRI) in 2021 (TRI21 2022). Most of the uses by these facilities are considered to be ancillary, indicating purposes other than chemical processing or manufacturing. Examples of ancillary uses as defined under TRI include cleaners, degreasers, lubricants, fuels, and waste treatment uses. TRI data should be used with caution since only certain types of industrial facilities are required to report. This is not an exhaustive list.

Table 5-1 Facilities that Produce, Process, or Use γ-Hexachlorocyclohexane

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AR | 1 | 1,000 | 9,999 | 9, 12
NE | 1 | 10,000 | 99,999 | 9, 12
OH | 2 | 1,000 | 99,999 | 12
TX | 2 | 1,000 | 99,999 | 9, 12
UT | 1 | 10,000 | 99,999 | 9, 12

a Post office state abbreviations used.

b Amounts on site reported by facilities in each state.

c Activities/Uses:

1. Produce
2. Import
3. Used Processing
4. Sale/Distribution
5. Byproduct
6. Reactant
7. Formulation Component
8. Article Component
9. Repackaging
10. Chemical Processing Aid
11. Manufacture Aid
12. Ancillary
13. Manufacture Impurity
14. Process Impurity

Source: TRI21 2022 (Data are from 2021)

HCH does not occur as a natural substance. The manufacturing of technical-grade HCH involves the photochlorination of benzene, which yields an isomeric mixture consisting of α-HCH, β-HCH, γ-HCH, δ-HCH, ε-HCH, and inerts (IARC 1979); this reaction can be started by free-radical initiators such as visual or ultraviolet light, X-rays, or γ-rays (Kirk and Othmer 1985). Treatment with methanol or acetic acid, followed by fractional crystallization, concentrates γ-HCH to the 99.9% required in the technical-grade of γ-HCH (IARC 1979); nitric acid is used to remove odor (NLM 2021). None of the isomers or technical-grade HCH are currently produced in the United States. The production of γ-HCH exceeded 2.27×10^6^ g in 1976 (NLM 2021); commercial γ-HCH production in the United States reportedly ended in that year (EPA 1989a).

γ-HCH was available in emulsifiable and flowable concentrates, soluble concentrates/liquids, wettable powders, dusts, ready-to-use liquids, pressurized liquids and impregnated materials, oil base and aerosol sprays, and granules, as well as a smoke generator (Berg 1988; EPA 1985a). γ-HCH was sold separately or in combination with fungicides, fertilizers, other insecticides, or wood preservatives (Hayes 1982).

### 5.2.2 Import/Export

Current data on the importation of γ-HCH were not located. Γ-HCH was not included in import/export information submitted by manufacturers under EPA’s Chemical Data Reporting (CDR) database in the 2020 (covering 2016–2019) reporting cycle (EPA 2022a). The reporting threshold was 2,500 pounds.

Γ-HCH historically was imported from France, Germany, Spain, Japan, and China (EPA 1985a). Currently, India is the only country where γ-HCH is reportedly produced; thus, India may be the current supplier to the United States (Vijgen et al. 2011). The U.S. imports of γ-HCH declined from 1.52×10^5^ kg in 1977 to 8.53×10^4^ kg in 1982 (NLM 2021). In 2002, it was estimated that 90 metric tons (9.0×10^4^ kg) of γ-HCH were imported into the United States (Hauzenberger et al. 2002). Up until 2001, it was estimated that 500 metric tons of γ-HCH-containing pesticide products were exported annually by the United States (primarily to Canada) (Hauzenberger et al. 2002). That export volume dropped to 25 metric tons in 2001 and continued to decline significantly as other countries and the United States ceased the usage of γ-HCH containing pesticides.

### 5.2.3 Use

γ-HCH was initially registered by the U.S. Department of Agriculture (USDA) in the 1940s and over the years, was approved for use on a wide variety of fruit and vegetable crops (including seed treatment), tobacco, greenhouse vegetables and ornamentals, forestry (including Christmas tree plantations), farm animal premises, and other uses. In February 1977, EPA issued a notice of Rebuttal Presumption Against Registration (RPAR), now called a Special Review, and continued registration of pesticide products containing γ-HCH. EPA took this action in response to indications of γ-HCH’s potential carcinogenic effect, possible developmental and reproductive effects, possible blood dyscrasias, and delayed toxic effects, as well as its acute toxic effects seen in aquatic wildlife (IARC 1979). In October of 1983, EPA issued a “Notice of Intent to Cancel Pesticide Products Containing γ-HCH.” The contentions concerning developmental and reproductive effects were successfully challenged by industry. EPA no longer permits the use of γ-HCH for purposes involving direct aerial application (EPA 1985b). The notice restricted certain applications of γ-HCH on livestock, structures, and domestic pets to certified applicators or persons under their direct supervision (EPA 1985b). In November 1993, EPA issued a “Notice of Receipt of a Request for Amendments to Delete Uses” for several formulations of γ-HCH powder, 99.5% technical-grade HCH, and dust concentrate, which would delete from the pesticide label most uses of γ-HCH for agricultural crops and use on animals and humans (EPA 1993). According to the EPA’s last Registration Eligibility Decision (RED), the last approved food/feed use of γ-HCH that was supported for re-registration was seed treatment on barley, corn, oats, rye, sorghum, and wheat (EPA 2002). Since the 1998 and 1999 use deletions, the registrants were no longer interested in supporting the seed treatment use on broccoli, Brussel sprouts, celery, cabbage, cauliflower, collards, kale, kohlrabi, mustard greens, lettuce, radishes, spinach, or Swiss Chard (EPA 2002). Based on EPA estimates from 1996 to 2001, about 233,000 pounds of γ-HCH were used annually as a seed treatment (EPA 2002). In August 2006, EPA issued “Notice of Receipt of Requests to Voluntarily Cancel Lindane Pesticide Registrations,” which would end the use of γ-HCH as seed treatments, and notice of final orders of cancellation was issued in December of 2006 (EPA 2006a, 2006b).

γ-HCH is available and regulated by the FDA, for the pharmaceutical treatment of scabies and head lice (EPA 2002). A 1% γ-HCH lotion is available for the treatment of scabies, and a 1% shampoo is available for the treatment of head lice; both are prescription use only. Both uses have been on the market since 1947, but they were labeled as a second line therapy in 1995 after a review by the FDA. The FDA has issued revised labels for 1% γ-HCH lotion and 1% γ-HCH shampoo to be used with caution for infants, children, and the elderly or anyone who weighs <110 pounds (50 kg), and people with other skin conditions (FDA 2015). The products are contraindicated in premature infants and people with disorders that cause seizures (FDA 2015). In the past, γ-HCH was used in veterinary products to control mites and other pests, but recent data suggest that no products are currently registered in the United States for this use (Hauzenberger et al. 2002).

### 5.2.4 Disposal

HCH is listed as a toxic substance under Section 313 of the Emergency Planning and Community Right to Know Act (EPCRA) under Title III of the Superfund Amendments and Reauthorization Act (SARA) (EPA 2020c). Disposal of wastes containing HCH is controlled by a number of federal regulations.

The recommended disposal technique for γ-HCH is incineration, at 400–500 °C in the presence of a catalytic mixture of 5–10% metal chloride (copper, iron, zinc, or aluminum) on activated carbon (EPA 1975). Residence times based on this method were not reported. Other effective waste disposal methods include treatment with strongly alkaline solution or oxidation. In a laboratory-scale study, 98.5% γ-HCH was removed after a 6.5-hour treatment at pH 11.5 (EPA 1975). Γ-HCH can be effectively oxidized by ozone and somewhat effectively oxidized by potassium permanganate; oxidation with chlorine or hydrogen peroxide was ineffective (EPA 1975). EPA standard treatment for hazardous wastes containing α-, β-, δ-, and γ-HCH is through either incineration or removal from liquid wastes by adsorption, prior to land disposal (EPA 2014).

While current disposal techniques may be adequate, chemical and biological degradation methods may provide increased efficiency and quality of disposal at a greatly reduced cost. Some methods utilize various absorbents, which can be natural (ex. Agricultural solid wastes, biomass) or engineered materials (e.g., nanomaterials, activated carbon absorbents), to remove pesticides from wastewater prior to treatment of the absorbent solid waste via microbial degradation or incineration (Saleh et al. 2020). Microbial strains enriched from HCH-contaminated media can be employed for direct treatment of wastewater. One laboratory-scale study was able to degrade HCH in wastewater with a consortium of Pseudomonas, Burkholderia, Flavobacterium, and Vibrio microbial strains (Saleh et al. 2020). Another method successfully degraded γ-HCH via UV-Fenton treatment (Saleh et al. 2020). This process is cost effective, around $28.70 per kilogram of contaminants treated, and has shown a 90% chemical oxygen demand (COD) reduction in studies with other organochlorine pesticides.

It’s unclear how frequently chemical or biological degradation methods are employed, but there are clear benefits of these disposal techniques. They can be cost-effective, reliable, and can be adapted to the variety of disposal challenges presented by the multitude of pesticides that are currently used. The use of microbial consortia ensures that each pesticide will be degraded rapidly. These methods can also be used for pesticide mixtures (Saleh et al. 2020).

## 5.3 RELEASES TO THE ENVIRONMENT

The Toxics Release Inventory (TRI) data should be used with caution because only certain types of facilities are required to report (EPA 2022b). This is not an exhaustive list. Manufacturing and processing facilities are required to report information to the TRI only if they employ ≥10 full-time employees; if their facility’s North American Industry Classification System (NAICS) codes is covered under EPCRA Section 313 or is a federal facility; and if their facility manufactures (defined to include importing) or processes any TRI chemical in excess of 25,000 pounds, or otherwise uses any TRI chemical in excess of 10,000 pounds, in a calendar year (EPA 2022b).

### 5.3.1 Air

Estimated releases of 189 pounds (~0.086 metric tons) of γ-HCH to the atmosphere from 7 domestic manufacturing and processing facilities in 2021 accounted for about 69% of the estimated total environmental releases from facilities required to report to the TRI (TRI21 2022). These releases are summarized in Table 5-2.

Table 5-2 Releases to the Environment from Facilities that Produce, Process, or Use γ-Hexachlorocyclohexane^a^

State^c^ | RF^d^ | Reported amounts released in pounds per year^b^
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | On-site^j^ | Off-site^k^ | On- and off-site
γ-HCH
AR | 1 | 0 | 0 | 0 | 35 | 0 | 0 | 35 | 35
NE | 1 | 180 | 0 | 0 | 20 | 0 | 180 | 20 | 200
OH | 2 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 1
TX | 2 | 8 | 0 | 0 | 0 | 0 | 8 | 0 | 8
UT | 1 | 0 | 0 | 0 | 0 | 28 | 0 | 28 | 28
Total | 7 | 189 | 0 | 0 | 56 | 28 | 189 | 84 | 273

a The TRI data should be used with caution since only certain types of facilities are required to report. This is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, wastewater treatment-(metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other onsite landfills, land treatment, surface impoundments, other land disposal, other landfills.

i Storage only, solidification/stabilization (metals only), other off-site management, transfers to waste broker for disposal, unknown.

j The sum of all releases of the chemical to air, land, water, and underground injection wells.

k Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI21 2022 (Data are from 2021)

All isomers of HCH are considered hazardous air pollutants (HAPs) known to cause or suspected of causing cancer or other serious human health effects or harmful environmental effects (EPA 2020a), as regulated under the Clean Air Act. EPA’s National Emission Inventory (NEI) database contains comprehensive and detailed estimates regarding sectors part of the emissions inventory system (EIS) which emit criteria air pollutants and HAPs for the 50 United States, Washington D.C., Puerto Rico, and the U.S. Virgin Islands. The NEI database includes point and non-point source emissions, onroad sources, non-road sources, and event sources such as emissions from wildfires or prescribed burning. According to data from the 2017 NEI, 62.40 pounds of γ-HCH were released from waste disposal, industrial solvent use, industrial processes, and fuel combustion (EPA 2020b). These data are summarized in Table 5-3.

Table 5-3 γ-HCH Emissions as Reported by the 2017 National Emission Inventory

Release sector | Emissions (pounds)
Waste disposal | 54.607700078
Solvent; industrial surface coating and solvent use | 5.91946
Industrial processes; ferrous metals | 1.819
Industrial processes; NEC | 0.04
Fuel combustion; commercial/institutional oil | 0.01

NEC = not elsewhere classified

Source: EPA 2020b

Historically, the largest source of γ-HCH releases to the air resulted from agricultural use of the pesticide γ-HCH, from aerial pesticide application or wind erosion of contaminated soils. γ-HCH may have also been released to the atmosphere via volatilization from treated agricultural soils and plant foliage (Lewis and Lee 1976). Evaporative loss of γ-HCH from water is not considered a significant potential source of atmospheric γ-HCH because of its relatively high water solubility (Mackay and Leinonen 1975). Quantitative historical estimates of the amount of γ-HCH released from these sources were not located in the literature. Aerial applications of γ-HCH were prohibited in the United States as its use as a pesticide was continuously restricted and eventually prohibited (EPA 1985b, 2006a, 2006b), and atmospheric releases from agricultural sources today are not expected.

### 5.3.2 Water

No releases of γ-HCH to water from 7 domestic manufacturing and processing facilities required to report to the TRI were reported in 2021 (TRI21 2022). This estimate includes releases to wastewater treatment and publicly owned treatment works (POTWs) (TRI21 2022). These releases are summarized in Table 5-2.

γ-HCH can be released to surface water via “down-the-drain” releases from consumer wash-off of treatments for lice and scabies (EPA 2002). These releases would be treated by wastewater treatment and POTWs, which did not report releases of γ-HCH to the TRI in 2021. Average γ-HCH concentrations in wastewater treated in Los Angeles County, California, have been reported to range from 3.6×10^−5^ to 0.03 μg/L (EPA 2002; Humphreys et al. 2008). α-HCH was not detected in 165 wastewater and wastewater treatment effluent samples collected between 2001 and 2010 (WQP 2021). One wastewater sample collected in 2003 contained 0.014 μg/L α-HCH (WQP 2021). β-HCH was not detected in 24 wastewater samples collected between 2003 and 2009 (WQP 2021). Wastewater may be a negligible source of hexachlorocyclohexanes to surface water and groundwater.

After soil or aerial application for agricultural use, γ-HCH could be released to surface water via surface runoff (as the dissolved chemical or adsorbed to particulates) or via wet deposition of rain and snow (Tanabe et al. 1982; Wheatley and Hardman 1965). Lake Ontario received 7 kg/year of α-HCH and <2 kg/year of γ-HCH due to suspended sediment loading from the Niagara River between 1979 and 1981 (Kuntz and Warry 1983). Historically, the Great Lakes in general received 0.77–3.3 metric tons/year of α-HCH and 3.7–15.9 metric tons/year of γ-HCH from atmospheric deposition of these contaminants (Eisenreich et al. 1981). Because γ-HCH is no longer allowed to be used for agricultural purposes, these are not expected to be significant sources of releases today.

Further from agricultural areas, urban stormwater runoff has historically resulted in releases of HCH to water in the range of parts per billion to parts per trillion. In 1982, α- and γ-HCH were detected in samples of urban stormwater runoff from Denver, Colorado, and Washington, D.C., at 0.0027–0.1 and 0.052–0.1 μg/L in 20 and 11%, respectively, of the 86 samples collected; β-HCH was detected only in runoff from Washington, D.C., in 5% of the samples at a concentration of 0.1 μg/L (Cole et al. 1984). In urban runoff samples collected in the Canadian Great Lakes Basin, γ-HCH was detected at mean concentrations of 0.0065 μg/L and 0.0035 mg/kg in the aqueous and sediment portions, respectively; the mean annual loading of the compound in runoff in the basin was reported to be 4.1 kg/year (Marsalek and Schroeter 1988). Stormwater samples collected in 2007, just after the ban on γ-HCH for agricultural use, showed concentrations between 6.0×10^−5^ and 0.14 μg/L α-HCH and 3.8×10^−4^ and 0.0976 μg/L β-HCH (WQP 2021).

γ-HCH could be released to groundwater via soil leachate after agricultural application or from improper disposal at contaminated sites. Available adsorption data indicate that γ-HCH has a low to moderate mobility in soils, and the results of monitoring studies suggest that γ-HCH does migrate to groundwater (Page 1981; Sandhu et al. 1978). Groundwater samples were collected from a packaging and reformulating pesticide facility in Florida, which had disposed of γ-HCH wastes in unlined trenches until 1996. Ground water concentrations for the site ranged from 30 to 420 μg/L for α-, γ-, and δ-HCH (Chartrand et al. 2015).

### 5.3.3 Soil

Estimated releases of 56 pounds (~0.025 metric tons) of γ-HCH to soil from 7 domestic manufacturing and processing facilities in 2021, constituting about 20% of the estimated total environmental releases from facilities required to report to the TRI (TRI21 2022). No additional quantities were released via underground injection (TRI21 2022). These releases are summarized in Table 5-2.

γ-HCH has historically been released to the soil by direct application of the pesticide to soil, and can be released by direct or indirect releases during formulation, storage, and/or disposal. Hazardous waste sites where γ-HCH has been disposed of in the past are sources of γ-HCH in soils. However, the application of γ-HCH to laboratory refuse columns simulating municipal landfills indicated that γ-HCH did not volatilize or leach from the refuse surface, and movement through the column was slight, suggesting that codisposal of γ-HCH with municipal refuse will result in minimal releases (Reinhart and Pohland 1991; Reinhart et al. 1991).

## 5.4 ENVIRONMENTAL FATE

### 5.4.1 Transport and Partitioning

Air. HCH isomers are volatile, relatively persistent substances in the atmosphere and are expected to be capable of long-range transportation. HCH can exist in the vapor and particulate phases based on the reported vapor pressures of the isomers (NLM 2021). Volatilization of γ-HCH used as a seed treatment was confirmed, with 12–30% of the applied pesticide volatilizing within 6 weeks of planting the seed (Waite et al. 2001, 2007). Correspondingly, atmospheric concentrations of γ-HCH were variable and increased when pesticide usage occurred; α-HCH concentrations were less variable throughout the year (Hoff et al. 1992a). During the winter, higher ratios of α-HCH to γ-HCH reflected the movement of air containing the more persistent α-HCH isomer from the colder Arctic regions to the south, while the lower ratios in the summer reflected both increased γ-HCH usage in the region and the lack of movement of Arctic air (Hoff et al. 1992a). γ-HCH was also seen to move with warm air during the summer months from the lower United States (or areas even further to the south) to the Great Lakes region, although a similar trajectory could not be identified for the more ubiquitous α-HCH. Levels of α-HCH in air are not dominated by volatilization or partitioning to surfaces, but are dependent on local temperature changes (Hoff et al. 1992b). α-HCH appears to have a long residence time in the atmosphere and is controlled primarily by transport. Long-range transport potentials were estimated for α- and γ-HCH based on North American monitoring data, and were reported to be 11,151 miles (17,946 km) and 6,047 miles (9,732 km), respectively (Shen et al. 2004). The potential for widespread global distribution has been reported in several studies (Hargrave et al. 1988; Knap and Binkley 1991; Tanabe et al. 1982; Wittlinger and Ballschmiter 1990). α- and γ-HCH have been measured in arctic air as recently as 2018, but concentrations have been declining due to declining global emissions and limited use of lindane (Wong et al. 2021).

HCH isomers in the atmosphere are likely to be subject to rain-out and dry deposition, which may result in the contamination of surface soil and water. Air-sea exchange fluxes of −0.95 and −17 ng/m^2^/day were observed over the northwest Pacific Ocean for α- and γ-HCH, respectively, supporting the oceans as an important sink for atmospheric HCH (Wu et al. 2020). γ-HCH removal rates were 2.5%/week by rainfall and 3.3%/week by dry deposition, and the estimated residence time of γ-HCH in the atmosphere was 17 weeks (Atkins and Eggleton 1971). The dry deposition flux rate of α-HCH ranged from 0.1 to 5.1 ng/m^2^/day in deposition samples collected in June–August 1997 near the southern Baltic Sea (Wiberg et al. 2001). The flux rate of γ-HCH was 0.9–32.6 ng/m^2^/day over the same time frame. Seasonal variation resulted in lower dry deposition rates during the winter months. In samples collected between February and March 1998, the flux rate for α-HCH ranged from 0.25 to 0.54 ng/m^2^/day, and the dry deposition flux rate for γ-HCH was 3.4–14.1 ng/m^2^/day (Wiberg et al. 2001). The dry deposition flux rate of γ-HCH in south central Saskatchewan in 1998 where it had been used as a seed treatment in a canola field ranged from <29 to 2,203 ng/m^2^/day, and the amount in rainfall over the same period ranged from <10 to 200 ng/L (Waite et al. 2001). Uptake by plants may be another removal pathway, as observed for α- and γ-HCH under experimental conditions with lettuce, romaine, and garlic leaf (Yang et al. 2007). Removal was controlled by plant-air equilibration and correlated strongly with the reported log octanol-air partition coefficients (K_OA_), 7.44 and 7.72 α- and γ-HCH, respectively (Yang et al. 2007).

Water. In surface waters, HCH has a slight tendency to dissolve and remain in the water column based on the water solubilities and octanol-water partition coefficients (K_ow_) of the isomers (Clayton and Clayton 1981; Hansch and Leo 1995; Hollifield 1979; Kurihara et al. 1973). Although γ-HCH has a relatively high vapor pressure and Henry’s law constant compared with many other organochlorine insecticides, evaporative loss of γ-HCH from water is not considered to be significant. Mackay and Leinonen (1975) calculated theoretical losses of several pesticides from saturated water solutions and predicted a volatilization half-life of 191 days for γ-HCH. Evidence of increased flux from the Arctic Ocean of α-HCH due to increased temperatures and decreased sea ice coverage may suggest this as pathway of growing significance as global warming continues (Wong et al. 2021).

γ-HCH released to water may undergo adsorption/desorption with sediments and other materials in the water. Adsorption and desorption studies of γ-HCH in natural water-sediment systems performed by Saleh et al. (1982) indicate that a diversity of the natural water-sediment characteristics may affect the sorption-desorption behavior of γ-HCH in addition to the organic carbon content of the sediments. γ-HCH is sorbed to silt solutions with a slow desorption rate, indicating that transport through the environment is most likely to be particle mediated (Noegrohati and Hammers 1992). Biosorption of γ-HCH was seen for the fungus Rhizopus arrhizus and activated sludge, with equilibrium being reached within 1 and 4 hours, respectively. Death of the sludge biomass resulted in rapid desorption with zero-order kinetics, suggesting that adsorbed γ-HCH can be released back into the environment (Tsezos and Wang 1991a). The sorption of γ-HCH from water using wood charcoal has been described (Keerthinarayana and Bandyopadhyay 1998); it was found to be a good sorbent for γ-HCH from water.

Sediment and Soil. HCH present in soil can leach to groundwater, sorb to soil particulates, or volatilize to the atmosphere. In general, the leaching of organic chemicals through soil is governed by the water solubility of the chemicals and their propensity to bind to soil. Based on the results of a number of laboratory soil column leaching studies that used soils of both high and low organic carbon content as well as municipal refuse, γ-HCH generally has low to moderate mobility in soils, with K_oc_ values ranging from 641 to 3,362; log K_oc_ range of 2.810–3.5266 (EPA 1982b; Melancon et al. 1986; Reinhart et al. 1991). Adsorption of γ-HCH to soil particulates is generally a more important partitioning process than leaching to groundwater. However, groundwater sediments, which have low organic carbon content (<0.1%), are not sufficient to adsorb γ-HCH to the extent that groundwater contamination is prevented (Nordmeyer et al. 1992). The presence of black carbon in soils from incomplete combustion may impact sorption affinity. HCH isomers showed varying preference for partitioning to black carbon (α-HCH > β-HCH > δ-HCH) in soils with 0.82–2.26% organic carbon and 0.04–0.5% black carbon (Ali et al. 2016). Sorption was observed to be a limiting factor in bioavailability of γ-HCH in soil to earthworms (Šmídová et al. 2012).

Using sediment (0.44% organic carbon) obtained from a sugarcane growing region of Australia, the K_oc_ of γ-HCH was measured as 2,164 (Just et al. 1990). The K_oc_ of γ-HCH in a mineral soil containing 1.26% organic carbon content was measured as 832 (Chiou et al. 1998). In a sandy soil (0.105% organic carbon) γ-HCH had a measured K_oc_ of 3,362, and a desorption K_d_ of 3.53 (Melancon et al. 1986). The partition coefficient (K_p_) of γ-HCH in a laboratory column experiment with municipal solid waste was 853 (Reinhart et al. 1991). In a study involving a laboratory sediment/water system (pH 7.42; 2.18% organic carbon), α- and γ-HCH isomers were adsorbed on sediments under both aerobic and anaerobic conditions and few differences were noted in the adsorption behavior of each isomer. Under aerobic and anaerobic conditions, the K_oc_ values of α-HCH were 681 and 617, respectively, while the K_oc_ values for γ-HCH were 641 and 694, respectively (Wu et al. 1997). A mixture of HCH isomers (α-, β-, γ-, and δ-HCH) sorbed very strongly to a soil from Nagpur, India (pH 7.6, 0.387% organic carbon), with a K_oc_ value of 54,000. Some desorption was observed, believed to be due to the water solubility of HCH (Wadaskar et al. 2006). Desorption experiments with a sandy loam soil slurry showed isomeric differences in desorption capacity, α- ≥ γ- > δ- > β-HCH (Quintero et al. 2005).

γ-HCH sorbed to the soil can partition to the atmosphere by wind erosion of surface soil particulates (Stanley et al. 1971) and via volatilization from treated agricultural soils and plant foliage (Lewis and Lee 1976). In tests conducted in a model laboratory system at 10 and 20°C, volatilization half-lives of γ-HCH from soil and oat plant surfaces of 2.3–24.8 and 0.29–0.73 days, respectively, were reported (Dorfler et al. 1991a); half-lives were greater on dry, sandy soils versus peat soils; however, when moisture was added to the soils, the half-life was greater for the peat soil, while warmer temperatures decreased the half-life under all soil and moisture conditions (Dorfler et al. 1991b). In tests performed with a wind tunnel, a volatilization rate of >20% for γ-HCH from soil surfaces within a 24-hour period was determined (Rüdel 1997). A 6-fold increase in γ-HCH volatilization from soil was seen in laboratory experiments when the temperature increased from 15 to 45°C; flooding the soil also increased the volatilization (Samuel and Pillai 1990). A field study conducted in south central Saskatchewan, Canada in 1997–1998 in which γ-HCH was applied as a seed treatment to canola, determined that between 12 and 30% of the initial amount applied volatilized to the atmosphere (Waite et al. 2001); a follow-up study determined volatilization rates of 190 mg/hectare/week at 1 week after application and 420 mg/hectare/week 2 weeks after application (Waite et al. 2007). The volatilization rate from plant surfaces was 55% for γ-HCH. Application of γ-HCH to fields of sunflowers and sugarbeets resulted in a 54% evaporative loss of the pesticide within 24 hours (Neururer and Womastek 1991).

Other Media. γ-HCH has a low to moderate potential to bioaccumulate. A summary of some of the bioconcentration factors (BCFs) from experimental studies with γ-HCH are provided in Table 5-4. γ-HCH shows limited uptake from soils and bioconcentration by plants and terrestrial organisms and does not appear to biomagnify to a great extent.

Table 5-4 Results of Experimental Bioaccumulation Studies with γ-Hexachlorocyclohexane

Species | Exposure route | Bioconcentration factor | Reference
Brine shrimp | Water | 183 | Matsumura and Benezet 1973
Rainbow trout (fry) | Water | 319 | Ramamoorthy 1985
Pink shrimp | Water | 84 | Schimmel et al. 1977
Pinfish | Water | 218 | Schimmel et al. 1977
Grass shrimp | Water | 63 | Schimmel et al. 1977
Sheepshead minnow | Water | 490 | Schimmel et al. 1977
Brine shrimp | Sand | 95 | Matsumura and Benezet 1973
Northern brook silverside fish | Sand | 1,613 | Matsumura and Benezet 1973

A BCF of 1,273 (lipid basis) in prawns (crustacean) was seen to be 0.58 times the γ-HCH concentration in the underlying sediment, indicating that aquatic organisms may accumulate γ-HCH from the water column, and uptake from contaminated sediment alone may not be extensive (Just et al. 1990). BCFs for the isomers of HCH, using zebra fish under steady-state conditions, were 1,100 for α-HCH, 1,460 for β-HCH, 850 for γ-HCH, and 1,770 for δ-HCH; BCFs determined by uptake and clearance rate constants were slightly lower (Butte et al. 1991). Elimination of γ-HCH occurred rapidly in zebra mussels (BCF of 10) and metabolism of γ-HCH was not observed (Berny et al. 2002). BCFs on a wet weight basis for γ-HCH in different fish species were positively correlated with their lipid content (Geyer et al. 1997). The bioaccumulation of γ-HCH by tubificide oligochaetes from a static system consisting of sediment and water has been reported (Egeler et al. 1997). Microalgae Scenedesmus quadricauda and Coccomyxa subellipsoidea were exposed for 24 hours to mine dump effluent containing α-, β-, γ-, and δ-HCH, resulting in bioaccumulation factors (BAFs) of 74.6, 60.5, 29.4, and 107.2 for α-, β-, γ-, and δ-HCH, respectively, in S. quadricauda, and BAFs of 50.8, 47.6, 21.5, and 56.3 for α-, β-, γ-, and δ-HCH, respectively, in C. subellipsoidea (Kováčik et al. 2018).

γ-HCH applied to an aquatic mesocosm (i.e., a small, artificial ecosystem) at 61.3 μg/L was reduced by 50% at 24 hours post-application, while at 19 weeks post-application, the concentration in the water was only 0.2%; no γ-HCH was detected at 21 weeks. The biological half-life was estimated to be 16.7 days. Movement through the water column was shown by increasing sediment concentrations up to a maximum of 75.4 μg/kg at 96 hours post-application; however, sediment concentrations decreased to below the detection limit at 23 weeks to give a half-life in sediment of 48.1 days. Rooted aquatic macrophytes have a BCF of 56 at a maximum concentration of 1.7 mg/kg at 24 hours post-application; however, at 14 weeks, all residues were below the detection limit for a half-disappearance time of 18 days.

Gastropods in the system had a maximum γ-HCH concentration of 7.2 mg/kg at 24 hours post-treatment, yielding a BCF of 232.4 and a half-disappearance time of 13.7 days with all residues eliminated by 13 weeks (Caquet et al. 1992).

Trophic transfer of γ-HCH may occur in the foodweb. A study assessed the potential of transfer between zebra mussels and their predators, tufted ducks (Aythia fugigula) at the birds’ wintering grounds in Lake Geneva, bordering Switzerland and France. γ-HCH concentrations in the mussels ranged from approximately 5 to 500 ng/g wet weight, while γ-HCH in the liver of the tufted ducks ranged from 8.9 to 175.6 ng/g wet weight (Bemy et al. 2003).

In tests with radiolabeled γ-HCH, grain, maize, and rice plants accumulated 0.95, 0.11, and 0.04%, respectively, of the amount of bound residues following 14–20 days growth in a sandy loam soil. Bioconcentration increased by 4–10 times when the plants were grown in test soils containing both bound and extractable residues of γ-HCH (Verma and Pillai 1991). Plants and grains grown on soil treated with γ-HCH showed α-HCH as the predominant isomer, although all isomers were found to some extent; amounts decreased with increasing time after application (Singh et al. 1991). A different trend in isomer uptake was observed in garlic. Garlic (Allium sativum L.) was planted in pots containing soil treated with α-, β-, γ-, and δ-HCH isomers. The BCFs of the underground parts were in the range of 0.48–0.90, 1.60–1.84, 1.40–2.34, and 2.60–3.64 for α-, β-, γ-, and δ-HCH, respectively, and above-ground parts were 1.50–2.26, 4.50–6.79, 5.16–6.81, and 9.30–12.18, respectively (Chen et al. 2013). The phytoavailability of the isomers was observed to be δ- > γ- ≥ β- > α-HCH, which generally agreed with the isomer’s water solubility and vapor pressure (Chen et al. 2013). Evidence of plant uptake from air has been reported. Lettuce, romaine, and garlic leaf were maintained in air chambers that exposed them to air polluted with α- and γ-HCH for 5 days. Measured accumulation factors of α-HCH in the crops were 77.25, 190.8, and 95.23 for lettuce, romaine, and garlic leaf, respectively, and accumulation factors of γ-HCH were 187.6, 321.9, and 124.5, respectively (Yang et al. 2007).

Uptake of γ-HCH by earthworms from a treated soil has also been reported. Eisenia andrei exposed to grassland soil spiked with γ-HCH for 24 hours had measured BAFs ranging from 5 to 35 (Šmídová et al. 2015). Following exposure to 5 ppm of the compound for up to 8 weeks, earthworms bioconcentrated γ-HCH by a factor of 2.5. The earthworms biotransformed more than 50% of the accumulated γ-HCH; the main degradation product was γ-2,3,4,5,6-pentachlorocyclohex-1-ene (Viswanathan et al. 1988).

γ-HCH and the other isomers of HCH do not appear to undergo biomagnification in terrestrial food chains to a great extent, although there is a moderate potential for transfer of γ-HCH to animal tissue as a result of soil ingestion or ingestion of contaminated foliage (Wild and Jones 1992). Clark et al. (1974) found that γ-HCH levels in the adipose tissue of cattle were 10 times higher than in the feed (0.002 mg/kg). Szokolay et al. (1977) examined relative accumulation of HCH isomers including γ-HCH and various components in the food chain in Czechoslovakia. Lower γ-HCH residues were found in tissues of animals (chickens, sheep, pigeons) feeding entirely on plant material, whereas carnivores had higher concentrations.

γ-HCH that is adsorbed to sediments may be recycled to the atmosphere as gas bubbles that are formed in the sediment by the methanogenesis and denitrification processes of bacteria. In one case studied, it was estimated that 85% of the γ-HCH associated with the sediment gas bubbles would be released to the atmosphere, with the remaining 15% being dissolved in the water column as the bubble rises toward the surface (Fendinger et al. 1992).

### 5.4.2 Transformation and Degradation

Air. HCH is degraded in the atmosphere by reacting with photochemically produced hydroxyl radicals. The rate of this reaction is not very rapid however, and all of the HCH isomers have rather long atmospheric lifetimes. The rate constants for the reaction of α- and γ-HCH with hydroxyl radicals were measured as 1.4×10^−13^ and 1.9×10^−13^ cm^3^/molecule-second, respectively (Brubaker and Hites 1998). Using an average hydroxyl radical concentration of 5×10^5^ molecule/cm^3^, the corresponding half-lives are about 115 and 84 days for α- and γ-HCH, respectively. In locations where the atmospheric hydroxyl radical concentration is very low, the persistence times of these compounds are much longer. Cortes and Hites (2000) estimated that the average half-life of α- and γ-HCH around the Great Lakes region ranged from about 3 to 4 years. Calculated half-lives based on artic air measurements ranged from 4.6 to 8.9 years for α-HCH, and from 4.4 to 10 years for γ-HCH; one arctic station reported a half-life of −28 years for γ-HCH, possibly due to the shorter monitoring period and the lack of change in concentrations over this period (Wong et al. 2021). Since HCH does not absorb light >290 nm, direct photolysis in the atmosphere is not expected to be an important environmental fate process. However, Chen et al. (1984) reported photodegradation half-lives of 91, 152, 104, and 154 hours for thin films of α-HCH, β-HCH, γ-HCH, and δ-HCH, respectively, when irradiated with light of wavelength 295–305 nm. No absorption bands were observed in this spectral region, however, for any of the HCH isomers, and the mechanism of photodegradation and its environmental significance are uncertain. A direct photolysis study of α-HCH showed maximum absorption in the middle ultraviolet (UV) range at 252 nm, with a half-life around 2 hours (pseudo-first-order rate constant of 0.34/hour) (Zhang et al. 2014). The environmental relevance of this is unclear, since the middle UV range wavelengths are filtered out by the stratosphere. Similar indirect photolysis studies were conducted at ≥280 nm with α-HCH in the presence of H_2_O_2_ at a molar ratio of 100:1 (H_2_O_2_:α-HCH). The indirect photolysis half-life was around 4.3 hours (pseudo-first-order rate constant 0.16/hour). A proposed final photolysis product is 2,4,6-trichlorophenol (Zhang et al. 2014).

Water. Biodegradation is believed to be the dominant degradative process for γ-HCH in aquatic systems, although hydrolysis and indirect photolysis may also occur. Sharom et al. (1980) found that <30% of the applied γ-HCH remained in unsterilized natural waters in capped bottles after 16 weeks. Biodegradation was concluded to be responsible for these results, although it was unclear to what extent hydrolysis or adsorption to the glass bottles may have contributed. Zoeteman et al. (1980) estimated river, lake, and groundwater half-lives for γ-HCH from degradation data in these environments to be 3–30, 30–300, and >300 days, respectively. In natural lake water with a pH of 9.0 and a hardness of >600 mg calcium carbonate/L, the half-life of γ-HCH was estimated to be 65 hours (Ferrando et al. 1992). γ-HCH, applied at concentrations of 50 or 500 μg/L to aerobic batch cultures of microorganisms with sodium acetate as a carbon source, was initially removed by adsorption and followed by desorption onto the biomass with subsequent decomposition (McTernan and Pereira 1991). Approximately 56–62% of the γ-HCH was removed from the water column in 23 days, with 26% removal by adsorption onto the biological solids produced in these batch reactors. Microbial growth, using γ-HCH in the absence of sodium acetate, increased as the microorganisms became acclimated; the pesticide still showed toxic properties, as evidenced by a concurrent increase in microbial death rates. Evidence of biodegradation of HCH isomers in groundwater has also been reported. In an in situ study of a former pesticide formulating plant, the biodegradation half-lives of α-, β-, and δ-HCH isomers were determined in groundwater below the site by compound-specific stable carbon isotope analysis respectively. Half-lives were determined based on isotopic depletion from samples collected over 3 years at various wells spreading out from the contaminant source. Half-lives were 223, 62–287, and 120–632 days for α-, β-, and δ-HCH isomers, respectively (Bashir et al. 2015).

It has been shown that γ-HCH is degraded by nitrogen-fixing blue-green algae. These algae reduce the toxic effects of γ-HCH following repeated inoculations (Kar and Singh 1979b). The degradation of γ-HCH became more efficient with time, thus reducing the pesticide’s toxicity in cultures of nitrogen-fixing blue-green algae. Dechlorination of γ-HCH to γ-pentachlorocyclohexene was also shown to occur with fungi in aqueous suspensions (Macholz and Kujawa 1985) and in algal cultures (Sweeney 1969).

Hydrolysis is not considered an important degradation process for HCH in aquatic environments under neutral pH conditions. However, under alkaline conditions, γ-HCH is hydrolyzed fairly rapidly. Saleh et al. (1982) tested rates of hydrolysis of γ-HCH in sterilized natural waters at 25°C and found that hydrolysis of γ-HCH followed first-order kinetics with half-lives of 92 hours at pH 9.3, 648 hours at pH 7.8, and 771 hours at pH 7.3. EPA (1989b) reported a hydrolysis half-life of 207 days at pH 7 and 25°C using distilled water. Alkaline hydrolysis (pH 9.78) of α-HCH was observed with a calculated half-life of 1,083 hours (based on pseudo-first-order rate constant of 0.0064/hour), giving 1,3,4,5,6-pentachlorocyclohexane, 1,2,4-trichlorobenzene, and 1,2,3-trichlorobenzene as the major products (Zhang et al. 2014).

Somewhat conflicting information is available on the rate of photolysis of γ-HCH in water. Since HCH does not contain chromophores that absorb light >290 nm, direct photolysis is not expected to occur. However indirect photolysis, whereby a photosensitizing agent may absorb light and then transfer its excitation energy to HCH, may occur. Humic and fulvic acids are well-known photosensitizing agents and are practically ubiquitous in natural waters. In the study by Saleh et al. (1982), the authors reported γ-HCH first-order photolysis half-lives of 169, 1,791, and 1,540 hours in pond water, lake water, and water from a quarry at pH 9.3, 7.3, and 7.8, respectively, when solutions were exposed to direct sunlight. However, the rapid rate of degradation at pH 9.3 may have been enhanced by hydrolysis reactions rather than by photolysis. In another study, α- and γ-HCH were shown to undergo enhanced photolysis when aqueous solutions were spiked with 5 and 25 ppm of soil fulvic acid, and irradiated with natural sunlight (Malaiyandi et al. 1982). Hamada et al. (1981) found that γ-HCH underwent photodegradation to form two isomers of tetrachlorohexene and pentachlorohexene in propanol solution when irradiated with UV light produced by a low-pressure mercury lamp. Oxidants commonly found in natural waters, such as peroxy radicals, hydroxyl radicals, and singlet oxygen species, can degrade HCH in water. Mill (1999) estimated that the indirect photolysis half-life of HCH in natural waters is about 270 days, and the dominant oxidant for HCH was the hydroxyl radical. Photolysis of γ-HCH in aqueous solution in the presence of polyoxomethallate, a strong oxidizing agent, has also been demonstrated (Hiskia et al. 1997).

Sediment and Soil. γ-HCH in soil or sediment is degraded primarily by biodegradation, although hydrolysis may occur in moist soils under alkaline conditions. Tu (1976) reported that 71 of 147 microorganisms isolated from a loamy sand soil were able to utilize a γ-HCH solution as the sole carbon source. White rot fungus degraded radiolabeled γ-HCH in aerobic pure culture laboratory tests. In a silt loam soil/corncob test matrix, 34.7% of the compound was degraded over a 60-day test period, whereas 53.5% degradation was observed in liquid cultures over a 30-day test period (Kennedy et al. 1990). The results of this study have been confirmed by more recent studies (Mougin et al. 1996, 1997). The isolation of γ-HCH-degrading bacteria, classified as Sphingomonas paucimobilis, from contaminated soils has been reported (Thomas et al. 1996). A Pseudomonas species has also been isolated from pretreated soil that is able to degrade γ- and α-HCH, but not β-HCH, within 10–20 days under both flooded (anaerobic) and unflooded (aerobic) conditions; greater degradation rates were observed under aerobic conditions (Sahu et al. 1993). Under aerobic conditions, actinobacteria strains of Streptomyces sp. isolated from a polluted site were able to utilize α-HCH as its only carbon source, and some were able to utilize β-HCH when supplemented to the α-HCH system; no growth was observed in the presence of δ-HCH. At pH 7 and 30°C, the actinobacteria were able to degrade up to 100% α-HCH and 55% β-HCH after 7 days (Sineli et al. 2014). The concentrations and persistence of γ-HCH in soil may be dependent on soil types. An analysis of two soil types, loamy sand (approximately 1–2% organic matter) and muck (approximately 27–56% organic matter), for γ-HCH residues showed that mean residues in the loamy sand soil had decreased from 95 ppb dry weight in 1971 to below the detection limit of 10 ppb in 1989; however, in muck, residues had decreased from 426 ppb in 1971 to 168 ppb in 1989 (Szeto and Price 1991). The presence of crops on the soils also affects the persistence of HCH residues, with half-lives of 58.8 and 83.8 days for cropped and uncropped plots, respectively. β-HCH was the most persistent isomer, with half-lives of 184 and 100 days, respectively, on cropped and uncropped plots; γ-HCH was next at 107 and 62.1 days, followed by α-HCH at 54.4 and 56.1 days, and finally, δ-HCH at 33.9 and 23.4 days. Only trace amounts of the isomers were found to leach below 20 cm soil depth (Singh et al. 1991). The β-HCH isomer comprised 80–100% of the total HCH residues found in soil or vegetation on land surrounding an industrial landfill in Germany 10 years after the final HCH input (Heinisch et al. 1993). Biodegradation was observed to be a limiting factor in uptake of γ-HCH by earthworms (Šmídová et al. 2012).

Most available information suggests that γ-HCH transformation is favored in biologically rich, anaerobic environments (EPA 1979; Haider 1979; Kalsch et al. 1998). In bench-scale anaerobic digestion tests designed to assess the fate of semivolatile organic pollutants in primary and secondary sludges, γ-HCH was found to undergo 98% degradation at 120 days. Sorption of the compound to the digester solids accounted for 2% of the initial feed; none of the compound was lost by volatilization. The digesters were operated at 35°C with a 30-day solids retention time (Govind et al. 1991). Similar results were seen with live activated sludge where initially reversible biosorption dominates the removal process followed by an increased aerobic biodegradation after approximately 10 hours of acclimation. The biodegradation process includes hydrolytic dechlorination with subsequent ring cleavage and finally, partial or total mineralization (Tsezos and Wang 1991b). Adaptation of sewage sludge is slow and may take 1–2 months; however, once acclimation occurs, 70–80% biodegradation of γ-HCH may occur, with the percentage of degradation decreasing with increasing sludge age (Nyholm et al. 1992). Co-oxidation and reductive dechlorination are the probable degradation mechanisms (Jacobsen et al. 1991; Nyholm et al. 1992).

Numerous diverse studies on biological degradation have shown that γ-HCH was transformed to tetrachlorohexene; tri-, tetra-, and pentachlorinated benzenes; penta- and tetracyclohexanes; other isomers of HCH; and other related chemicals. The products varied depending on the organisms present, analytical methods applied, and when the sample was analyzed relative to its collection date (EPA 1979). Laboratory studies have demonstrated the bioisomerization of γ-HCH to α-, β-, and δ-HCH but bioisomerization in the environment was considered to be nonsignificant by an investigator who conducted a field study (Waliszewski 1993). Levels of individual isomers were approximately 0.1–1.4 and 0.8–4.0% of the γ-HCH concentrations at 3–31 and 34–46 weeks, respectively, following γ-HCH treatment of soil. The study authors suggested that their inability to simulate all environmental conditions in the laboratory could explain differences between laboratory and field results.

Abiotic transformation and degradation processes of γ-HCH in soil/sediment are not thought to be significant pathways. As discussed earlier for water, photolysis or hydrolysis are not considered important degradation pathways of γ-HCH and other isomers; the exception being hydrolysis under alkaline conditions.

Other Media. Several Organisation for Economic Cooperation and Development (OECD) and European Union standardized tests exist to quantify potential for biodegradation in a wastewater treatment facility. A closed bottle test, conducted according to EC directive 92/69/EEC, was initiated with 2 mg/L of γ-HCH in a 25 mg/L slurry of activated sludge in mineral nutrient medium, under aerobic conditions. γ-HCH achieved 100% degradation based on theoretical oxygen uptake after 9 days (Lapertot and Pulgarin 2006).

## 5.5 LEVELS IN THE ENVIRONMENT

Reliable evaluation of the potential for human exposure to HCH depends, in part, on the reliability of supporting analytical data from environmental samples and biological specimens. Concentrations of HCH in unpolluted atmospheres and in pristine surface waters are often so low as to be near the limits of current analytical methods. In reviewing data on HCH levels monitored or estimated in the environment, it should also be noted that the amount of chemical identified analytically is not necessarily equivalent to the amount that is bioavailable.

Table 5-5 shows the lowest limit of detections that are achieved by analytical analysis in environmental media. An overview summary of the range of concentrations detected in environmental media, based on the most recent data available, post-cancellation of γ-HCH as a pesticide, is presented in Table 5-6.

Table 5-5 Lowest Limit of Detection Based on Standards^a^

Media | Detection limit | Reference
Air | 0.2 pg/m^3^ – 200 ng/m^3^ (α-, β-, γ-HCH) | EPA 1999d
Drinking water | 0.0053 μg/L (α-HCH); 0.0036 μg/L (β-HCH); 0.0060 μg/L (γ-HCH); 0.0020 μg/L (δ-HCH) | EPA 1995
Surface water and groundwater | 7 pg/L – 0.0053 μg/L (α-HCH); 6 pg/L – 0.0036 μg/L (β-HCH); 9 pg/L – 0.0060 μg/L (γ-HCH); 5 pg/L – 0.0020 μg/L (δ-HCH) | EPA 1995, 2007
Soil | 6 ng/L; 1.3 ng/kg (α-HCH); 7 ng/L; 0.6 ng/kg (β-HCH); 11 ng/L; 0.7 ng/kg (γ-HCH); 5 ng/L; 2.0 ng/kg (δ-HCH) | EPA 2000b, 2007
Sediment | 0.500 μg/kg; 6 ng/L (α-HCH); 0.221; 7 ng/L (β-HCH); 0.200 μg/kg; 11 ng/L (γ-HCH); 5 ng/L (δ-HCH) | EPA 2000b; USGS 2003
Whole blood | 1 ppb (α-, β-, γ-HCH); 1.3 ng/g lipid (β-HCH); 0.92 ng/g lipid (γ-HCH) | CDC 2019; EPA 1980

a Detection limits based on using appropriate preparation and analytics. These limits may not be possible in all situations.

Table 5-6 Summary of Ambient Environmental Levels of HCH

Media | Low | High | Reference
α-HCH
Outdoor air (ng/m^3^) | 0.00016 | 0.017 | WQP 2023
Indoor air | No data
Surface water (ng/L) | 0.1 | 1.7 | WQP 2023
Groundwater | Not detected | | WQP 2023
Drinking water | No data
Food | Not detected | | FDA 2020b
Soil and sediment | Not detected | | WQP 2023
β-HCH
Outdoor air (ng/m^3^) | 0.00034 | 0.064 | WQP 2023
Indoor air | No data
Surface water (ng/L) | 0.11 | 1.2 | WQP 2023
Groundwater | Not detected | | WQP 2023
Drinking water | No data
Food | Not detected | | FDA 2020b
Soil and sediment (μg/kg) | 0.032 | 0.39 | WQP 2023
γ-HCH
Outdoor air (ng/m^3^) | <1.7 | No data | EPA 2021
Indoor air | No data
Surface water | No data
Groundwater | No data
Drinking water | No data
Food | Not detected | | FDA 2020b
Soil and sediment | No data
δ-HCH
Outdoor air | Not detected | | WQP 2023
Indoor air | No data
Surface water (ng/L) | 0.44 | 3.7 | WQP 2023
Groundwater | Not detected | | WQP 2023
Drinking water | No data
Food | Not detected | | FDA 2020b
Soil and sediment | Not detected | | WQP 2023
HCH, technical grade
Outdoor air | No data
Indoor air | No data
Surface water | No data
Groundwater | No data
Drinking water | No data
Food | No data
Soil and sediment (μg/kg) | 0.47 | 1.26 | WQP 2023

Detections of HCH in air, water, and soil at NPL sites are summarized in Table 5-7.

Table 5-7 Hexachlorocyclohexanes (HCHs); Levels in Water, Soil, and Air of National Priorities List (NPL) Sites

Medium | Median^a^ | Geometric mean^a^ | Geometric standard deviation^a^ | Number of quantitative measurements | NPL sites
α-HCH
Water (ppb) | 0.987 | 1.08 | 45.2 | 43 | 29
Soil (ppb) | 3,390 | 2,970 | 156 | 52 | 28
Air (ppbv) | 0.0016 | 0.0010 | 11 | 6 | 5
β-HCH
Water (ppb) | 0.68 | 1.09 | 18.7 | 34 | 22
Soil (ppb) | 950 | 911 | 61.7 | 44 | 33
Air (ppbv) | 0.0017 | 0.00080 | 7.1 | 2 | 2
γ-HCH
Water (ppb) | 0.515 | 0.819 | 49.2 | 64 | 38
Soil (ppb) | 2,800 | 2,090 | 127 | 66 | 42
Air (ppbv) | 0.0044 | 0.0038 | 29 | 7 | 7
δ-HCH
Water (ppb) | 0.57 | 1.18 | 34.5 | 29 | 19
Soil (ppb) | 1,100 | 392 | 71.9 | 31 | 22
Air (ppbv) | 0.0002 | 0.00016 | 1.5 | 3 | 2
HCH, technical grade
Water (ppb) | 0.86 | 3.0 | 24 | 6 | 5
Soil (ppb) | 8,700 | 2,300 | 81 | 10 | 6
Air (ppbv) | 0.000017 | 0.000017 | 1 | 2 | 1

a Concentrations found in ATSDR site documents from 1981 to 2022 for 1,868 NPL sites (ATSDR 2022). Maximum concentrations were abstracted for types of environmental media for which exposure is likely. Pathways do not necessarily involve exposure or levels of concern.

### 5.5.1 Air

HCH isomers have been detected in ambient air. The highest concentrations were found prior to γ-HCH agricultural use restrictions; available monitoring data after the restriction and ban of γ-HCH pesticides showed a gradual decrease and the results of the most recent monitoring studies are below the parts per billion range. The results of outdoor air monitoring studies are presented in Table 5-8. Precipitation samples, if available, are included in Table 5-8 because they reflect removal of atmospheric HCH.

One reference to indoor air monitoring was located in the literature search. In a study of preschool children’s potential exposure to pesticides in North Carolina, indoor air samples from 13 daycare centers and 129 homes of the preschool children (ages 20–66 months) were collected between 2000 and 2001 (Morgan et al. 2014). γ-HCH was detected in ranges of below the limit of detection (<0.09 ng/m^3^) to 18.5 ng/m^3^ in the children’s homes and <0.09–8.97 ng/m^3^ in the preschools. Detection frequencies were 13 and 20%, respectively. Seventy-four percent of the homeowners reported applying insecticides at their homes, and 90% of these had applied an insecticide in the past year before sampling. Among the daycare centers, 62% reported using insecticides, and 88% of those reported usage within a year of sample collection (Morgan et al. 2014).

### 5.5.2 Water

Water monitoring data are presented in Table 5-9. HCH isomers have been detected in surface water, groundwater, and drinking water. The highest concentrations were found in groundwater below a facility that processed pesticides and stored wastes in unlined trenches until 1996 (Law et al. 2004). A study of the same site some years later still detected HCH isomers (Chartrand et al. 2015). Generally, surface water concentrations are lower than those detected in groundwater. Data from the EPA’s Water Quality Portal (WQP), a system that maintains water monitoring data from stations across the United States, have been divided into two categories: prior to γ-HCH pesticide cancellation (years up to and including 2006) and recent years post-cancellation (WQP 2023). Although recent data are limited, a decrease in surface and groundwater concentrations of α-, β-, and δ-HCH can be seen in this dataset; data for γ-HCH were not reported. From other studies, a decrease of γ-HCH in surface water can be observed, possibly due to use limitations; trends for drinking water and groundwater are not as clear. Most recent monitoring data report concentrations below the parts per billion range for surface water and groundwater.

Table 5-8 Outdoor Air Monitoring Data for Hexachlorocyclohexanes (HCHs)

Locations | Geographic type | Date(s) | Range^a^ | Mean^a^ | Notes | Reference
α-HCH
Alabama | Not reported | January–October 1996 and May 1997 | | 0.092 ng/m^3^ | | Jantunen et al. 2000
Eagle Harbor, Michigan; Sleeping Bear Dunes State Park, Michigan; Sturgeon Point, New York | Rural | 1990–1997 | | 0.110–0.140 ng/m^3^ | | Cortes and Hites 2000
Chesapeake Bay | Rural and agricultural | April 2000–September 2003; excluding winter months | 0.002–0.142 ng/m^3^ | 0.026 ng/m^3^ | Gas phase; average of averages at three sites; detection frequency 99–100% | Goel et al. 2010
Chesapeake Bay | Rural and agricultural | April 2000 –September 2003; excluding winter months | | 0.0012 ng/m^3^ | Particulate phase; detection frequency 1% | Goel et al. 2010
Chesapeake Bay | Rural and agricultural | April 2000–September 2003; excluding winter months | 0.2–11 ng/L | 1.7 ng/L | Rainwater; average of averages at three sites; detection frequency 3–18% | Goel et al. 2010
Youngstown, Ohio | Urban/suburban | 2000–2001 | | 0.051 ng/m^3^ | | Shen et al. 2004
Solomons, Maryland | Rural | 2000–2001 | | 0.091 ng/m^3^ | | Shen et al. 2004
Wilmington, North Carolina | Urban/suburban | 2000–2001 | | 0.015 ng/m^3^ | | Shen et al. 2004
Turkey Point, Florida | Rural | 2000–2001 | | 0.029 ng/m^3^ | | Shen et al. 2004
Muscle Shoals | Suburban/rural | 2000–2001 | | 0.056 ng/m^3^ | | Shen et al. 2004
United States | Ambient air | 2015–2019 | 0.00016–0.017 ng/m^3^ | 0.0042 ng/m^3^ | Detected in 83% of 481 samples; no data reported for 2020–2023^b^ | WQP 2023 ^c^
β-HCH
United States | Ambient air | 2015–2018 | 0.00034–0.064 ng/m^3^ | 0.005 ng/m^3^ | Detected in 28% of 481 samples; no data reported for 2020–2023^b^ | WQP 2023 ^c^
γ-HCH
College Station, Texas | Rural | 1979–1980 | 0.01–1.60 ng/m^3^ | 0.23 ng/m^3^ | Ground level, ambient air | Atlas and Giam 1988
College Station, Texas | Rural | 1979–1980 | 0.30–7.8 ng/L | 2.81 ng/L | Rainwater samples | Atlas and Giam 1988
Adirondack Mountains, New York | Not reported | 1985 | | 0.509 ng/m^3^ | Troposphere samples | Knap and Binkley 1991
Newport News, Virginia | Not reported | 1988 | | 0.021 ng/m^3^ | Troposphere samples | Knap and Binkley 1991
Alabama | Not reported | January–October 1996 and May 1997 | | 0.050 ng/m^3^ | | Jantunen et al. 2000
Eagle Harbor, Michigan; Sleeping Bear Dunes State Park, Michigan; Sturgeon Point, New York | Rural | 1990–1997 | | 0.024–0.062 ng/m^3^ | | Cortes and Hites 2000
Lake Superior | Not reported | 1984; wetfall season | | 3.0 ng/L | Rainwater samples, annual loading rate of 2.0 μg/m^2^/year | Strachan 1988
Portland, Oregon | Urban | 1982 | | 0.45–1 ng/L | Rain and snow water | Pankow et al. 1984
Hawaii | Not reported | 1970–1971 | 1–19 ng/L | 5 ng/L | Rainwater | Bevenue et al. 1972
Youngstown, Ohio | Urban/suburban | 2000–2001 | | 0.049 ng/m^3^ | | Shen et al. 2004
Solomons, Maryland | Rural | 2000–2001 | | 0.072 ng/m^3^ | | Shen et al. 2004
Wilmington, North Carolina | Urban/suburban | 2000–2001 | | 0.026 ng/m^3^ | | Shen et al. 2004
Turkey Point, Florida | Rural | 2000–2001 | | 0.031 ng/m^3^ | | Shen et al. 2004
Muscle Shoals | Suburban/agricultural | 2000–2001 | | 0.055 ng/m^3^ | | Shen et al. 2004
North Carolina | Not reported | 2000–2001 | <0.09–0.11 ng/m^3^ | | Air samples collected outside daycare centers; detection frequency 8% | Morgan et al. 2014
North Carolina | Not reported | 2000–2001 | <0.09–6.15 ng/m^3^ | | Air samples collected outside students; homes; detection frequency 12% | Morgan et al. 2014
Chesapeake Bay | Rural and agricultural | April 2000–September 2003; excluding winter months | 0.0012–0.382 ng/m^3^ | 0.049 ng/m^3^ | Gas phase; average of averages at three sites; detection frequency 81–100% | Goel et al. 2010
Chesapeake Bay | Rural and agricultural | April 2000–September 2003; excluding winter months | 0.0013–0.027 ng/m^3^ | 0.024 ng/m^3^ | Particulate phase; average of averages at two sites; detection frequency 2–7% | Goel et al. 2010
Chesapeake Bay | Rural and agricultural | April 2000–September 2003; excluding winter months | 0–35 ng/L | 4.0 ng/L | Rainwater; average of averages at two sites; detection frequency 1–61% | Goel et al. 2010
Texas | Various ambient air monitoring sites | January–December 2007 | | 0.005 ng/m^3^ | Detected in 20 samples; below the limit of detection in 345 samples | EPA 2021
Texas | Various ambient air monitoring sites | January–December 2008 | | <1.7 ng/m^3^ | Below the limit of detection in 488 samples | EPA 2021
Texas | Various ambient air monitoring sites | January–June 2009 | | <1.7 ng/m^3^ | Below the limit of detection in 120 samples | EPA 2021
δ-HCH
United States | Ambient air | 2015–2019 | | ND | Not detected in 26 samples; no data reported for 2020–2023^b^ | WQP 2023 ^c^

a Liquid unit conversion: 1 ng/L = 1 ppt = 0.001 ppb; gaseous unit conversion: ppbv = ([concentration ng/m^3^] × 0.001) / 11.89, assuming standard temperature and pressure.

b As of June 2023.

c Data collected by USGS monitoring stations across the United States; mean and ranges do not reflect samples reported as not detected/below detection limit.

ND = not detected; USGS = U.S. Geological Survey

Table 5-9 Water Monitoring Data for Hexachlorocyclohexanes (HCHs)

Locations | Geographic type | Date(s) | Range^a^ | Mean^a^ | Notes | Reference
α-HCH
Lake Superior | Surface water | Spring 1997 | | 2.8 ng/L | | Marvin et al. 2004
Lake Erie | Surface water | Spring 1998 | | 0.41 ng/L | | Marvin et al. 2004
Lake Ontario | Surface water | Spring 1998 | | 0.40 ng/L | | Marvin et al. 2004
York River estuary | Surface water | June 1998–April 1999 | ~0.025–0.175 ng/L | | Concentrations were lower in freshwater areas than areas with higher salinity | Padma and Dickhut 2002
United States | Surface water | 1978–2006 | 2.93×10^−5^–55,000 ng/L | 150 ng/L | Detected in 0.5% of 35,766 samples | WQP 2023 ^b^
United States | Surface water | 2020 | | ND | Not detected in 775 samples | WQP 2023 ^b^
United States | Surface water | 2021 | 0.11–0.976 ng/L | 0.54 ng/L | Detected in 0.2% of 902 samples | WQP 2023 ^b^
United States | Surface water | 2022 | 0.1–1.7 ng/L | 0.28 ng/L | Detected in 2% of 945 samples | WQP 2023 ^b^
United States | Surface water | 2023^d^ | | ND | Not detected in 9 samples | WQP 2023 ^b^
United States | Surface water at Portland Harbor Superfund Site | 2003–2006 | 4.2×10^−5^–0.002 ng/L | 0.026 | Detected in 45% of 193 samples | WQP 2023 ^b^
United States | Groundwater | 1981–2006 | 1.1–5,000 ng/L | 153 ng/L | Detected in 0.3% of 16,493 samples | WQP 2023 ^b^
United States | Groundwater | 2020, 2022 | | ND | Not detected in 125 samples; no data reported for 2021 or 2023^c^ | WQP 2023 ^b^
United States | Groundwater at EPA Region 10 Superfund Sites | 1987–2002 | | ND | Not detected in 396 samples | WQP 2023 ^b^
United States | Groundwater at Boomsnub Superfund Site | 1995 | | ND | Not detected in 18 samples | WQP 2023 ^b^
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 58–5.0×10^5^ ng/L | 51,000 ng/L | Samples collected from 19 shallow wells; not detected (<20 ng/L) in 6 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 30–4.2×10^5^ ng/L | 44,000 ng/L | Samples collected from 15 deep wells; not detected (<20 ng/L) in 5 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Surface water near active pesticide reformulating and packaging facility | 2000 | 660–680 ng/L | 670 ng/L | Three samples collected from creek adjacent to the site; not detected (<20 ng/L) in one sample; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
β-HCH
United States | Surface water | 1980–2006 | 0.0385–80,000 ng/L | 1,260 ng/L | Detected in 1% of 7,198 samples | WQP 2023 ^b^
United States | Surface water | 2020 | | ND | Not detected in 248 samples | WQP 2023 ^b^
United States | Surface water | 2021 | 0.18–0.84 ng/L | 0.49 ng/L | Detected in 4% of 221 samples | WQP 2023 ^b^
United States | Surface water | 2022 | 0.11–1.2 ng/L | 0.42 ng/L | Detected in 8% of 454 samples | WQP 2023 ^b^
United States | Surface water | 2023^d^ | | ND | Not detected in 5 samples | WQP 2023 ^b^
United States | Surface water Portland Harbor Superfund Site | 2004–2006 | 0.00017–0.0337 | 0.0060 | Detected in 25% of 190 samples | WQP 2023 ^b^
United States | Groundwater | 1981–2006 | 10–300 ng/L | 48 ng/L | Detected in 1% of 2,478 samples | WQP 2023 ^b^
United States | Groundwater | 2020 | | ND | Not detected in 3 samples; no data reported for 2021–2023^c^ | WQP 2023 ^b^
United States | Groundwater at EPA Region 10 Superfund Sites | 1987–2002 | | ND | Not detected in 395 samples | WQP 2023 ^b^
United States | Groundwater at Boomsnub Superfund Site | 1995 | | ND | Not detected in 18 samples | WQP 2023 ^b^
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 30–43,000 ng/L | 12,000 ng/L | Samples collected from 19 shallow wells; not detected (<20 ng/L) in 8 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 82–820 ng/L | 340 ng/L | Samples collected from 15 deep wells; not detected (<20 ng/L) in 8 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Surface water near active pesticide reformulating and packaging facility | 2000 | 38–440 ng/L | 300 ng/L | Three samples collected from creek adjacent to the site | Law et al. 2004
γ-HCH
New Jersey | Wells | Not reported (1981 or earlier) | NR–900 ng/L | | 1,076 wells, not detected in around half of samples | Page 1981
Chesterfield County, South Carolina | Rural drinking water | Not reported (1978 or earlier) | 0–93 ng/L | 23 ng/L | | Sandhu et al. 1978
Hampton, South Carolina | Rural drinking water | Not reported (1978 or earlier) | 0–319 ng/L | 147 ng/L | | Sandhu et al. 1978
Cincinnati, Ohio | Drinking water | Not reported (1976 or earlier) | | 0.01 ng/L | | Keith et al. 1976
Oahu, Hawaii | Drinking water | 1970–1971 | | 0.2 ng/L | | Bevenue et al. 1972
Ozark Plateaus Province of Arkansas, Kansas, Missouri, and Oklahoma | Groundwater | April–September 1993 | 28 and 32 ng/L | | Detected in two samples from domestic wells | Adamski and Pugh 1996
Connecticut | Drinking water well | Not reported (1999 or earlier) | | 60 ng/L | | Eitzer and Chevalier 1999
United States | Drinking water | 1998–2005 | 1–690 ng/L | 62 ng/L | Samples collected from 44 states across the United States; ranges and averages do not include samples reported to be below the method reporting level | EPA 2010
Washington, D.C. and Denver, Colorado | Surface water | Not reported (1984 or earlier) | 52–100 ng/L | | | Cole et al. 1984
Niagara River | Surface water | 1980–1981 | | 2.1 ng/L | Mean of 99% samples | Kuntz and Warry 1983
Lake Michigan tributary streams | Surface water | Not reported (1974 or earlier) | ND–150 ng/L | | | EPA 1974
United States | Surface water | Not reported (1985 or earlier) | | Median: 20 ng/L | Detected in 27% of 4,505 samples | Staples et al. 1985
Lake Ontario | Surface water | 1983 | 0.806–1.85 ng/L | | | Biberhofer and Stevens 1987
Patuxent River | Surface water | 1995 | 1.0 ng/L | | | Harman-Fetcho et al. 1999
Lake Superior | Surface water | Spring 1997 | | 0.38 ng/L | | Marvin et al. 2004
Lake Erie | Surface water | Spring 1998 | | 0.32 ng/L | | Marvin et al. 2004
Lake Ontario | Surface water | Spring 1998 | | 0.24 ng/L | | Marvin et al. 2004
York River estuary | Surface water | June 1998–April 1999 | ~0.04–0.21 ng/L | | Concentrations were higher in freshwater areas than areas with higher salinity | Padma and Dickhut 2002
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 110–6.6×10^5^ ng/L | 99,000 ng/L | Samples collected from 19 shallow wells; not detected (<20 ng/L) in 11 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 120–3.6×10^5^ ng/L | 73,000 ng/L | Samples collected from 15 deep wells; not detected (<20 ng/L) in 10 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Surface water near active pesticide reformulating and packaging facility | 2000 | 440–470 ng/L | 460 ng/L | Three samples collected from creek adjacent to the site; not detected (<20 ng/L) in one sample; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
δ-HCH
United States | Surface water | 1980–2006 | 0.00339–75,000 ng/L | 1.56 ng/L | Detected in 0.8% of 7,106 samples | WQP 2023 ^b^
United States | Surface water | 2020 | | ND | Not detected in 248 samples | WQP 2023 ^b^
United States | Surface water | 2021 | 0.48–1 ng/L | 0.72 ng/L | Detected in 3% of 221 samples | WQP 2023 ^b^
United States | Surface water | 2022 | 0.44–3.7 ng/L | 0.97 ng/L | Detected in 5% of 545 samples | WQP 2023 ^b^
United States | Surface water | 2023^d^ | | ND | Not detected in 5 samples | WQP 2023 ^b^
United States | Surface water Portland Harbor Superfund Site | 2004–2006 | 0.000508–1.67 | 0.14 | Detected in 14% of 190 samples | WQP 2023 ^b^
United States | Ground water | 1980–2006 | 20–300 ng/L | 4.8 ng/L | Detected in 1% of 2,417 samples | WQP 2023 ^b^
United States | Ground water | 2020 | | ND | Not detected in three samples; no data reported for 2021–2023^c^ | WQP 2023 ^b^
United States | Groundwater at EPA Region 10 Superfund Sites | 1987–2002 | | ND | Not detected in 391 samples | WQP 2023 ^b^
United States | Groundwater at Boomsnub Superfund Site | 1995 | | ND | Not detected in 18 samples | WQP 2023 ^b^
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 40–5.7×10^5^ ng/L | 74,000 ng/L | Samples collected from 19 shallow wells; not detected (<20 ng/L) in 8 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Groundwater below active pesticide reformulating and packaging facility | 2000 | 36–2.9×10^5^ ng/L | 26,000 ng/L | Samples collected from 15 deep wells; not detected (<20 ng/L) in 3 wells; mean and ranges do not reflect samples reported as not detected/below detection limit | Law et al. 2004
Northeastern Florida | Surface water near active pesticide reformulating and packaging facility | 2000 | 55–970 ng/L | 640 ng/L | Three samples collected from creek adjacent to the site | Law et al. 2004
HCH, mixture
Northeastern Florida | Groundwater below contaminated site | Not reported (2015 or earlier) | 30,000–4.2×10^5^ ng/L | | Range reported for α-, γ-, and δ-HCH | Chartrand et al. 2015

a Liquid unit conversion: 1 ng/L = 1 ppt = 0.001 ppb.

b Data collected by USGS monitoring stations across the United States; mean and ranges do not reflect samples reported as not detected/below detection limit.

c As of June 2023.

ND = not detected; USGS = U.S. Geological Survey

### 5.5.3 Sediment and Soil

HCH has been detected in soil and sediment as a result of agricultural use. Soil and sediment monitoring data are presented in Table 5-10. Data from the EPA’s WQP has been divided into two categories to reflect potential detection decreases as a result of the γ-HCH pesticide cancellation in 2006 (WQP 2021). A clear trend could not be discerned from the data, possibly due to the large ranges reflecting differences in land use. Most recent monitoring data report concentrations at the parts per billion range.

### 5.5.4 Other Media

HCH isomers have been detected in aquatic organisms; the results of these monitoring studies are summarized in Table 5-11. Data on terrestrial organism monitoring were not located. Schmitt et al. (1985) reported the results of a monitoring study of fish tissues from 107 freshwater stations in the United States from 1976 to 1981, which supported a decline in tissue occurrence of detectable α- and γ-HCH residues in aquatic organisms. α- and β-HCH have been detected in organisms as recently as 2018, however (WQP 2021). The most recent monitoring studies have detected HCH isomers in aquatic organisms in the parts per billion range.

Historically, as a result of pesticide use, γ-HCH was detected in meat, vegetables, and other food items, both imported to and produced in the United States. Due to the discontinued agricultural use of γ-HCH by the United States and many other countries, residues are typically no longer detected in food products. γ-HCH was detected in 5 out of 612 imported rice samples at a maximum concentration of 0.03 ppm during an FDA pesticide monitoring study conducted in 1993–1994 (Roy et al. 1997). A 10-year (1982–1991) FDA study of ready-to-eat foods commonly consumed in the United States showed that α-, β-, δ-, and γ-HCH were frequently detected (Rogers et al. 1995). The results of this study reported average concentrations of 0.0010, 0.0027, 0.0030, and 0.0012 ppm for α-, β-, δ-, and γ-HCH isomers, respectively, in 243 ready-to-eat foods. HCH isomers were also detected in the following feed types formulated for infants and toddlers and in adult diet foodstuffs: whole milk and other dairy products; meat, fish, and poultry; oils and fats; vegetables; and sugars and adjuncts (Gartrell et al. 1986a, 1986b).

γ-HCH residues were detected in fat samples of domestic farm animals collected in Ontario, Canada, in 1986–1988. Mean concentrations in fat from chickens, turkeys, beef, lamb, and pork ranged from 0.012 to 0.032 ppm; the mean concentration in hen eggs was 0.008 ppm (Frank et al. 1990). A pesticide residue screening program carried out by the H.E.B. Food Stores of San Antonio between 1989 and 1991 detected γ-HCH in 4 of 429 onion samples (detection limit 0.02 ppm); however, none of the positive samples exceeded the action level for this commodity (Schattenberg and Hsu 1992). γ-HCH was detected at levels of ≤10 ppm in 6 out of 5,784 fruit and vegetable commodities analyzed in Canada from 1992 to 1994 (Neidert and Saschenbrecker 1996). α-, β-, and γ-HCH were detected in butter samples from the United States at mean levels of 0.38, 0.42, and 0.78 ppb, respectively (Kalantzi et al. 2001). HCH isomers were also detected in butter samples from 20 other countries, with the highest levels being observed in a single butter sample from India with reported concentrations of 98, 108, and 164 ppb for α-, β-, and γ-HCH, respectively (Kalantzi et al. 2001).

Table 5-10 Soil and Sediment Monitoring Data for Hexachlorocyclohexanes (HCHs)

Locations | Geographic type | Date(s) | Range^a^ | Mean^a^ | Notes | Reference
α-HCH
Alabama | Soil | Not reported (1999 or earlier) | 0–0.269 µg/kg | | Detected in 26 of 39 soils from 6 regions | Harner et al. 1999
Sequoia National Park, Rocky Mountain National Park, Mt. Rainier National Park, Denali National Park, Noatak National Preserve, and Gates of the Arctic National Park and Preserve | Sediment core from deepest point in several lakes | 2003–2005 | <0.8 µg/kg | | Not detected | Genualdi et al. 2011
United States | Soil and sediment | 1978–2006 | 4.0×10^−5^–879 µg/kg | 3.0 µg/kg | Detected in 8% of 9,360 samples | WQP 2023 ^b^
United States | Soil and sediment | 2020–2021 | | ND | Not detected in 178 samples; no data reported for 2022–2023^c^ | WQP 2023 ^b^
United States | Soil and sediment at Lower Duwamish Waterway Superfund Site | 1991–2006 | 0.14–1.8 µg/kg | 0.59 µg/kg | Detected in 2% of 335 samples | WQP 2023 ^b^
United States | Soil/sediment at Portland Harbor Superfund Site | 1997–2006 | 0.00238–120 µg/kg | 1.6 µg/kg | Detected in 15% of 1,772 samples | WQP 2023 ^b^
United States | Soil at Delta 400 West Plume | 2004 | | ND | Not detected in 7 samples | WQP 2023 ^b^
β-HCH
United States | Soil and sediment | 1983–2006 | 4.0×10^−5^–4,230 µg/kg | 18 µg/kg | Detected in 8% of 8,106 samples | WQP 2023 ^b^
United States | Soil and sediment | 2020 | 0.032–0.39 µg/kg | 0.17 µg/kg | Detected in 4% of 142 samples | WQP 2023 ^b^
United States | Soil and sediment | 2021 | | ND | Not detected in 8 samples; no data reported for 2022–2023^c^ | WQP 2023 ^b^
United States | Soil and sediment at Lower Duwamish Waterway Superfund Site | 1991–2006 | 0.087–13 µg/kg | 4.1 µg/kg | Detected in 1% of 327 samples | WQP 2023 ^b^
United States | Soil/sediment at Portland Harbor Superfund Site | 1997–2006 | 0.00138–318 µg/kg | 3.9 µg/kg | Detected in 42% of 1,819 samples | WQP 2023 ^b^
United States | Soil at Delta 400 West Plume | 2004 | | ND | Not detected in 7 samples | WQP 2023 ^b^
γ-HCH
Alabama, Arkansas, Illinois, Iowa | Georgia, Soil | Not reported (1974 or earlier) | 10–150 µg/kg | 52 µg/kg | | Crockett et al. 1974
Alabama | Soil | Not reported (1999 or earlier) | 0–1.07 µg/kg | | Detected in 26 of 39 soils from 6 regions | Harner et al. 1999
Niagara River | Suspended sediment | Not reported (1983 or earlier) | | 2 µg/kg | Detection frequency 33% | Kuntz and Warry 1983
Lake Ontario | Settling particulates | 1982 | | 2.4 µg/kg | | Oliver and Charlton 1984
James River, Virginia | Creek sediments | 1976 | 7.3–8.5 µg/kg | | | Saleh et al. 1978
Gulf of Mexico | Sediment | 1987 | <0.02–1.74 µg/kg | 0.07 µg/kg | Detection frequency 19% | Sericano et al. 1990
Around the Great Lakes | Sediment | May 1989 | <0.10–0.99 µg/kg wet weight | | | Verbrugge et al. 1991
Indian River Lagoon, Florida | Sediment from impoundments along the river | Not reported (1992 or earlier) | 9.4–34.4 µg/kg | | 33 sediment samples from 11 impoundment | Wang et al. 1992
δ-HCH
United States | Soil and sediment | 1983–2006 | 0.0078–89.8 µg/kg | 3.4 µg/kg | Detected in 6% of 5,747 samples | WQP 2023 ^b^
United States | Soil and sediment | 2020–2021 | | ND | Not detected in 162 samples; no data reported for 2022–2023^c^ | WQP 2023 ^b^
United States | Soil and sediment at Lower Duwamish Waterway Superfund Site | 1991–2006 | 0.081–1,100 µg/kg | 160 µg/kg | Detected in 3% of 254 samples | WQP 2023 ^b^
United States | Soil/sediment at Portland Harbor Superfund Site | 1997–2006 | 0.00216–45.4 µg/kg | 1.3 µg/kg | Detected in 9% of 1,797 samples | WQP 2023 ^b^
United States | Soil at Delta 400 West Plume | 2004 | | ND | Not detected in 7 samples | WQP 2023 ^b^
HCH, mixture
South Carolina | 0–10 cm surface soils from cotton fields | November 1999 | 0.1–0.54 µg/kg dry weight | 0.27 µg/kg dry weight | Reported as sum of α-, β-, and γ-isomers; not detected (<0.1 µg/kg dry weight) in 10 of 16 samples; mean and ranges do not reflect samples reported as not detected/below detection limit | Kannan et al. 2003
Georgia | 0–10 cm surface soils from cotton fields | December 1999 | 0.16–0.49 µg/kg dry weight | 0.33 µg/kg dry weight | Reported as sum of α-, β-, and γ-isomers; not detected (<0.1 µg/kg dry weight) in 14 of 16 samples; mean and ranges do not reflect samples reported as not detected/below detection limit | Kannan et al. 2003
United States | Sediment | 2017 | 0.47–1.26 µg/kg | 0.75 µg/kg | HCH isomer or mixture not specified; detected in 19% of 42 samples | WQP 2023 ^b^

a Solid unit conversion: 1 µg/kg = 1 ppb.

b Data collected by USGS monitoring stations across the United States; mean and ranges do not reflect samples reported as not detected/below detection limit.

c As of July 2023.

ND = not detected; USGS = U.S. Geological Survey

Table 5-11 Organism Monitoring Data for Hexachlorocyclohexanes (HCHs)

Locations | Species | Date(s) | Range^a^ | Mean^a^ | Notes | Reference
α-HCH
Southwestern and Midwestern United States | Freshwater Fish | 1980–1981 | 0.03–0.04 ng/g | | Highest concentrations detected from 107 monitoring stations across the United States | Schmitt et al. 1985
United States | Freshwater fish | 1984 | NR–10 ng/g | <10 ng/g | | Schmitt et al. 1990
Louisiana section of the Mississippi River | Blue crab, cobia, flathead catfish, freshwater drum, long-nose gar, red drum, red snapper, river shrimp, small-mouth buffalo, spotted gar | 1990–1994 | | ND | | Watanabe et al. 2003
Louisiana section of the Mississippi River | Bigmouth buffalo | 1990–1994 | | 2.4 ng/g | Average detection in 1 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Blue catfish | 1990–1994 | 0.333–26.3 ng/g | | Range of average detections in 3 of 4 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Carp | 1990–1994 | | 31.1 ng/g | Range of average detections in 3 of 4 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Channel catfish | 1990–1994 | 1.83–7.23 ng/g | | Range of average detections in 2 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Crawfish | 1990–1994 | | 4.25 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Largemouth bass | 1990–1994 | | 1.00 ng/g | Average detection in 1 of 2 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Striped bass | 1990–1994 | | 2.88 ng/g | Average detection in 1 of 2 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White bass | 1990–1994 | | 1.44 ng/g | Average detection in 1 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White crappie | 1990–1994 | | 1.75 ng/g | Average detection in 1 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Southwestern Michigan | Adult green frogs | 1998 | | 0.02 ng/g | 0.04 ppb detected in juvenile frogs | Gilliland et al. 2001
Gulf of California | Clams (Chione californiensis) | Not reported (2015 or earlier) | <0.005–1.77 ng/g wet weight | | Detection frequency 16.7% in 1 of 3 study areas, not detected in other areas; adipose tissue samples; surrounding area has primarily agricultural activity | Vargas-Gonzalez et al. 2016
Lake Apopka, Florida | Largemouth bass (Micropterus salmoides) | March 2013 | | ND | Limit of quantification 0.1–0.5 ng/g wet weight | Dang et al. 2016
United States | Freshwater fish | 2020–2022 | | ND | Not detected in 253 samples; no data reported for 2023^b^ | WQP 2023 ^c^
β-HCH
Upper Steele Bayou, Mississippi | Fish | 1988 | ND–20 ng/g wet weight | | | Ford and Hill 1991
Upper Steele Bayou, Mississippi | Snakes | 1988 | | ND | | Ford and Hill 1991
Southwestern Michigan | Adult green frogs | 1998 | | 0.01 ng/g | Not detected in juvenile frogs | Gilliland et al. 2001
Louisiana section of the Mississippi River | Cobia, long-nose gar, red drum, red snapper | 1990–1994 | | ND | | Watanabe et al. 2003
Louisiana section of the Mississippi River | Bigmouth buffalo | 1990–1994 | 2.25–11.2 ng/g | | Range of average detection in 3 of 3 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Blue catfish | 1990–1994 | 3.67–8.33 ng/g | | Range of average detection in 3 of 4 sampling years; not detected in other year | Watanabe et al. 2003
Louisiana section of the Mississippi River | Blue crab | 1990–1994 | 4.00–11.0 ng/g | | Range of average detections in 2 of 2 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Carp | 1990–1994 | 5.00–11.3 ng/g | | Range of average detections in 2 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Channel catfish | 1990–1994 | 0.333–7.77 ng/g | | Range of average detections in 3 of 4 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Crawfish | 1990–1994 | | 27.5 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Flathead catfish | 1990–1994 | | 0.500 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Freshwater drum | 1990–1994 | | 0.333 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Largemouth bass | 1990–1994 | | 2.00 ng/g | Average detection in 1 of 2 sampling years; not detected in other year | Watanabe et al. 2003
Louisiana section of the Mississippi River | River shrimp | 1990–1994 | | 8.67 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Small-mouth buffalo | 1990–1994 | 0.25–2.00 ng/g | | Range of average detection in 3 of 4 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Spotted gar | 1990–1994 | | 39.0 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Striped bass | 1990–1994 | 5.50–57.9 ng/g | | Range of average detection in 2 of 2 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White bass | 1990–1994 | | 3.11 ng/g | Average detection in 1 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White crappie | 1990–1994 | 1.00–11.0 ng/g | | Range of average detection in 2 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Gulf of California | Clams (C. californiensis) | Not reported (2015 or earlier) | | ND | Limit of detection 0.01 ng/g wet weight; Adipose tissue samples; surrounding area has primarily agricultural activity | Vargas-Gonzalez et al. 2016
Lake Apopka, Florida | Largemouth bass (M. salmoides) | March 2013 | | ND | Limit of quantification 0.1–0.5 ng/g wet weight | Dang et al. 2016
United States | Freshwater fish | 2020 | | ND | Not detected in 172 samples | WQP 2023 ^c^
United States | Freshwater fish; Oncorhynchus kisutch | 2022 | 1.7–1.8 ng/g | 1.9 ng/g | Detected in 11% of 19 samples; detected only in Oncorhynchus kisutch (33% of 6 samples); no data reported for 2021 or 2023^b^ | WQP 2023 ^c^
γ-HCH
Gulf of Mexico | Oyster | 1987 | <0.25–9.06 ng/g | 1.74 ng/g | Detection frequency 80% | Sericano et al. 1990
United States | Freshwater fish | 1980–1981 | 0.02–0.03 ng/g | | Whole body concentrations were >0.01 ng/g at 1 of 107 monitoring stations | Schmitt et al. 1985
United States | Freshwater fish | 1984 | NR–40 ng/g | <10 ng/g | | Schmitt et al. 1990
Southwestern Michigan | Adult green frogs | 1998 | | 0.07 ng/g | Not detected in juvenile frogs | Gilliland et al. 2001
Louisiana section of the Mississippi River | Blue crab, channel catfish, cobia, crawfish, flathead catfish, freshwater drum, long-nose gar, red drum | 1990–1994 | | Not detected | | Watanabe et al. 2003
Louisiana section of the Mississippi River | Bigmouth buffalo | 1990–1994 | 1.00–1.80 ng/g | | Range of average detection in 2 of 3 sampling years; not detected in other year | Watanabe et al. 2003
Louisiana section of the Mississippi River | Blue catfish | 1990–1994 | 2.25–26.5 ng/g | | Range of average detection in 3 of 4 sampling years; not detected in other year | Watanabe et al. 2003
Louisiana section of the Mississippi River | Carp | 1990–1994 | 0.714–5.00 ng/g | | Range of average detections in 2 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Largemouth bass | 1990–1994 | | 1.00 ng/g | Average detection in 1 of 2 sampling years; not detected in other year | Watanabe et al. 2003
Louisiana section of the Mississippi River | Red snapper | 1990–1994 | | 0.333 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | River shrimp | 1990–1994 | | 1.67 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Small-mouth buffalo | 1990–1994 | 0.250–7.00 ng/g | | Range of average detection in 4 of 4 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Spotted gar | 1990–1994 | | 857 ng/g | Average detection in 1 of 1 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | Striped bass | 1990–1994 | 0.500–1.25 ng/g | | Range of average detection in 2 of 2 sampling years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White bass | 1990–1994 | | 7.56 ng/g | Average detection in 1 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Louisiana section of the Mississippi River | White crappie | 1990–1994 | 0.750–1.20 ng/g | | Range of average detection in 2 of 3 sampling years; not detected in other years | Watanabe et al. 2003
Gulf of California | Clams (C. californiensis) | Not reported (2015 or earlier) | | Not detected | Limit of detection 0.005 ng/g wet weight; adipose tissue samples; surrounding area has primarily agricultural activity | Vargas-Gonzalez et al. 2016
Lake Apopka, Florida | Largemouth bass (M. salmoides) | March 2013 | | 0.8 ng/g wet weight (gastrointestinal tract); 1.6 ng/g wet weight (liver); 2.6 ng/g wet weight (kidney); 0.8 ng/g wet weight (spleen); 4.8 ng/g wet weight (brain); 1.8 ng/g wet weight (gonad); 1.3 ng/g wet weight (muscle) | 117.8 ng/g lipid (gastrointestinal tract); 29.4 ng/g lipid (liver); 742.6 ng/g lipid (kidney); 102.0 ng/g lipid (spleen); 144.1 ng/g lipid (brain); 77.6 ng/g lipid (gonad); 125.2 ng/g lipid (muscle) | Dang et al. 2016
δ-HCH
Southwestern Michigan | Adult green frogs | 1998 | | 0.03 ng/g | Not detected in juvenile frogs | Gilliland et al. 2001
Gulf of California | Clams (C. californiensis) | Not reported (2015 or earlier) | <0.01–1.97 ng/g wet weight | | Detection frequency 16.7% in 1 of 3 study areas, not detected in other areas; adipose tissue samples; surrounding area has primarily agricultural activity | Vargas-Gonzalez et al. 2016
Lake Apopka, Florida | Largemouth bass (M. salmoides) | March 2013 | | Not detected | Limit of quantification 0.1–0.5 ng/g wet weight | Dang et al. 2016
United States | Freshwater fish | 2020 | | ND | Not detected in 191 samples; no data reported for 2022–2023^b^ | WQP 2023 ^c^

a Organism concentration unit conversion: 1 ng/g = 1 ppb.

b As of June 2023.

c Data collected by USGS monitoring stations across the United States; mean and ranges do not reflect samples reported as not detected/below detection limit.

Not detected; NR = not reported; USGS = U.S. Geological Survey

Based on the most recent pesticide residue monitoring results published by the FDA from 2018, no γ-HCH residues were detected on food products produced in or imported to the United States (FDA 2020a). The products sampled were broadly encompassing of domestic and imported food and agricultural commodities, and included fruits, vegetables, grains, beans, nuts, honey, milk, and meat, amongst many other categories. A recent study, however, detected averages of 0.22 ppb α-HCH and 0.77 ppb γ-HCH in tobacco products (n=20; cigarettes from one pack were pooled for analysis) purchased in the United States (Quadroni and Bettinetti 2019). It is unclear if these products were domestic or imported.

Strategies exist to reduce pesticide residues on food products. γ-HCH residues on tomatoes decreased by 23.9% 15 days after application of the pesticide (from 0.1956 to 0.1488 ppm). Processing the tomatoes (e.g., pureeing, making tomato juice) reduced the residue levels by 100% after the waiting period; however, washing the tomatoes reduced the residues by up to 55.9% (Bessar et al. 1991). An analysis of pesticide residues in green coffee and after roasting indicated that technical-grade HCH was found in green coffee at concentrations ranging from <0.005 to 0.204 ppm. However, storage and roasting reduced the pesticide residues by 60–67% and up to 98%, respectively, with darker roasting resulting in the greatest reduction (McCarthy et al. 1992).

## 5.6 GENERAL POPULATION EXPOSURE

Exposure of the general population to HCH has declined steadily since its use as a pesticide was discontinued. Human exposure to γ-HCH may result from environmental exposures to contaminated water or soil, or possible ingestion of small amounts in drinking water. Historically, γ-HCH and its most persistent metabolite, β-HCH, have been detected in blood, adipose tissue, and breast milk. Based on the most recent U.S. population survey, γ-HCH is generally no longer detected in blood, but β-HCH still is (CDC 2019). This is consistent with the decreased general population exposure to γ-HCH as a pesticide. Medicinal exposure to γ-HCH can occur from prescription scabies and lice treatments. An analysis of data from 238 families in Missouri between June 1989 and March 1990 indicated that 9.2% of the families reported using Kwell shampoo (contains γ-HCH) for lice control on children (Davis et al. 1992). In general, accidental or intentional ingestion of these products would lead to the highest exposures. Worker exposure constitutes the next highest exposure population, although worker exposure is decreasing in both the number of workers exposed and the levels of exposure. Lastly, the general population receives the lowest levels, which occur mainly from ingestion of foods and water with γ-HCH residues. Living near a waste disposal site contaminated with γ-HCH will also increase the likelihood of exposure.

Ingestion of food containing pesticide residue, historically a significant route of exposure, is no longer expected to be a likely route of non-medicinal human exposure to γ-HCH. During studies conducted between 1982 and 1991, γ-HCH was detected in 4–6% of the foods collected in eight market basket surveys from different regions of the United States (Gunderson 1988, 1995a, 1995b). The most recent results of this survey reported no detections (limit of detection 0.4–2.8 ppb) in foods surveyed in 2017 for α-, β-, γ-, or δ-HCH (FDA 2020b). γ-HCH was also not detected in domestic or imported food products in the United States by the FDA (FDA 2020a). Foods representative of consumption patterns by eight infant and adult population groups were prepared for consumption prior to analysis in a revision to FDA’s Total Diet Studies methodology. The estimated mean daily intakes (ng/kg body weight/day) of α-, β-, and γ-HCH for these groups continuously decreased between all study periods (1982–1984, 1984–1986, and 1986–1991). From 1986 to 1991 daily intakes ranged from 0.5 to 2.7 ng/kg/day for α-HCH, were all <1 ng/kg/day for β-HCH, and ranged from 0.6 to 3.2 ng/kg/day for γ-HCH (Gunderson 1988, 1995a, 1995b). An estimated γ-HCH daily dietary intake based on 2003 FDA pesticide residue monitoring data for fruits and vegetables was determined to be trace only for domestic produce and 0.00754 ng/kg/day for imported produce (Katz and Winter 2009). While HCH isomers have been previously detected in freshwater fish, lindane was not detected (<0.25 ng/mL) in the serum of Detroit area anglers who consumed their catches, in 2013 (Wattigney et al. 2022). Because γ-HCH and its isomers were not detected in most recently available food monitoring data, current daily intake can be assumed to be negligible.

A small degree of exposure to γ-HCH from drinking water may be possible. α-, β-, and δ-HCH have been detected in recent surface water samples, although these may not represent drinking water sources (WQP 2023). γ-HCH was detected in drinking water samples collected for the 1998 to 2005 EPA 6-year review of drinking water quality (EPA 2010). Data for HCH were not reported for the most recent available period, 2006–2011.

Contaminated soils, which have been sampled as recently as 2021, may present another exposure pathway (WQP 2023). Studies in which soils containing 10 ppm radiolabeled γ-HCH were added to human skin samples at quantities that exceeded monolayer coverage (5 mg soil/cm^2^ skin) demonstrated mean γ-HCH absorptions of 1.04% from sandy soils and 1.64% from silt soils (Duff and Kissel 1996). However, data from soil absorption studies can vary due to factors such as the amount of soil added to skin, exposure time, and possible evaporation of the contaminant.

The results of biomonitoring studies can be used as indicators of human exposures to HCH. The National Human Adipose Tissue Survey (NHATS) conducted in 1982 showed that β-HCH (the most prevalent HCH isomer in fatty tissue) was detected in 87% of 46 composite samples at concentrations <19–570 ng/g (ppb) (EPA 1986). It was detected most often in postmortem samples collected from individuals from the southern United States. In another survey conducted in 1970–1975, β-HCH was detected in >90% of the postmortem human adipose tissue samples at an average level of 300 ppb (Kutz et al. 1979). In a review of the NHATS data available from 1970 to 1983, EPA (1985c) reported that the estimated 1983 national median level of β-HCH was 80 ppb, in comparison to the historic level of 140 ppb. The median level had decreased over time, but the compound continued to be detected in nearly 100% of the population surveyed. Median levels were highest in the South census region and tended to increase with age but had not been found to differ across the sexes or racial groups. A further analysis of the NHATS data indicated that average β-HCH concentrations in fat had decreased from 0.45 ppm in 1970 to approximately 0.16 ppm since 1981 (Kutz et al. 1991). In a similar study in Japan, levels of HCHs in the adipose tissue of Japanese males increased from the late 1940s to 1966, coinciding with an increased annual production of HCH, and began dropping when HCHs were banned in 1971, with only the only the more persistent β-HCH isomer detected after 1974 (Loganathan et al. 1993). Recent adipose tissue concentrations in the United States were not located, but the trend towards lower concentrations may have continued following the discontinued use of γ-HCH as a pesticide.

A comparison of the levels of α- and β-HCH in the whole blood and biopsy fat of 25 patients showed median levels of <0.04 ng/g (maximum, <0.04 ng/g [LOD]) and 0.13 ng/g (maximum, 2.60 ng/g) for the blood and 1.1 ng/g (maximum, 9.6 ng/g) and 18.0 ng/g (maximum, 748.6 ng/g) for the fat tissue, respectively (Mes 1992). A further comparison of β-HCH levels in breast milk and adipose tissue samples was made for populations living near the Great Lakes (Canada only) and in other Canadian regions. Mean β-HCH levels in breast milk (0.6 ng/g, n=70 samples) and adipose tissue (23.4 ng/g, n=16 samples) were lower near the Great Lakes than in other parts of Canada (0.8 [n=305 samples] and 30.8 ng/g [n=90 samples], respectively) (Mes and Malcolm 1992). In addition, studies indicate that γ-HCH can also be present in breast milk at a previously reported average level of 0.006 ppm in Alberta, Canada (Currie et al. 1979). In a study of 50 donors of breast milk in Oahu, Hawaii, Takahashi et al. (1981) demonstrated HCH in 82% of the samples at a mean level of 81 ppb within a range of 0–480 ppb, expressed in terms of extractable lipid.

γ-HCH was one of the most frequently detected pesticides in the blood of Virginia residents, although the number of individuals sampled was not identified (Griffith and Blanke 1975). γ-HCH blood concentrations were the highest in residents of the middle age group (41–60 years). Some of the frequency of γ-HCH occurrence in the state was attributed to its common use in commercial vaporizers and its presence in cigarette smoke (Griffith and Blanke 1975). NHANES analyzed blood and urine specimens for the presence of HCH isomers. β-HCH was detected in approximately 13.9% of the U.S. population (12–74 years) in the Northeast, Midwest, and South. The median level for the 91% quantifiable positive results was 1.7 ppb (Murphy and Harvey 1985).

In a more recent study (1999–2000) of pesticide serum concentrations in pregnant Latina women living in an agricultural community in California, median serum levels were 36.9 ng/g lipid for β-HCH and 1.1 ng/g lipid for γ-HCH (Bradman et al. 2007). The median serum concentration of β-HCH was 5.9 ng/g lipid in 48 mothers enrolled in the California Childhood Leukemia Study in 2006–2007 (Whitehead et al. 2015). Maternal and blood cord samples were collected predominantly from Latina women, who were in their second or third trimester of pregnancy, as part of a study from October 2010 to June 2011 in San Francisco, California. Sixty-seven percent of maternal blood samples were above the method detection limit for β-HCH (5 ng/L wet weight or 0.005 ng/g wet weight). The lipid adjusted median cord:maternal serum ratio was 1.0, suggesting equivalent exposures for the fetus and the mother. (Morello-Frosch et al. 2016). In another study of 10 whole blood samples obtained from a blood donation center in Palo Alto, California, α-HCH was detected in all samples, β- and δ-HCH were detected in 60% of samples, and γ-HCH was detected in 80% of samples. Whole blood concentrations were 0.291–0.828, 0.544–1.15, 0.250–0.694, and 0.550–1.26 ng/g for α-, β-, γ-, and δ-HCH, respectively (Hao et al. 2020). Because HCH is persistent and can be transported long distances, its isomers have been detected in peoples living near the Arctic Circle. In 2019, β-HCH was detected in 59% of plasma samples (n = 54) from people in Old Crow, Canada, which is predominantly Vuntut Gwitchin First Nation people (Drysdale et al. 2021).

The geometric mean was below the detection limit (0.01 ng/L or 9.8×10^−6^ ng/g) with a 95^th^ percentile of 8.3×10^−5^ ng/g (0.085 ng/L; 13,000 ng/g lipid adjusted). γ-HCH was not detected (Drysdale et al. 2021).

The Centers for Disease Control and Prevention (CDC) completed its Fourth National Report on Human Exposure to Environmental Chemicals that was derived from data obtained from NHANES (CDC 2019). The first report on 27 chemicals was issued in March 2001. This fourth report, released in January 2019, presents blood and urine levels of environmental chemicals from a sample of people who represent the noninstitutionalized, civilian U.S. population during 2-year study periods over 1999–2016. Lipid serum levels of β- and γ-HCH from the most recent available study periods, 2015–2016 and 2011–2012, respectively, are summarized in Table 5-12. Serum monitoring was not conducted in the following NHANES study periods.

Table 5-12 Geometric Mean of the Serum Concentration (ng/g) of β-Hexachlorocyclohexane (β-HCH) (2015–2016) and γ-Hexachlorocyclohexane (γ-HCH) (2011–2012) in the U.S. Population

Population group (sex, age) | Geometric mean | Unadjusted standard error | Sample size (pools)^a^
β-HCH
Non-Hispanic white
Male, 12–19 years | NA^b^ | NA | 7
Male, 20–39 years | NA | NA | 10
Male, 40–59 years | 0.012 | 0.001 | 10
Male, ≥60 years | 0.03 | 0.004 | 14
Female, 12–19 years | NA | NA | 5
Female, 20–39 years | NA | NA | 11
Female, 40–59 years | 0.015 | 0.002 | 9
Female, ≥60 years | 0.095 | 0.026 | 13
Non-Hispanic black
Male, 12–19 years | NA | NA | 5
Male, 20–39 years | NA | NA | 7
Male, 40–59 years | 0.013 | 0.002 | 7
Male, ≥60 years | 0.017 | 0.001 | 7
Female, 12–19 years | NA | NA | 4
Female, 20–39 years | NA | NA | 9
Female, 40–59 years | 0.018 | 0.002 | 12
Female, ≥60 years | 0.095 | 0.014 | 7
Mexican American
Male, 12–19 years | NA | NA | 6
Male, 20–39 years | 0.011 | 0.002 | 7
Male, 40-59 years | 0.027 | 0.005 | 4
Male, ≥60 years | 0.058 | 0.01 | 5
Female, 12–19 years | NA | NA | 5
Female, 20–39 years | 0.016 | 0.003 | 6
Female, 40–59 years | 0.055 | 0.006 | 8
Female, ≥60 years | 0.16 | 0.037 | 7
All Hispanic
Male, 12–19 years | NA | NA | 9
Male, 20–39 years | 8.86 | 1.79 | 11
Male, 40–59 years | 17.6 | 3.9 | 9
Male, ≥60 years | 81.2 | 13 | 9
Female, 12–19 years | NA | NA | 8
Female, 20–39 years | 11.9 | 2 | 11
Female, 40–59 years | 52.5 | 5.3 | 13
Female, ≥60 years | 135 | 22 | 13
Asian
Male, 12–19 years | 0.058 | 0.015 | 3
Male, 20–39 years | 0.391^c^ | 0.127 | 5
Male, 40–59 years | 0.488 | 0.114 | 4
Male, ≥60 years | 0.805 | 0.108 | 3
Female, 12–19 years | 0.056 | 0.007 | 3
Female, 20–39 years | 0.496^c^ | 0.225 | 4
Female, 40–59 years | 0.166^c^ | 0.078 | 5
Female, ≥60 years | 1.2 | 0.11 | 3
γ-HCH
Non-Hispanic white
Male, 12–19 years | NA | NA | 6
Male, 20–39 years | NA | NA | 12
Male, 40–59 years | NA | NA | 12
Male, ≥60 years | NA | NA | 12
Female, 12–19 years | NA | NA | 5
Female, 20–39 years | NA | NA | 13
Female, 40–59 years | NA | NA | 11
Female, ≥60 years | NA | NA | 14
Non-Hispanic black
Male, 12–19 years | NA | NA | 7
Male, 20–39 years | NA | NA | 9
Male, 40–59 years | NA | NA | 7
Male, ≥60 years | NA | NA | 9
Female, 12–19 years | NA | NA | 6
Female, 20–39 years | NA | NA | 8
Female, 40–59 years | NA | NA | 8
Female, ≥60 years | NA | NA | 8
Mexican American
Male, 12–19 years | NA | NA | 5
Male, 20–39 years | NA | NA | 4
Male, 40–59 years | NA | NA | 4
Male, ≥60 years | NA | NA | 2
Female, 12–19 years | NA | NA | 4
Female, 20–39 years | NA | NA | 4
Female, 40–59 years | NA | NA | 3
Female, ≥60 years | NA | NA | 3
All Hispanic
Male, 12–19 years | NA | NA | 7
Male, 20–39 years | NA | NA | 8
Male, 40–59 years | NA | NA | 7
Male, ≥60 years | NA | NA | 6
Female, 12–19 years | NA | NA | 7
Female, 20–39 years | NA | NA | 8
Female, 40–59 years | NA | NA | 7
Female, ≥60 years | NA | NA | 7
Asian
Male, 12–19 years | NA | NA | 3
Male, 20–39 years | NA | NA | 6
Male, 40–59 years | NA | NA | 6
Male, ≥60 years | NA | NA | 4
Female, 12–19 years | NA | NA | 4
Female, 20–39 years | NA | NA | 6
Female, 40–59 years | NA | NA | 6
Female, ≥60 years | NA | NA | 3

a Each pool contained serum from eight people.

b NA = not available; proportion of results below limit of detection (1.3 ng/g lipid for β-HCH and 0.92 ng/g lipid for γ-HCH) was too high to provide a valid result.

c Standard error of the mean is >30%.

^a^Source: CDC 2019

Factors such as age, dietary habits, and residence can influence the body burden of γ-HCH in exposed individuals. In one study, it was shown that women between the ages of 26 and 34 years who lived in a rural area of India and were nonvegetarians tended to show higher body levels of γ-HCH than other Indian women who lived in an urban area or who were vegetarians (Saxena et al. 1981a). The higher levels of γ-HCH in women at an older child-bearing age suggest that a longer life span may cause a greater accumulation of pesticide in the body. Higher pesticide levels were found in mutton, eggs, and chicken, which are common in nonvegetarian meals; therefore, there tended to be a higher level of γ-HCH in the bodies of nonvegetarians. In another study, when corrected for age and BMI, vegans had an almost statistically significantly lower (p=0.076) mean β-HCH plasma concentration, not adjusted for lipids, than omnivores. Mean β-HCH plasma concentrations were 6.151 ng/g lipid for vegans and 5.720 ng/g lipid for omnivores (Arguin et al. 2010). In a study of hair samples, 460 ng/g γ-HCH was detected in samples from people who worked as pesticide applicators and 40 ng/g γ-HCH was detected in samples from people who lived close to farms in Atlanta, Georgia. Hair collected from people in Houston, Texas, representing urban environmental exposure, had 1,500 ng/g γ-HCH detected (Smith-Baker and Saleh 2011). The study authors did not suggest an explanation for the higher levels in the samples from environmentally exposed persons in Houston, Texas compared with levels in pesticide applicators in Atlanta, Georgia; however, the sample sizes were very small (eight applicators and eight each environmentally exposed persons in Atlanta and Houston). In addition, the ages of the volunteers from whom hair samples were collected were not reported, and hair from older individuals could have higher accumulation of γ-HCH. Further, there was no information on whether any volunteers had previous exposure to γ-HCH applied to the scalp for treatment of lice.

A study conducted in Colorado indicated, in general, that no quantitative relationships were demonstrated between pesticide levels in household dust and pesticide levels in blood. However, γ-HCH levels in blood sera in a pesticide formulator (16.8 ng/g) and his wife (5 ng/g) were found to be elevated in a household in which dust levels measured 5.85 ng/g (Starr et al. 1974). It is possible that the γ-HCH found in the wife’s blood and in the household came from the clothes and person of the pesticide formulator.

The Nonoccupational Pesticide Exposure Study (NOPES) conducted by EPA was based on the Total Exposure Assessment Methodology (TEAM) approach to exposure estimation. NOPES was designed to provide estimates of nonoccupational exposure to 32 household pesticides in the United States. Samples were collected at two locations: (1) Jacksonville, Florida, an area representative of high pesticide usage; and (2) Springfield/Chicopee, Massachusetts, an area of low-to-moderate pesticide usage. Detectable levels of γ-HCH were found in the personal air samples of 32–70% of the Jacksonville sample population; the range of mean concentrations in the air samples was 7–22 ng/m^3^. For the Springfield population, detectable levels of γ-HCH were found in personal air samples collected from 8–10% of the population, with mean concentrations of 0.7–5 ng/m^3^ (EPA 1990).

## 5.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

The populations with the most potential for chronic-duration exposure to HCH are workers who work at facilities that produce, process, or use γ-HCH. Exposure of the general population to γ-HCH tends to be low because federal regulations limiting its use have taken effect. However, γ-HCH is available in some prescription medications (e.g., shampoos, lotions), and the possibility of exposure may arise from use of these products. Individuals living near hazardous waste sites contaminated with HCH may also be exposed.

Historically, the largest occupational exposures came from people who work with pesticides. A study on occupational pesticide exposure of commercial seed-treating applicators was conducted in Montana (Grey et al. 1983). No exposure was detectable on the chest and arm pads, but γ-HCH was detected on the hands and on the respirator pads. Workers involved with γ-HCH application complained of nasal irritation if they did not wear a respirator or mask. The α-, β-, γ-, and δ-isomers of HCH have been detected in the blood serum and adipose tissue of individuals occupationally exposed to HCH in pesticide formulation. Serum levels of <0.5 ppb–1 ppm α-HCH, <0.9 ppb–0.72 ppm β-HCH, <0.7 ppb–0.17 ppm γ-HCH, and 0.002–0.16 ppm δ-HCH have been detected in exposed workers (Baumann et al. 1980; Kashyap 1986; Morgan and Lin 1978; Nigam et al. 1986). Mean adipose tissue levels of 5.8 mg α-HCH/kg, 45.6 mg β-HCH/kg, and 3.1 mg γ-HCH/kg have also been reported in exposed workers (Baumann et al. 1980).

A number of case reports (e.g., Bhalla and Thami 2004; Daud et al. 2010; Juan et al. 2004; Paul et al. 2013; Shah et al. 2013; Ramabhatta et al. 2014; Wiles et al. 2015; Yu et al. 2015) have documented toxic effects in humans overexposed to γ-HCH through excessive dermal application or accidental or intentional ingestion of products used to treat scabies and head lice; effects observed in these studies are described in Chapter 2.