# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

HCH consists of eight isomers (Safe 1993). Only γ-HCH, α-HCH, β-HCH, and δ-HCH are of commercial significance and considered in this profile. The pesticide lindane refers to products that contain >99% γ-HCH. The α-, β-, and δ-isomers, as well as technical-grade HCH are not synonymous with γ-HCH (Farm Chemicals Handbook 1993). Technical-grade HCH (CAS Registry Number 608-73-1) is not an isomer of HCH, but rather a mixture of several isomers; it consists of approximately 60–70% α-HCH, 5–12% β-HCH, 10–15% γ-HCH, 6–10% δ-HCH, and 3–4% ε-HCH (Kutz et al. 1991). Information regarding the chemical identities of α-, β-, γ-, and δ-HCH is located in Table 4-1.

Table 4-1 Chemical Identity of Hexachlorocyclohexane Isomers^a^

Characteristic | α-Hexachlorocyclohexane | β-Hexachlorocyclohexane
Synonym(s) and registered trade name(s) | 1-alpha, 2-alpha, 3-beta, 4-alpha, 5-beta, 6-beta-benzene-trans-hexachloride; alpha-1,2,3,4,5,6-hexachlorocyclohexane; alpha-benzene hexachloride; alpha-BHC; alpha-HCH; alpha-hexachloran; alpha-hexachlorane; alpha-hexachlorocyclohexane; alpha-lindane; benzenehexachloride-alpha-isomer; cyclohexane 1,2,3,4,5,6-(alpha, DL); cyclohexane 1,2,3,4,5,6-hexachloro, alpha-; cyclohexane 1,2,3,4,5,6-hexachloro-, alpha-isomer; cyclohexane, alpha-1,2,3,4,5,6-hexachloro; ENT 9232 | 1-alpha, 2-beta, 3-alpha, 4-beta, 5-aplha, 6-beta-hexachlorocyclohexane; beta 1,2,3,4,5,6-hexachlorocyclohexane; beta-benzenehexachloride; beta-BHC; beta HCH; beta-hexachloran; beta-hexachlorobenzene; beta-lindane; cyclohexane, 1,2,3,4,5,6-hexachloro-, beta-; cyclohexane, 1,2,3,4,5,6-hexachloro-, beta-isomer; cyclohexane, 1,2,3,4,5,6-hexachloro-, trans-; cyclohexane, beta-1,2,3,4,5,6-hexachloro-; ENT 9233; trans-alpha-benzenehexachloride
Chemical formula | C_6_H_6_Cl_6_ | C_6_H_6_Cl_6_
SMILES | C1(C(C(C(C(C1Cl)Cl)Cl)Cl)Cl)Cl | C1(C(C(C(C(C1Cl)Cl)Cl)Cl)Cl)Cl
Chemical structure | [image] | [image]
CAS Registry Number | 319-84-6 | 319-85-7

Characteristic | γ-Hexachlorocyclohexane | δ-Hexachlorocyclohexane
Synonym(s) and registered trade name(s) | Lindane; 1-alpha, 2-alpha, 3-beta, 4-alpha, 5-alpha, 6-beta-hexachlorocyclohexane; benzene hexachloride-gamma-isomer; BHC; cyclohexane 1,2,3,4,5,6-hexachloro-gamma-isomer; ENT 7796; gamma-benzene hexachloride; gamma-BHC; gamma-hexachlorocyclohexane; gamma-1,2,3,4,5,6-hexa-chlorocyclohexane; gamma-HCH; gamma-lindane; HCH; HCCH; hexachlorocyclohexane, gamma-isomer; 1,2,3,4,5,6-hexachlorocyclohexane, gamma-isomer, Etan 3G (Diachem S.P.A.); Forlin; Gamaphex; Isotox (Chevron Chemical Co.); Germate Plus (Gustafson Inc.); Gamma-Mean 400 and Gamma Mean L. (Oregon-California Chemicals, Inc.); Hammer (Exsin Industries); Lindagam; Novigam; Silvanol; Kwell | 1-alpha,2-alpha,3-alpha, 4-beta, 5-alpha, 6-beta-hexachlorocyclohexane; cyclohexane, 1,2,3,4,5,6-hexachloro-, delta-isomer; cyclohexane, delta-1,2,3,4,5,6-hexachloro-; delta-(AEEEEE)-1,2,3,4,5,6-hexachlorocyclohexane; delta-benzenehexachloride; delta-BHC; delta-HCH; delta-1,2,3,4,5,6-hexachlorocyclohexane; delta-lindane; ENT 9234
Chemical formula | C_6_H_6_Cl_6_ | C_6_H_6_Cl_6_
SMILES | C1(C(C(C(C(C1Cl)Cl)Cl)Cl)Cl)Cl | C1(C(C(C(C(C1Cl)Cl)Cl)Cl)Cl)Cl
Chemical structure | [image] | [image]
CAS Registry Number | 58-89-9 | 319-86-8

a All information obtained from NLM 2021.

CAS = Chemical Abstracts Service; SMILES = Simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of α-, β-, γ-, and δ-HCH is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Hexachlorocyclohexane Isomers

Property | α-Hexachlorocyclohexane (CAS 319-84-6) | β-Hexachlorocyclohexane (CAS 319-85-7) | γ-Hexachlorocyclohexane (CAS 58-89-9) | δ-Hexachlorocyclohexane (CAS 319-86-8)
Molecular weight | 290.83^a^ | 290.83^a^ | 290.83^a^ | 290.83^a^
Color | Brownish to white^b^ | No data | White^c^ | No data
Physical state | Crystalline solid^b^; monoclinic prisms^a^ | Crystalline solid^a,d^ | Crystalline solid^d^; monoclinic prisms^b^ | Fine plates^a,c^
Melting point | 159–160°C^a^ | 314–315°C^a^ | 112.5°C^a,e^ | 141–142°C^a^
Boiling point | 288°C at 760 mmHg^b^ | 60°C at 0.5 mmHg^a^ | 323.4°C at 760 mmHg^b^ | 60°C at 0.36 mmHg^a^
Density (g/cm^3^) | 1.87 at 20°C^a^ | 1.89 at 19°C^a^ | 1.89 at 19°C^f^ | No data
Odor | Phosgene-like odor^b^ | No data | Slightly musty odor^b^ | No data
Odor threshold:
Water | 0.88 ppm for unspecified purity^g^ | 0.00032 mg/kg^h^ | 12 mg/kg^h^ | No data
Air | No data | No data | No data | No data
Solubility:
Water | 10 ppm^i^; 69.5 mg/L at 28°C^j^ | 5 ppm^k^ | 17 ppm^k^; 7.3 mg/L at 25°C^b^ | 10 ppm^j^
Organic solvents | Soluble in alcohol^j^; 1.8 g/100 g in ethanol^i^; 6.2 g/100 g in ether^j^ | 1.1 g/100 g in ethanol; 1.8 g/100 g in ether; 1.9 g/100 g in benzene^i^ | 6.4 g/100 g in ethanol; 20.8 g/100 g in ether; 28.9 g/100 g in benzene^i^ | 24.4 g/100 g in ethanol; 35.4 g/100 g in ether; 41.4 g/100 g in benzene^i^
Partition coefficients:
Log K_ow_ | 3.8^l^ | 3.78^l^ | 3.72^l^ | 4.14^l^
Log K_oc_ | 3.57^f^ | 3.57^m^ | 3.0^m^; 3.57^f^ | 3.8^f^
Vapor pressure | 4.5×10^−5^ mmHg at 25°C^b^ | 3.6×10^−7^ mmHg at 20°C^b^ | 4.2×10^−5^ mmHg at 20°C^b^; 9.4×10^−6^ mmHg at 20°C^b^ | 3.5×10^−5^ mmHg at 25°C^b^
Henry’s law constant | 6.86×10^−6b^ | 4.5×10^−7m,n^ | 3.5×10^−6b^ | 2.1×10^−7o,p^
Autoignition temperature | No data | No data | Not flammable^b^ | No data
Flashpoint | No data | No data | Approximately 150°F (closed cup)^b^ | No data
Flammability limits | No data | No data | Not flammable^b^ | No data
Conversion factors^q^ | ppm to mg/m^3^ in air (20°C): ppm × 4.96 = mg/m^3^; mg/m^3^ to ppm in air (20°C): mg/m^3^ × 0.20 = ppm
Explosive limits | No data | No data | No data | No data

CAS = Chemical Abstracts Service

a Lide 1991.

b NLM 2021.

c Kirk and Othmer 1985.

d IARC 1979.

e Budavari et al. 1989.

f Weiss 1986.

g Fazzalari 1978.

h Verschueren 1983.

i Clayton and Clayton 1981.

j Kurihara et al. 1973.

k Hollifield 1979.

l Hansch and Leo 1995.

m Rippen et al. 1982.

n Veith et al. 1979.

o Pankow et al. 1984.

p EPA 1982a.

q Same for all isomers.