# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR HCH

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to HCH, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to HCH:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

The systematic review for this profile is divided into four sections:

1. Steps 1, 2, and 3 for α-, β-, and γ-HCH (Sections C.1, C.2, and C.3)
2. Steps 4, 5, 6, 7, and 8 for α-HCH (Sections C.4, C.5, C.6, C.7, and C.8)
3. Steps 4, 5, 6, 7, and 8 for β-HCH (Sections C.9, C.10, C.11, C.12, and C.13)
4. Steps 4, 5, 6, 7, and 8 for γ-HCH (Sections C.14, C.15, C.16, C.17, and C.18)

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to HCH. The inclusion criteria used to identify relevant studies examining the health effects of HCH are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

- Species; - Human; - Laboratory mammals
- Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
- Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of HCH. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for HCH released for public comment in January 2023. See Appendix B for the databases searched and the search strategy.

A total of 691 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of HCH.

Title and Abstract Screen. In the Title and Abstract Screen step, 691 records were reviewed; 45 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 299 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 299 documents (446 studies), 64 documents (70 studies) were included in the qualitative review.

The epidemiological database for HCH is extensive. To facilitate the selection and inclusion of human studies of greater utility in assessing the hazards of HCH, only studies meeting the criteria below were included in the Toxicological Profile.

- Exposure was assessed for individuals, either using a biomarker or through detailed individual history (i.e., ecological study designs were excluded);
- The study presented an effect estimate specific to one or more HCH isomers;
- The statistical analysis of the association was multivariate, with consideration of at least one potential covariate. Studies limited to bivariate analyses (i.e., Pearson or Spearman correlation coefficients) were not included, nor were studies in which the analysis was limited to a comparison between blood concentrations in cases and controls;
- The health outcomes evaluated in the study were not mechanistic in nature (e.g., oxidative stress, genotoxicity);
- Case reports and case series were included if there was clear evidence of exposure to one or more HCH isomers.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Documents for HCH isomers and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1 through 2-2).

There was only a single study of δ-HCH, and inadequate data for derivation of an MRL, so a systematic review of the data for this isomer was not undertaken.

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—α-HCH

Overviews of the potential health effect outcomes for α-HCH identified in human and animal studies are presented in Tables C-3 and C-4, respectively. There was a small number of human studies examining a handful of endpoints; the largest number of studies was devoted to developmental endpoints. The human studies used measures of α-HCH in blood or tissues to assess exposure, so the route is unknown; for the purpose of enumerations, these studies are considered to reflect oral exposure (e.g., through contaminated food). There were no inhalation or dermal animal studies of α-HCH, and very few oral studies. The available animal studies primarily examined liver effects and cancer. The most sensitive effect in animal studies were hepatic. Studies examining hepatic effects were carried through to Steps 4–8 of the systematic review. There were 70 studies (published in 64 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review. There were no human studies examining hepatic effects of α-HCH.

Table C-3 Overview of the Health Outcomes for α-Hexachlorocyclohexane Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Oral studies
Cohort
Cohort
Case control | | | | | | | | 2 | | | | 1 | 3 | | 4 | 2 | 5
Case control | | | | | | | | 1 | | | | 1 | 2 | | 3 | | 3
Population | | | | | | | | 2 | | | 4 | 1 | | 3 | 3 | 1
Population | | | | | | | | | | | 1 | | | 1 | 2
Case series
Case series
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for α-Hexachlorocyclohexane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration
Oral studies
Acute-duration | 1 | | | | | | 4 | | | | | | | | | 1
Acute-duration | | | | | | | 1 | | | | | | | | | 1
Intermediate-duration | 1 | | | | | | 10 | | | | | | 2 | | | | 6
Intermediate-duration | | | | | | | 7 | | | | | | | | | | 6
Chronic-duration | 1 | | | | | | 2 | 1 | | | | | | | | | 2
Chronic-duration | 1 | | | | | | 2 | 1 | | | | | | | | | 2
Dermal studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes studies evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—α-HCH

### C.5.1 Risk of Bias Assessment—α-HCH

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; - Were the comparison groups appropriate?
Confounding bias; - Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the α-HCH health effects studies (animal experimental studies) are presented in Table C-8. There were no observational epidemiology or human controlled experimental studies of α-HCH.

Table C-8 Summary of Risk of Bias Assessment for α-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Hepatic effects
Oral intermediate exposure
Sumida et al. 2007 (rat; 28 days) | − | − | + | + | − | + | + | ++ | NA | First
Ito et al. 1973 (mouse; 24 weeks) | − | − | + | + | + | ++ | + | ++ | NA | First
Ito et al. 1975 (rat; 24 or 48 weeks) | − | − | + | + | − | ++ | + | ++ | NA | First
Nagasaki et al. 1975 (rat; 24 weeks) | − | − | + | + | − | − | + | ++ | NA | Second
Nagasaki et al. 1975 (mouse; 24 weeks) | − | − | + | + | − | − | + | ++ | NA | Second
Nagasaki et al. 1975 (hamster; 24 weeks) | − | − | + | + | − | − | + | ++ | NA | Second
Tryphonas and Iverson 1983 (mouse; 50 weeks) | − | − | + | + | ++ | + | + | ++ | NA | First
Oral chronic exposure
Fitzhugh et al. 1950 (rat; 72 weeks) | − | − | + | + | ++ | + | + | ++ | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—α-HCH

Confidence in the body of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to HCH and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

In the case of α-HCH, the only available type of study was experimental animal.

### C.6.1 Initial Confidence Rating—α-HCH

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to α-HCH and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies are presented in Tables C-9, C-10, and C-11, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-9 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-10 Key Features of Study Design for Human Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-11 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies of hepatic effects observed in the animal experimental studies are presented in Table C-12.

Table C-12 Presence of Key Features of Study Design for α-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic effects
Oral intermediate exposure
Sumida et al. 2007 (rat; 28 days) | Yes | No | Yes | Yes | Moderate
Ito et al. 1973 (mouse; 24 weeks) | Yes | Yes | Yes | Yes | High
Ito et al. 1975 (rat; 24 or 48 weeks) | Yes | Yes | Yes | No | Moderate
Nagasaki et al. 1975 (rat; 24 weeks) | Yes | No | Yes | No | Low
Nagasaki et al. 1975 (mouse; 24 weeks) | Yes | Yes | Yes | No | Moderate
Nagasaki et al. 1975 (hamster; 24 weeks) | Yes | No | Yes | No | Low
Tryphonas and Iverson 1983 (mouse; 50 weeks) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Fitzhugh et al. 1950 (rat; 72 weeks) | Yes | No | Yes | Yes | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-13. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-13.

Table C-13 Initial Confidence Rating for α-HCH Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hepatic effects
Oral intermediate exposure
Animal studies
Sumida et al. 2007 (rat; 28 days) | Moderate | High
Ito et al. 1973 (mouse; 24 weeks) | High | High
Ito et al. 1975 (rat; 24 or 48 weeks) | Moderate | High
Nagasaki et al. 1975 (rat; 24 weeks) | Low | High
Nagasaki et al. 1975 (mouse; 24 weeks) | Moderate | High
Nagasaki et al. 1975 (hamster; 24 weeks) | Low | High
Tryphonas and Iverson 1983 (mouse; 50 weeks) | High | High
Oral chronic exposure
Animal studies
Fitzhugh et al. 1950 | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating—α-HCH

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hepatic effects are presented in Table C-14. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with α-HCH exposure is presented in Table C-15.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

Table C-14 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Hepatic effects:
Human studies | NA | NA | NA
Animal studies | High | +1 consistency, +1 magnitude | High

Table C-15 Confidence in the Body of Evidence for α-Hexachlorocyclohexane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hepatic | NA | High

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—α-HCH

In the seventh step of the systematic review of the health effects data for HCH, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for HCH is presented in Table C-16.

Table C-16 Level of Evidence of Health Effects for α-Hexachlorocyclohexane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies | NA
Animal studies
Hepatic | High | Health Effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—α-HCH

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for α-HCH are listed below and summarized in Table C-17.

Presumed Health Effects

- Hepatic
  ○ No information on hepatic effects in humans exposed to α-HCH.
  ○ High evidence level in animals including increased liver weight and histopathological lesions after oral exposure to α-HCH (Fitzhugh et al. 1950; Ito et al. 1973, 1975; Nagasaki et al. 1975; Sumida et al. 2007; Tryphonas and Iverson 1983).
  ○ Plausible mechanism based on increased oxidative stress markers in livers of animals exposed to low oral doses in vivo (Barros et al. 1991).

Table C-17 Hazard Identification Conclusions for α-Hexachlorocyclohexane

Outcome | Hazard identification
Hepatic effects | Presumed health effect

## C.9 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—β-HCH

Overviews of the potential health effect outcomes for β-HCH identified in human and animal studies are presented in Tables C-18 and C-19, respectively. Human studies examined a wide range of outcomes, with more studies of endocrine (thyroid hormone levels) developmental outcomes, other noncancer endpoints (diabetes and metabolic perturbations) and cancer than other outcomes. The human studies used measures of β-HCH in blood or tissues to assess exposure, so the route is unknown; for the purpose of enumerations, these studies are considered to reflect oral exposure (e.g., through contaminated food). Animal studies are limited to oral exposures, and the endpoints examined were limited. The animal data show that the liver and nervous system are sensitive effects of exposure to β-HCH; studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 15 studies (published in 15 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-18 Overview of the Health Outcomes for β-Hexachlorocyclohexane Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Oral studies
Cohort | 1 | | 1 | | | | | | | | | | 1 | 2 | 7 | 2 | 3
Cohort | 1 | | 1 | | | | | | | | | | | 2 | 4 | | 1
Case cohort | | | | | | | | | | | | | | | | 1 | 1
Case cohort
Case control | | | | | | | | 2 | | | 1 | 1 | 5 | 4 | 9 | 7 | 25
Case control | | | | | | | | | | | 1 | 1 | 4 | 4 | 4 | 5 | 11
Nested case control | | | | | | | | | | | | | | | 1 | 1 | 1
Nested case control
Population | 2 | 1 | 3 | | | | 2 | 2 | | | 9 | 2 | 2 | 5 | 13 | 11 | 1
Population | 2 | | 1 | | | | 1 | | | | 6 | 1 | 1 | 2 | 8 | 5 | 1
Case series
Case series
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-19 Overview of the Health Outcomes for β-Hexachlorocyclohexane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration
Oral studies
Acute-duration | 1 | | | | 2 | | 3 | 1 | | | | 1 | 2 | | | 1
Acute-duration | | | | | | | 2 | 1 | | | | | 2 | | | 1
Intermediate-duration | 2 | | | | 1 | | 4 | 1 | | | | 3 | 2 | 3 | | | 1
Intermediate-duration | 1 | | | | 1 | | 4 | 1 | | | | 3 | 2 | 3
Chronic-duration | 1 | | | | | | 1 | 1 | | | | | | | | | 1
Chronic-duration | 1 | | | | | | 1 | 1 | | | | | | | | | 1
Dermal studies
Acute-duration
Acute-duration
Intermediate-duration
Intermediate-duration
Chronic-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function

## C.10 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—β-HCH

### C.10.1 Risk of Bias Assessment—β-HCH

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies were presented above in Tables C-5, C-6, and C-7, respectively. As described in Section C.5.1, each risk of bias question was answered on a four-point scale and studies were assigned to one of three risk of bias tiers.

The results of the risk of bias assessment for the different types of β-HCH health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-20 and C-21, respectively.

Table C-20 Summary of Risk of Bias Assessment for β-Hexachlorocyclohexane—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Neurological effects
Cohort
Medehouenou et al. 2019 | ++ | ++ | + | ++ | ++ | ++ | First
Case-control
Petersen et al. 2008 | + | − | ++ | ++ | + | ++ | Second
Richardson et al. 2009, 2011 | − | + | ++ | ++ | ++ | ++ | First
Singh et al. 2012, 2013, 2014 | + | + | ++ | ++ | ++ | ++ | First
Xu et al. 2022 | + | + | ++ | ++ | ++ | ++ | First
Zhang et al. 2021 | + | + | ++ | ++ | ++ | ++ | First
Cross-sectional
Kim et al. 2015 | ++ | ++ | + | ++ | ++ | ++ | First
Steenland et al. 2014 | − | + | + | ++ | ++ | ++ | First
Outcome: Hepatic effects
Cross-sectional
Arrebola et al. 2014 | ++ | ++ | − | ++ | ++ | ++ | First
Freire et al. 2015 | ++ | ++ | − | ++ | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

Table C-21 Summary of Risk of Bias Assessment for β-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Hepatic effects
Oral intermediate exposure
Van Velsen et al. 1986 (rat; 13 weeks) | − | − | + | + | ++ | ++ | + | ++ | NA | First
Hanada et al. 1973 (mouse; 32 weeks) | − | − | + | + | + | − | + | ++ | NA | First
Ito et al. 1973 (mouse; 24 weeks) | − | − | + | + | + | ++ | + | ++ | NA | First
Ito et al. 1975 (rat; 24–48 weeks) | − | − | + | + | − | ++ | + | ++ | NA | First
Oral chronic exposure
Fitzhugh et al. 1950 (rat; 107 weeks) | − | − | + | + | ++ | + | + | ++ | NA | First
Outcome: Neurological effects
Oral acute exposure
Van Velsen et al. 1986 (rat; 2 weeks) | − | − | + | + | ++ | ++ | + | ++ | NA | First
Cornacoff et al. 1988 (mouse; 1 week) | − | − | + | + | − | ++ | + | ++ | NA | First
Oral intermediate exposure
Muller et al. 1981 (rat; 30 days) | − | − | + | + | − | − | + | ++ | NA | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

## C.11 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—β-HCH

As discussed in greater detail in Section C.6, confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.11.1 Initial Confidence Rating—β-HCH

As discussed in greater detail in Section C.6.1, the body of evidence for an association (or no association) between exposure to β-HCH and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. Refer to Tables C-9, C-10, and C-11, respectively, for the key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies.

The presence or absence of the key features and the initial confidence levels for studies examining neurological and hepatic effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-22 and C-23, respectively.

Table C-22 Presence of Key Features of Study Design for β-Hexachlorocyclohexane—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Neurological effects
Cohort
Medehouenou et al. 2019 | No | Yes | Yes | Yes | Moderate
Case-control
Petersen et al. 2008 | No | No | Yes | Yes | Low
Richardson et al. 2009, 2011 | No | No | Yes | Yes | Low
Singh et al. 2012, 2013, 2014 | No | No | Yes | Yes | Low
Xu et al. 2022 | No | No | Yes | Yes | Low
Zhang et al. 2021 | No | No | Yes | Yes | Low
Cross-sectional
Kim et al. 2015 | No | No | Yes | Yes | Low
Steenland et al. 2014 | No | No | Yes | Yes | Low
Outcome: Hepatic effects
Cross-sectional
Arrebola et al. 2014 | No | No | Yes | Yes | Low
Freire et al. 2015 | No | No | Yes | Yes | Low

Table C-23 Presence of Key Features of Study Design for β-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic effects
Oral intermediate exposure
Van Velsen et al. 1986 (rat; 13 weeks) | Yes | Yes | Yes | Yes | High
Hanada et al. 1973 (mouse; 32 weeks) | Yes | Yes | Yes | No | Moderate
Ito et al. 1973 (mouse; 24 weeks) | Yes | Yes | Yes | Yes | High
Ito et al. 1975 (rat; 48 weeks) | Yes | Yes | Yes | No | Moderate
Oral chronic exposure
Fitzhugh et al. 1950 (rat; 107 weeks) | Yes | No | Yes | Yes | Moderate
Outcome: Neurological effects
Oral acute exposure
Van Velsen et al. 1986 (rat; 2 weeks) | Yes | Yes | Yes | No | Moderate
Cornacoff et al. 1988 (mouse; 1 week) | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Muller et al. 1981 (rat; 30 days) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-24. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-24.

Table C-24 Initial Confidence Rating for β-Hexachlorocyclohexane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Neurological effects
Oral acute exposure
Animal studies
Van Velsen et al. 1986 | Moderate | Moderate
Cornacoff et al. 1988 | Moderate | Moderate
Oral intermediate exposure
Animal studies
Muller et al. 1981 | High | High
Oral chronic exposure
Human studies
Medehouenou et al. 2019 | Moderate | Moderate
Singh et al. 2012, 2013, 2014 | Low | Moderate
Petersen et al. 2008 | Low | Moderate
Richardson et al. 2009, 2011 | Low | Moderate
Kim et al. 2015 | Low | Moderate
Steenland et al. 2014 | Low | Moderate
Xu et al. 2022 | Low | Moderate
Zhang et al. 2021 | Low | Moderate
Outcome: Hepatic effects
Oral intermediate exposure
Animal studies
Van Velsen et al. 1986 (rat; 13 weeks) | High
Hanada et al. 1973 (mouse; 32 weeks) | Moderate
Ito et al. 1973 (mouse; 24 weeks) | High | High
Ito et al. 1975 (rat; 48 weeks) | Moderate
Oral chronic exposure
Human studies
Arrebola et al. 2014 | Low | Low
Freire et al. 2015 | Low | Low
Animal studies
Fitzhugh et al. 1950 | Moderate | Moderate

### C.11.2 Adjustment of the Confidence Rating—β-HCH

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The five properties of the body of evidence that were considered to determine whether the confidence rating should be downgraded and the four properties of the body of evidence that were considered to determine whether the confidence rating should be upgraded are described above in Section C.6.2. The summaries of the assessment of the confidence in the body of evidence for neurological and hepatic effects are presented in Table C-25. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with β-HCH exposure is presented in Table C-26.

Table C-25 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Neurological effects
Human studies | Moderate | +1 consistency, −1 indirectness | Moderate
Animal studies | High | −1 indirectness, +1 dose-response, +1 consistency | High
Hepatic effects
Human studies | Low | −1 indirectness | Very low
Animal studies | High | +1 dose-response, +1 consistency | High

Table C-26 Confidence in the Body of Evidence for β-Hexachlorocyclohexane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Neurological | Moderate | High
Hepatic | Very Low | High

## C.12 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—β-HCH

As described in Section C.7, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted.

A summary of the level of evidence of health effects for β-HCH is presented in Table C-27.

Table C-27 Level of Evidence of Health Effects for β-Hexachlorocyclohexane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Neurological | Moderate | Health effect | Moderate
Hepatic | Very Low | No health effect | Inadequate
Animal studies
Neurological | High | Health effect | High
Hepatic | High | Health effect | High

## C.13 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS–β-HCH

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. Refer to Section C.8 for the four hazard identification conclusion categories for health effects, the hazard characterization scheme (see Figure C-1), and the hazard identification conclusion categories.

The hazard identification conclusions for β-HCH are listed below and summarized in Table C-28.

Presumed Health Effects

- Neurological
  ○ Moderate level of evidence in humans based on case-control studies reporting associations between serum β-HCH and risk of Parkinson and Alzheimer diseases (Petersen et al. 2008; Richardson et al. 2009, 2011; Singh et al. 2012, 2013, 2014; Xu et al. 2022) and a cross-sectional study showing an association between risk of cognitive deficits and β-HCH in blood (Kim et al. 2015).
  ○ High level of evidence in animals exposed orally based on clinical signs of neurotoxicity in rats and mice after acute durations (Cornacoff et al. 1988; Van Velsen et al. 1986) and reduced nerve conduction velocity in rats exposed for an intermediate duration (Muller et al. 1981). Clinical signs showed dose-related increase in severity.
  ○ Supported by evidence for neurological effects of γ-HCH in humans and animals (see Section 2.15).
- Hepatic
  ○ Very low level of evidence in humans based on two cross-sectional studies reporting no association between serum or adipose levels of β-HCH and hepatic clinical chemistry endpoints except for increased serum bilirubin in females (Arrebola et al. 2014; Freire et al. 2015).
  ○ High level of evidence in animals based on liver weight and histopathology changes in rats and mice exposed by dietary administration for intermediate and chronic durations (Fitzhugh et al. 1950; Hanada et al. 1973; Ito et al. 1973, 1975; Van Velsen et al. 1986).

Table C-28 Hazard Identification Conclusions for – β-HCHs

Outcome | Hazard identification
Neurological | Presumed health effect
Hepatic | Presumed health effect

## C.14 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—γ-HCH

Overviews of the potential health effect outcomes for γ-HCH identified in human and animal studies are presented in Tables C-29 and C-30, respectively. Most of the human studies evaluated developmental, reproductive, renal, endocrine, or cancer endpoints. Most of human studies of noncancer endpoints used measures of γ-HCH in blood or tissues to assess exposure, so the route is unknown; for the purpose of enumerations, these studies are considered to reflect oral exposure (e.g., through contaminated food). Studies of occupational exposure via pesticide application are considered to reflect primarily inhalation exposure. Most of the animal studies used oral administration, and the available studies examined comprehensive noncancer and cancer endpoints. The effects seen at the lowest doses in the animal studies were developmental and immune system effects. Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 41 studies (published in 35 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-29 Overview of the Health Outcomes for γ-Hexachlorocyclohexane Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Cohort | | | | | | | | | | | 1 | | | | | | 1
Cohort | | | | | | | | | | | 1 | | | | | | 1
Case control
Case control
Population
Population
Case series
Case series
Oral studies
Cohort | | | | | | | | 2 | | | | 1 | 2 | 1 | 3 | | 3
Cohort | | | | | | | | | | | | | 2 | 1 | 1 | | 1
Case cohort
Case cohort
Case control | | | | | | | | 2 | | | | 1 | 2 | 2 | 6 | 3 | 20
Case control | | | | | | | | 1 | | | | 1 | 1 | 1 | 4 | 1 | 8
Population | | 1 | | | | | | 2 | | | 4 | 2 | | 4 | 2 | 2
Population | | 1 | | | | | | | | | 1 | 1 | | 2 | 1 | 1
Case series
Case series
Meta analysis | | | | | | | | | | | | | | | | | 1
Meta analysis
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-30 Overview of the Health Outcomes for γ-Hexachlorocyclohexane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration | | | | | | | 1 | 1 | | | | | 2
Acute-duration | | | | | | | | | | | | | 2
Intermediate-duration | 2 | 2 | | | 1 | | 1 | 1 | | 1
Intermediate-duration
Chronic-duration
Chronic-duration
Oral studies
Acute-duration | 12 | 2 | 2 | 2 | 2 | | 18 | 4 | | | 2 | 3 | 19 | 11 | 22
Acute-duration | 2 | | | | 2 | | 11 | 2 | | | | 3 | 17 | 5 | 16
Intermediate-duration | 7 | 2 | 4 | | 3 | | 19 | 10 | | | 2 | 8 | 13 | 16 | 12 | 2 | 2
Intermediate-duration | | 1 | 3 | | | | 15 | 7 | | | 2 | 7 | 12 | 13 | 9 | 2 | 1
Chronic-duration | 3 | | | | 1 | | 3 | 1 | | | | | 1 | 1 | | | 4
Chronic-duration | 1 | | | | | | 3 | 1 | | | | | 1 | 1 | | | 2
Dermal studies
Acute-duration | 2 | 1 | | | | | | | 1 | 1 | | | 2
Acute-duration | 0 | 1 | | | | | | | | 1 | | | 2
Intermediate-duration | 1 | 1 | | | | | 1 | 1 | 2 | | | 1 | 1
Intermediate-duration | 0 | 1 | | | | | 1 | 1 | 1 | | | | 1
Chronic-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function

## C.15 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—γ-HCH

### C.15.1 Risk of Bias Assessment—γ-HCH

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies were presented above in Tables C-5, C-6, and C-7, respectively. As described in Section C.5.1, each risk of bias question was answered on a four-point scale and studies were assigned to one of three risk of bias tiers.

The results of the risk of bias assessment for the different types of γ-HCH health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-31 and C-32, respectively.

Table C-31 Summary of Risk of Bias Assessment for γ-Hexachlorocyclohexane—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Developmental effects
Cohort
Fenster et al. 2006 | ++ | + | − | + | ++ | ++ | First
Yang et al. 2021a | ++ | + | + | ++ | ++ | ++ | First
Garcia- Villarino et al. 2022 | ++ | ++ | + | ++ | ++ | ++ | First
Case-control
Fernandez et al. 2007 | ++ | ++ | + | ++ | ++ | ++ | First
Mustafa et al. 2013 | + | + | + | ++ | + | ++ | First
Sharma et al. 2012 | + | + | + | ++ | ++ | ++ | First
Siddiqui et al. 2003 | + | + | + | ++ | + | ++ | First
Yang et al. 2021b | ++ | + | + | ++ | ++ | ++ | First
Yin et al. 2021 | ++ | + | + | ++ | ++ | ++ | First
Cross-sectional
Fang et al. 2019a, 2019b | ++ | + | ++ | ++ | + | ++ | First
Freire et al. 2011 | ++ | + | − | ++ | − | ++ | Second
Outcome: Immunological effects
Cohort
Landgren et al. 2009 | ++ | ++ | ++ | + | ++ | ++ | First
Case-control
Meng et al. 2016 | + | − | ++ | + | ++ | ++ | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

Table C-32 Summary of Risk of Bias Assessment for γ-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Developmental effects
Oral acute exposure
Dalsenter et al. 1997a (rat; once) | − | − | + | + | ++ | − | + | ++ | NA | First
Dalsenter et al. 1997b (rat; once) | − | − | + | + | − | + | + | ++ | NA | First
Dalsenter et al. 1997b (rat; LDs 8–14) | − | − | + | + | − | + | + | ++ | NA | First
Johri et al. 2008 (rat; once) | − | − | + | + | − | − | + | ++ | NA | Second
Khera et al. 1979 (rat; GDs 6–15) | − | − | + | + | + | + | + | ++ | NA | First
Palmer et al. 1978 (rat; GDs 6–15) | + | + | + | + | + | − | + | ++ | NA | First
Rivera et al. 1991 (rat; once) | + | + | + | + | − | + | + | ++ | NA | First
Rivera et al. 1998 (rat; once) | + | + | + | + | − | − | + | ++ | NA | First
Rivera et al. 1998 (rat; PNDs 8–14) | − | − | + | + | − | − | − | ++ | NA | Third
Serrano et al. 1990 (rat; PNDs 8–10) | + | + | + | + | − | − | + | ++ | NA | First
Di Consiglio et al. 2009 (mouse; GDs 9–16) | + | + | + | + | + | − | + | ++ | NA | First
Hassoun and Stohs 1996a (mouse, once) | − | − | + | + | ++ | − | + | ++ | NA | First
La Sala et al. 2009 (mouse; 3 days) | + | + | + | + | − | − | + | ++ | NA | First
Maranghi et al. 2007 (mouse, GDs 91–6) | + | + | + | + | ++ | − | + | ++ | NA | First
Traina et al. 2003 (mouse; GDs 9–16) | + | + | + | + | ++ | − | + | ++ | NA | First
Palmer et al. 1978 (rabbit; GDs 6–18) | + | + | + | + | + | − | + | ++ | NA | First
Oral intermediate exposure
Breton et al. 2005 (rat; ~21 weeks (2-generation, premating–PND 98) | − | − | + | + | − | − | + | ++ | NA | First
EPA 1991a (rat; 2-generation, 70 days prior to mating until sacrifice) | + | + | + | + | + | + | ++ | ++ | NA | First
EPA 1999c (rat; GD 6–LD 10) | − | − | + | + | ++ | ++ | + | ++ | NA | First
Johri et al. 2007 (rat; GDs 521) | + | + | + | + | − | − | + | ++ | NA | First
Johri et al. 2008 (rat; GDs 5–21 and PND 45) | + | + | + | + | − | − | + | ++ | NA | First
Matsuura et al. 2005 (rat; ~10 weeks (2-generation; premating–PND 21)) | ++ | + | + | + | + | ++ | + | ++ | NA | First
Sauviat et al. 2005 (rat; ~13 weeks) | − | − | + | + | − | − | + | ++ | NA | Second
Srinivasan et al. 1991 (rat; GDs 0–21, LDs 1–28) | − | − | + | + | + | − | + | ++ | NA | First
Srivastava et al. 2019 (rat, GDs 5–21) | − | − | + | + | − | − | − | ++ | NA | Third
Seiler et al. 1994 (rabbit; 12–15 weeks, 3 days/week) | − | − | + | + | − | + | + | ++ | NA | First
Outcome: Immunological effects
Oral acute exposure
Mediratta et al. 2008 (rat; 14 days) | + | + | + | + | ++ | − | + | ++ | NA | First
Hong and Boorman 1993 (mouse; 10 days) | + | + | + | + | − | − | + | ++ | NA | First
Hong and Boorman 1993 (mouse; 3 days) | + | + | + | + | − | − | + | ++ | NA | First
Oral intermediate exposure
Koner et al. 1998 (rat; 8 weeks) | + | + | + | + | − | ++ | + | ++ | NA | First
Mediratta et al. 2008 (rat; 21 days) | + | + | + | + | ++ | − | + | ++ | NA | First
Meera et al. 1992 (mouse; 24 weeks) | − | − | + | + | − | + | + | ++ | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

## C.16 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—γ-HCH

As discussed in greater detail in Section C.6, confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.16.1 Initial Confidence Rating—γ-HCH

As discussed in greater detail in Section C.6.1, the body of evidence for an association (or no association) between exposure to γ-HCH and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. Refer to Tables C-9, C-10, and C-11, respectively, for the key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies.

The presence or absence of the key features and the initial confidence levels for studies examining developmental and immune system effects in the observational epidemiology and animal experimental studies are presented in Tables C-33 and C-34, respectively.

Table C-33 Presence of Key Features of Study Design for γ-Hexachlorocyclohexane—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual ll | Comparison group | Initial study confidence
Outcome: Developmental effects
Cohort
Fenster et al. 2006 | No | Yes | Yes | Yes | Moderate
Yang et al. 2021a | No | Yes | Yes | Yes | Moderate
Garcia-Villarino et al. 2022 | No | Yes | Yes | Yes | Moderate
Case-control
Fernandez et al. 2007 | No | No | Yes | Yes | Low
Mustafa et al. 2013 | No | No | Yes | Yes | Low
Sharma et al. 2012 | No | No | Yes | Yes | Low
Siddiqui et al. 2003 | No | No | Yes | Yes | Low
Yang et al. 2021b | No | No | Yes | Yes | Low
Yin et al. 2021 | No | No | Yes | Yes | Low
Cross-sectional
Fang et al. 2019a, 2019b | No | No | Yes | Yes | Low
Outcome: Immunological effects
Cohort
Landgren et al. 2009 | No | Yes | Yes | Yes | Moderate
Case-control
Meng et al. 2016 | No | No | Yes | Yes | Low
Cross-sectional
Wang et al. 2021a | No | No | Yes | Yes | Low

Table C-34 Presence of Key Features of Study Design for γ-Hexachlorocyclohexane—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Developmental effects
Oral acute exposure
Dalsenter et al. 1997a (rat; once) | Yes | Yes | Yes | Yes | High
Dalsenter et al. 1997b (rat; once) | Yes | Yes | Yes | Yes | High
Dalsenter et al. 1997b (rat; LDs 8–14) | Yes | Yes | Yes | Yes | High
Johri et al. 2008 (rat; once) | Yes | Yes | Yes | Yes | High
Khera et al. 1979 (rat; GDs 6–15) | Yes | Yes | Yes | Yes | High
Palmer et al. 1978 (rat; GDs 6–15) | Yes | Yes | Yes | Yes | High
Rivera et al. 1991 (rat; once) | Yes | No | Yes | Yes | Moderate
Rivera et al. 1998 (rat; once) | Yes | No | Yes | Yes | Moderate
Rivera et al. 1998 (rat; PNDs 8–14) | Yes | No | Yes | Yes | Moderate
Serrano et al. 1990 (rat; PNDs 8–10) | Yes | Yes | Yes | No | Moderate
Di Consiglio et al. 2009 (mouse; GDs 9–16) | Yes | No | Yes | Yes | Moderate
Hassoun and Stohs 1996a (mouse, once) | Yes | Yes | Yes | Yes | High
La Sala et al. 2009 (mouse; 3 days) | Yes | No | Yes | Yes | Moderate
Maranghi et al. 2007 (mouse, GDs 91–6) | Yes | Yes | Yes | Yes | High
Traina et al. 2003 (mouse; GDs 9–16) | Yes | Yes | Yes | Yes | High
Palmer et al. 1978 (rabbit; GDs 6–18) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Breton et al. 2005 (rat; ~21 weeks, 2-generation, premating–PND 98) | Yes | No | Yes | Yes | Moderate
EPA 1991a (rat; 2-generation, 70 days prior to mating until sacrifice) | Yes | Yes | Yes | Yes | High
EPA 1999c (rat; GD 6–LD 10) | Yes | Yes | Yes | Yes | High
Johri et al. 2007 (rat; GDs 5–21) | Yes | Yes | Yes | Yes | High
Johri et al. 2008 (rat; GDs 5–21 and PND 45) | Yes | Yes | Yes | Yes | High
Matsuura et al. 2005 (rat; ~10 weeks, 2-generation; premating–PND 21) | Yes | Yes | Yes | Yes | High
Sauviat et al. 2005 (rat; ~13 weeks) | Yes | No | Yes | Yes | Moderate
Srinivasan et al. 1991 (rat; GDs 0–21, LDs 1–28) | Yes | No | Yes | Yes | Moderate
Srivastava et al. 2019 (rat, GDs 5–21) | Yes | Yes | Yes | Yes | High
Seiler et al. 1994 (rabbit; 12–15 weeks, 3 days/week) | Yes | No | Yes | Yes | Moderate
Outcome: Immunological effects
Oral acute exposure
Mediratta et al. 2008 (rat; 14 days) | Yes | Yes | Yes | Yes | High
Hong and Boorman 1993 (mouse; 10 days) | Yes | Yes | Yes | Yes | High
Hong and Boorman 1993 (mouse; 3 days) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Koner et al. 1998 (rat; 8 weeks) | Yes | No | Yes | Yes | Moderate
Mediratta et al. 2008 (rat; 21 days) | Yes | No | Yes | Yes | Moderate
Meera et al. 1992 (mouse; 24 weeks) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-35. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-35.

Table C-35 Initial Confidence Rating for γ-Hexachlorocyclohexane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Developmental effects
Oral acute exposure
Animal studies
Dalsenter et al. 1997a | High | High
Dalsenter et al. 1997b | High | High
Dalsenter et al. 1997b | High | High
Johri et al. 2008 | High | High
Khera et al. 1979 | High | High
Palmer et al. 1978 | High | High
Rivera et al. 1991 | Moderate | High
Rivera et al. 1998 | Moderate | High
Rivera et al. 1998 | Moderate | High
Serrano et al. 1990 | Moderate | High
Di Consiglio et al. 2009 | Moderate | High
Hassoun and Stohs 1996a | High | High
Hassoun and Stohs 1996a | Moderate | High
La Sala et al. 2009 | High | High
Maranghi et al. 2007 | High | High
Traina et al. 2003 | High | High
Palmer et al. 1978 | High | High
Oral intermediate exposure
Animal studies
Breton et al. 2005 | Moderate | High
EPA 1991a | High | High
EPA 1999c | High | High
Johri et al. 2007 | High | High
Johri et al. 2008 | High | High
Matsuura et al. 2005 | High | High
Sauviat et al. 2005 | Moderate | High
Srinivasan et al. 1991 | Moderate | High
Srivastava et al. 2019 | High | High
Seiler et al. 1994 | Moderate | High
Oral chronic exposure
Human studies
Fenster et al. 2006 | Moderate | Moderate
Yang et al. 2021a | Moderate | Moderate
Garcia-Villarino et al. 2022 | Moderate | Moderate
Fernandez et al. 2007 | Low | Moderate
Mustafa et al. 2013 | Low | Moderate
Sharma et al. 2012 | Low | Moderate
Siddiqui et al. 2003 | Low | Moderate
Fang et al. 2019a, 2019b | Low | Moderate
Yang et al. 2021b | Low | Moderate
Yin et al. 2021 | Low | Moderate
Outcome: Immunological effects
Oral acute exposure
Animal studies
Mediratta et al. 2008 | High | High
Hong and Boorman 1993 | High | High
Hong and Boorman 1993 | High | High
Oral intermediate exposure
Animal studies
Koner et al. 1998 | Moderate | High
Mediratta et al. 2008 | Moderate | High
Meera et al. 1992 | High | High
Oral chronic exposure
Human studies
Landgren et al. 2009 | Moderate | Moderate
Meng et al. 2016 | Low | Moderate

### C.16.2 Adjustment of the Confidence Rating—γ-HCH

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The five properties of the body of evidence that were considered to determine whether the confidence rating should be downgraded and the four properties of the body of evidence that were considered to determine whether the confidence rating should be upgraded are described above in Section C.6.2. The summaries of the assessment of the confidence in the body of evidence for developmental and immune system effects are presented in Table C-36. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with γ-HCH exposure is presented in Table C-37.

Table C-36 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Developmental effects
Human studies | Moderate | −1 imprecision | Low
Animal studies | High | +1 consistency | High
Immunological effects
Human Studies | Moderate | −1 risk of bias | Low
Animal Studies | High | +1 consistency | High

Table C-37 Confidence in the Body of Evidence for γ-Hexachlorocyclohexane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Developmental | Low | High
Immune | Low | High

## C.17 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—γ-HCH

As described in Section C.7, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted.

A summary of the level of evidence of health effects for γ-HCH is presented in Table C-38.

Table C-38 Level of Evidence of Health Effects for γ-Hexachlorocyclohexane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Developmental | Low | Health effect | Low
Immunological | Low | Health effect | Low
Animal studies
Developmental | High | Health effect | High
Immunological | High | Health effect | High

## C.18 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—γ-HCH

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. Refer to Section C.8 for the four hazard identification conclusion categories for health effects, the hazard characterization scheme (see Figure C-1), and the hazard identification conclusion categories.

The hazard identification conclusions for γ-HCH are listed below and summarized in Table C-39.

Presumed Health Effects

- Developmental
  ○ Low level of evidence in humans based on associations between γ-HCH in maternal or fetal blood (or tissue) and intrauterine growth retardation/fetal growth retardation in small case-control studies in India (Sharma et al. 2012; Siddiqui et al. 2003), decreased gestational age and increased preterm birth in a cross-sectional study in China (Fang et al. 2019a, 2019b) and a case-control study in India (Mustafa et al. 2013), and cryptorchidism or hypospadias in a nested case-control study in Spain (Fernandez et al. 2007).
  ○ High level of evidence in animals based on studies in a variety of species exposed to γ-HCH for acute or intermediate durations during gestation or postnatal development demonstrating effects on a wide range of developmental endpoints, including birth outcomes (Beard et al. 1997; EPA 1991a, 1999c; Hassoun and Stohs 1996a; Matsuura et al. 2005; Sauviat et al. 2005) and development of the male and female reproductive tracts (Agrahari et al. 2019; Dalsenter et al. 1997a, 1997b; Di Consiglio et al. 2009; La Sala et al. 2009; Maranghi et al. 2007; Matsuura et al. 2005; Traina et al. 2003), central nervous system (Albertson et al. 1985; Breton et al. 2005; EPA 1999c; Johri et al. 2007, 2008; Rivera et al. 1991, 1998; Srivastava et al. 2019), heart (Sauviat et al. 2005), liver (Srinivasan et al. 1991), and thymus and spleen (Hassoun et al. 1996; Matsuura et al. 2005).
- Immunological
  ○ Low level of evidence in humans based on association between asthma and plasma levels of γ-HCH in children (Meng et al. 2016) and no evidence for increased prevalence of monoclonal gammopathy of undetermined significance in cohort of male pesticide applicators followed for 9 years (Landgren et al. 2009).
  ○ High level of evidence in animals based on acute- and intermediate-duration studies of γ-HCH administered orally to rats, mice, rabbits, and sheep showing suppression of the immune system (Banerjee et al. 1996; Desi et al. 1978; Dewan et al. 1980; Khurana et al. 1999; Koner et al. 1998; Mediratta et al. 2008; Meera et al. 1992) and effects on thymus, spleen, and lymph node weights or histology (Hong and Boorman 1993; Meera et al. 1992).

Table C-39 Hazard Identification Conclusions for γ-Hexachlorocyclohexane

Outcome | Hazard identification
Developmental | Presumed health effect
Immunological | Presumed health effect