# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR HCH

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to HCH.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for HCH. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of HCH have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of HCH are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer
- Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the 2005 draft toxicological profile for HCH released for public comment in January 2023; thus, the literature search was restricted to studies published between January 2020 and June 2023. The following main databases were searched in June 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for HCH. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to HCH were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2023 | ((319-84-6[rn] OR 319-85-7[rn] OR YM80ODM9PD[rn] OR 319-86-8[rn] OR 58-89-9[rn] OR 59NEE7PCAB[rn] OR 608-73-1[rn] OR “Hexachlorocyclohexane”[mh]) AND ((“Hexachlorocyclohexane/toxicity”[mh] OR “Hexachlorocyclohexane/adverse effects”[mh] OR “Hexachlorocyclohexane/poisoning”[mh] OR “Hexachlorocyclohexane/pharmacokinetics”[mh] OR “Hexachlorocyclohexane/blood”[mh] OR “Hexachlorocyclohexane/cerebrospinal fluid”[mh] OR “Hexachlorocyclohexane/urine”[mh] OR “Hexachlorocyclohexane/antagonists and inhibitors”[mh] OR (“Hexachlorocyclohexane/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh]))) OR (“Hexachlorocyclohexane”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Hexachlorocyclohexane”[mh] AND toxicokinetics[mh:noexp]) OR (“Hexachlorocyclohexane”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Hexachlorocyclohexane”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Hexachlorocyclohexane”[mh] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR Hexachlorocyclohexane/pharmacology[majr]) AND (2020/10/01:3000[mhda] OR 2020:3000[dp])) OR (((“gamma-Lindane”[tw] OR “1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “alpha-Benzene hexachloride”[tw] OR “alpha-Hexachlorocyclohexane”[tw] OR “beta-Benzene hexachloride”[tw] OR “beta-hexachlorocyclohexane”[tw] OR “delta-Benzene hexachloride”[tw] OR “delta-Benzenehexachloride”[tw] OR “delta-Hexachlorocyclohexane”[tw] OR “gamma-Benzene hexachloride”[tw] OR “gamma-Hexachlorocyclohexane”[tw] OR “1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “A-Hexachlorocyclohexane”[tw] OR “alpha-Benzene hexachloride”[tw] OR “alpha-Benzenehexachloride”[tw] OR “alpha-Hexachlorocyclohexane”[tw] OR “alpha-Lindane”[tw] OR “Aalindan”[tw] OR “Aficide”[tw] OR “Agrocide”[tw] OR “Agronexit”[tw] OR “Ameisentod”[tw] OR “Aparasin”[tw] OR “Aphtiria”[tw] OR “Aplidal”[tw] OR “Arbitex”[tw] OR “B-Hexachlorocyclohexane”[tw] OR “Benzene hexachloride”[tw] OR “Benzenehexachloride”[tw] OR “beta-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “beta-Hexachloro-cyclohexane”[tw] OR “beta-Hexachlorocyclohexane”[tw] OR “beta-Lindane”[tw] OR “Ben-Hex”[tw] OR “Benhexol”[tw] OR “Bexol”[tw] OR “Celanex”[tw] OR “Chloresene”[tw] OR “Codechine”[tw] OR “Cyclohexane, 1,2,3,4,5,6-hexachloro-”[tw] OR “delta-Benzene hexachloride”[tw] OR “delta-Benzenehexachloride”[tw] OR “delta-Hexachlorocyclohexane”[tw] OR “delta-Lindane”[tw] OR “Devoran”[tw] OR “Entomoxan”[tw] OR “Forst-Nexen”[tw] OR “Gallogama”[tw] OR “Gamacarbatox”[tw] OR “Gamacid”[tw] OR “Gamacide”[tw] OR “Gamaphex”[tw] OR “Gamene”[tw] OR “Gamiso”[tw] OR “gamma Benzene hexachloride”[tw] OR “gamma-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “gamma-Benzenehexachloride”[tw] OR “gamma-Benzohexachloride”[tw] OR “gamma-Hexachlorcyclohexanum”[tw] OR “gamma-Hexachloro-cyclohexane”[tw] OR “gamma-Hexachlorobenzene”[tw] OR “gamma-Hexachlorocyclohexane”[tw] OR “Gammalin”[tw] OR “Gammaterr”[tw] OR “Gammexane”[tw] OR “Geobilan”[tw] OR “Gexane”[tw] OR “HEXACHLORCYCLOHEXANE”[tw] OR “Hexachloro-cyclohexane”[tw] OR “Hexachlorocyclohexane”[tw] OR “hexachlorocyclohexanes”[tw] OR “Hexachlor”[tw] OR “Hexachlorcyclohexan”[tw] OR “Heclotox”[tw] OR “Hexachloran”[tw] OR “Hexachlorane”[tw] OR “Hexaverm”[tw] OR “Hexcidum”[tw] OR “Hexicide”[tw] OR “Hexyclan”[tw] OR “Hilbeech”[tw] OR “Hortex”[tw] OR “Hungaria L 7”[tw] OR “Hungaria L-7”[tw] OR “Jacutin”[tw] OR “Kokotine”[tw] OR “Kwell”[tw] OR “Lindane”[tw] OR “Lasochron”[tw] OR “Lendine”[tw] OR “Lentox”[tw] OR “Lidenal”[tw] OR “Lindafor”[tw] OR “Lindagam”[tw] OR “Lindagrain”[tw] OR “Lindagranox”[tw] OR “Lindan”[tw] OR “Lindanum”[tw] OR “Lindapoudre”[tw] OR “Lindatox”[tw] OR “Lindosep”[tw] OR “Lintox”[tw] OR “Linvur”[tw] OR “Lorexane”[tw] OR “Mszycol”[tw] OR “Neo-Scabicidol”[tw] OR “Nexol E”[tw] OR “Nexol-E”[tw] OR “Nicochloran”[tw] OR “Novigam”[tw] OR “Omnitox”[tw] OR “Ovadziak”[tw] OR “Owadziak”[tw] OR “Pedraczak”[tw] OR “Pflanzol”[tw] OR “Quellada”[tw] OR “Technical HCH”[tw] OR “technical grade HCH”[tw] OR “Scabene”[tw] OR “Silvanol”[tw] OR “Spritz-Rapidin”[tw] OR “Spritzlindane”[tw] OR “Spruehpflanzol”[tw] OR “Streunex”[tw] OR “α-Benzohexachloride”[tw] OR “α-Hexachlorocyclohexane”[tw] OR “α-Lindane”[tw] OR “β-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “β-Benzene hexachloride”[tw] OR “β-Hexachlorocyclohexane”[tw] OR “β-Lindane”[tw] OR “γ-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “γ-Benzene hexachloride”[tw] OR “γ-Benzohexachloride”[tw] OR “γ-Hexachlorobenzene”[tw] OR “γ-Hexachlorocyclohexane”[tw] OR “γ-Lindane”[tw] OR “δ-Benzene hexachloride”[tw] OR “δ-Hexachlorocyclohexane”[tw] OR “δ-Lindane”[tw] OR “alpha BHC”[tw] OR “alpha-BHC”[tw] OR “alpha-HCH”[tw] OR “beta BHC”[tw] OR “beta-BHC”[tw] OR “beta-HCH”[tw] OR “delta BHC”[tw] OR “delta-BHC”[tw] OR “delta-HCH”[tw] OR “Gamma-BHC”[tw] OR “gamma-HCH”[tw] OR “Nexit Stark”[tw] OR “Nexit-stark”[tw] OR “α-BHC”[tw] OR “α-HCH”[tw] OR “β-666”[tw] OR “β-BHC”[tw] OR “β-HCH”[tw] OR “γ-666”[tw] OR “γ-BHC”[tw] OR “γ-HCH”[tw] OR “δ-BHC”[tw] OR “δ-HCH”[tw] OR “total BHC”[tw] OR “α-666”[tw] OR “δ-666”[tw] OR “BHC-gamma”[tw] OR “α-Benzenehexachloride”[tw] OR “Detox 25”[tw] OR “Dol Granule”[tw] OR “ENT 7,796”[tw] OR “TAP 85”[tw] OR “Ameisenmittel merck”[tw] OR “Arcotal S”[tw] OR “Bentox 10”[tw] OR “Benzene-1,2,3,4,5,6-hexachloride”[tw] OR “beta-Hexachlorobenzene”[tw] OR “Detmol Extract”[tw] OR “Fenoform forte”[tw] OR “Gamma-mean 400”[tw] OR “Geolin G 3”[tw] OR “Hungaria L7”[tw] OR “Mglawik L”[tw] OR “Milbol 49”[tw] OR “Nexen FB”[tw] OR “sang-gamma”[tw] OR “sang gamma”[tw] OR “Submar”[tw] OR “Verindal Ultra”[tw] OR “HCH, technical grade”[tw] OR “beta-Hexachlorobenzene”[tw] OR “β-Hexachlorobenzene”[tw]) NOT medline[sb]) AND (2020/10/01:3000[crdt] OR 2020/10/01:3000[edat] OR 2020:3000[dp])) OR (“Hexachlorocyclohexane”[mh] AND 2022/04/01:3000[mhda]); “A-HCCH”[tw] OR “BHC alpha”[tw] OR “BHC beta”[tw] OR “BHC delta”[tw] OR “BHC-alpha”[tw] OR “BHC-beta”[tw] OR “BHC-delta”[tw] OR “D-BHC”[tw] OR “D-HCCH”[tw] OR “Dolmix”[tw] OR “ENT 9,232”[tw] OR “HCH (mixed isomers)”[tw] OR “Tri-6 Dust No. 30”[tw] OR “(1.alpha.,2.alpha.,3.beta.,4.alpha.,5.alpha.,6.beta.)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1.alpha.,2.alpha.,3.beta.,4.alpha.,5.beta.,6.beta.)1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1.alpha.,2.beta.,3.alpha.,4.beta.,5.alpha.,6.beta.)-1,2,3,4,5,6-hexachloro-cyclohexane”[tw] OR “(1alpha,2alpha,3alpha,4beta,5alpha,6beta)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1alpha,2alpha,3beta,4alpha,5beta,6beta)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1alpha,2beta,3alpha,4beta,5alpha,6beta)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1r,2r,3r,4r,5r,6r)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1R,2R,3R,4R,5S,6S)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1R,2S,3r,4R,5S,6r)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1R,2S,3r,4R,5S,6s)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “alpha-hexachlorcyclohexane”[tw] OR “1,2,3,4,5,6-G-HEXACHLOROCYCLOHEXANE”[tw] OR “1,2,3,4,5,6-Hexachloro(1a,2a,3a,4b,5a,6b)cyclohexane”[tw] OR “1,2,3,4,5,6-Hexachloro(1a,2b,3a,4b,5a,6b)cyclohexane”[tw] OR “1,2,3,4,5,6-Hexachloro-(1.alpha.,2.alpha.,3.alpha.,4.beta.,5.alpha.,6.beta.) cyclohexane”[tw] OR “1-alpha,2-alpha,3-alpha,4-beta,5-alpha,6-beta-Hexachlorocyclohexane”[tw] OR “1-alpha,2-beta,3-alpha,4-beta,5-alpha,6-beta-Hexachlorocyclohexane”[tw] OR “1a,2a,3b,4a,5b,6b-Hexachlorocyclohexane”[tw] OR “1α,2α,3β,4α,5α,6β)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1α,2α,3α,4β,5α,6.β)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1α,2α,3α,4β,5α,6β)-1,2,3,4,5,6-Hexachlorcyclohexan”[tw] OR “(1α,2α,3α,4β,5α,6β)-1,2,3,4,5,6-hexachlorocyclohexane”[tw] OR “(1α,2α,3α,4β,5α,6β)-1,2,3,4,5,6-hexaclorociclohexano”[tw] OR “(1α,2α,3β,4α,5α,6β)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1α,2α,3β,4α,5β,6β)-1,2,3,4,5,6-Hexachlorcyclohexan”[tw] OR “(1α,2α,3β,4α,5β,6β)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1α,2α,3β,4α,5β,6β)-1,2,3,4,5,6-hexaclorociclohexano”[tw] OR “(1α,2β,3α,4β,5α,6β)-1,2,3,4,5,6-Hexachlorcyclohexan”[tw] OR “(1α,2β,3α,4β,5α,6β)-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “(1α,2β,3α,4β,5α,6β)-1,2,3,4,5,6-hexaclorociclohexano”[tw] OR “A-Benzene hexachloride”[tw] OR “ALPHA-1,2,3,4,5,6-HEXACHLORCYCLOHEXAN”[tw] OR “alpha-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “alpha-Hexachloran”[tw] OR “alpha-Hexachlorane”[tw] OR “B-Benzene hexachloride”[tw] OR “Bercema-Spritz-Lindan 50”[tw] OR “Benzanex”[tw] OR “BETA-1,2,3,4,5,6-HEXACHLORCYCLOHEXAN”[tw] OR “beta-Hexachloran”[tw] OR “delta-(Aeeeee)-1,2,3,4,5,6-hexachlorocyclohexane”[tw] OR “Gamaxene”[tw] OR “Gamoline”[tw] OR “Gamtox”[tw] OR “Grammexene”[tw] OR “Gyben”[tw] OR “Hexablanc”[tw] OR “Hexachlorine cyclohexane”[tw] OR “Hexachlorzyklohexan”[tw] OR “Hexamul”[tw] OR “Hexapoudre”[tw] OR “Isatox”[tw] OR “Kanodane”[tw] OR “Lidano”[tw] OR “Prodactif”[tw] OR “Scabecid”[tw] OR “trans-alpha-Benzenehexachloride”[tw] OR “Trives-T”[tw] OR “BHC, d-”[tw] OR “BHC, total”[tw] OR “Cyclohexane,1,2,3,4,5,6-hexachloro-(1.alpha.,2.alpha.,3.beta.,4.alpha.,5.alpha.,6.beta.)-]”[tw] OR “Ciclohexano, 1,2,3,4,5,6-hexacloro-”[tw] OR “Cyclohexane, beta-1,2,3,4,5,6-hexachloro-”[tw] OR “Cyclohexane, delta-1,2,3,4,5,6-hexachloro-”[tw] OR “Cyclohexane, l,2,3,4,5,6-hexachloro-, (1alpha,2alpha,3beta,4alpha,5beta,6beta)-”[tw] OR “1,2,3,4,5,6-Benzenehexachloride”[tw] OR “1,2,3,4,5,6-Hexachlorohexane”[tw] OR “D-Benzene hexachloride”[tw] OR “D-Hexachlorocyclohexane”[tw] OR “delta-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “α-1,2,3,4,5,6-Hexachlorocyclohexane”[tw] OR “α-Hexachloran”[tw] OR “α-Hexachlorane”[tw] OR “α-Hexachlorcyclohexane”[tw] OR “β-Hexachloran”[tw] OR “γ-Hexachloran”[tw] OR “γ-Hexachlorane”[tw] OR “δ-1,2,3,4,5,6-Hexachlorocyclohexane”[tw]
NTRL
06/2023 | Date limit 2020-2023; Search Titles OR Keywords;; “Hexachlorocyclohexane” OR “Benzene hexachloride” OR “Lindane” OR “Hexachlorane” OR “Benzenehexachloride”
Toxcenter
06/2023 | FILE ‘TOXCENTER’ ENTERED AT 16:26:48 ON 12 MAY 2023; - L1 35805 SEA 319-84-6 OR 319-85-7 OR 319-86-8 OR 58-89-9 OR 608-73-1; - L2 35767 SEA L1 NOT TSCATS/FS; - L3 35033 SEA L2 NOT PATENT/DT; - L4 1214 SEA L3 AND ED>=20201001; ACTIVATE TOXQUERY/Q; -------; - L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); - L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); - L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); - L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; - L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); - L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); - L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); - L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); - L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); - L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); - L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); - L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); - L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); - L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); - L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); - L22 QUE (ENDOCRIN? AND DISRUPT?); - L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); - L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); - L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); - L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); - L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); - L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); - L29 QUE (NEPHROTOX? OR HEPATOTOX?); - L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); - L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); - L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; -------; - L42 643 SEA L4 AND L32; - L44 71 SEA L42 AND MEDLINE/FS; - L45 125 SEA L42 AND BIOSIS/FS; - L46 447 SEA L42 AND CAPLUS/FS; - L47 0 SEA L42 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); - L48 564 DUP REM L44 L45 L46 (79 DUPLICATES REMOVED); - L*** DEL 71 S L42 AND MEDLINE/FS; - L*** DEL 71 S L42 AND MEDLINE/FS; - L49 71 SEA L48; - L*** DEL 125 S L42 AND BIOSIS/FS; - L*** DEL 125 S L42 AND BIOSIS/FS; - L50 113 SEA L48; - L*** DEL 447 S L42 AND CAPLUS/FS; - L*** DEL 447 S L42 AND CAPLUS/FS; - L51 380 SEA L48; - L52 493 SEA (L49 OR L50 OR L51) NOT MEDLINE/FS; D SCAN L52

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
06/2023 | Compounds searched: 319-84-6, 319-85-7, 319-86-8, 58-89-9, 608-73-1
NTP
06/2023 | Date limit 2020-2023; “58-89-9” “Hexachlorocyclohexane” “Lindane” “Benzene hexachloride” “319-84-6” “319-85-7” “319-86-8” “608-73-1”; “Hexachlorane” “Benzenehexachloride”
Regulations.gov
06/2023 | “Lindane”; Hexachlorocyclohexane; “Benzene hexachloride”; “Hexachlorane”; “Benzenehexachloride”; “319-84-6”; “319-85-7”; “319-86-8”; “58-89-9”; “608-73-1”
NIH RePORTER
07/2023 | Search Criteria: Fiscal Year: Active Projects; Text Search: lindane OR Hexachlorocyclohexane OR Hexachlorocyclohexanes OR “Benzene hexachloride” OR Hexachlorane OR Benzenehexachloride (advanced); Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria: Fiscal Year: Active Projects; Text Search: “gamma-Lindane” OR “1,2,3,4,5,6-Hexachlorocyclohexane” OR “alpha-Benzene hexachloride” OR “alpha-Hexachlorocyclohexane” OR “beta-Benzene hexachloride” OR “beta-hexachlorocyclohexane” OR “delta-Benzene hexachloride” OR “delta-Benzenehexachloride” OR “delta-Hexachlorocyclohexane” OR “gamma-Benzene hexachloride” OR “gamma-Hexachlorocyclohexane” OR “1,2,3,4,5,6-Hexachlorocyclohexane” OR “A-Hexachlorocyclohexane” OR “alpha-Benzene hexachloride” OR “alpha-Benzenehexachloride” OR “alpha-Hexachlorocyclohexane” OR “alpha-Lindane” OR “Aalindan” OR “Aficide” OR “Agrocide” OR “Agronexit” OR “Ameisentod” OR “Aparasin” OR “Aphtiria” OR “Aplidal” OR “Arbitex” OR “B-Hexachlorocyclohexane” OR “Benzene hexachloride” OR “Benzenehexachloride” OR “beta-1,2,3,4,5,6-Hexachlorocyclohexane” OR “beta-Hexachloro-cyclohexane” OR “beta-Hexachlorocyclohexane” OR “beta-Lindane” OR “Ben-Hex” OR “Benhexol” OR “Bexol” OR “Celanex” OR “Chloresene” OR “Codechine” OR “Cyclohexane, 1,2,3,4,5,6-hexachloro-” OR “delta-Benzene hexachloride” OR “delta-Benzenehexachloride” OR “delta-Hexachlorocyclohexane” OR “delta-Lindane” OR “Devoran” OR “Entomoxan” OR “Forst-Nexen” OR “Gallogama” OR “Gamacarbatox” OR “Gamacid” OR “Gamacide” OR “Gamaphex” OR “Gamene” OR “Gamiso” OR “gamma Benzene hexachloride” OR “gamma-1,2,3,4,5,6-Hexachlorocyclohexane” OR “gamma-Benzenehexachloride” OR “gamma-Benzohexachloride” OR “gamma-Hexachlorcyclohexanum” OR “gamma-Hexachloro-cyclohexane” OR “gamma-Hexachlorobenzene” OR “gamma-Hexachlorocyclohexane” OR “Gammalin” OR “Gammaterr” OR “Gammexane” OR “Geobilan” OR “Gexane” OR “HEXACHLORCYCLOHEXANE” OR “Hexachloro-cyclohexane” OR “Hexachlorocyclohexane” OR “hexachlorocyclohexanes” OR “Hexachlor” OR “Hexachlorcyclohexan” OR “Heclotox” OR “Hexachloran” OR “Hexachlorane” OR “Hexaverm” OR “Hexcidum” OR “Hexicide” OR “Hexyclan” OR “Hilbeech” OR “Hortex” OR “Hungaria L 7” OR “Hungaria L-7” OR “Jacutin” OR “Kokotine” OR “Kwell” OR “Lindane” OR “Lasochron” OR “Lendine” OR “Lentox” OR “Lidenal” OR “Lindafor” OR “Lindagam” OR “Lindagrain” OR “Lindagranox” OR “Lindan” OR “Lindanum” OR “Lindapoudre” OR “Lindatox” OR “Lindosep” OR “Lintox” OR “Linvur” OR “Lorexane” OR “Mszycol” OR “Neo-Scabicidol” OR “Nexol E” OR “Nexol-E” OR “Nicochloran” OR “Novigam” OR “Omnitox” OR “Ovadziak” OR “Owadziak” OR “Pedraczak” OR “Pflanzol” OR “Quellada” OR “Technical HCH” OR “technical grade HCH” OR “Scabene” OR “Silvanol” OR “Spritz-Rapidin” OR “Spritzlindane” OR “Spruehpflanzol” OR “Streunex” (advanced); Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria: Fiscal Year: Active Projects; Text Search: “α-Benzohexachloride” OR “α-Hexachlorocyclohexane” OR “α-Lindane” OR “β-1,2,3,4,5,6-Hexachlorocyclohexane” OR “β-Benzene hexachloride” OR “β-Hexachlorocyclohexane” OR “β-Lindane” OR “γ-1,2,3,4,5,6-Hexachlorocyclohexane” OR “γ-Benzene hexachloride” OR “γ-Benzohexachloride” OR “γ-Hexachlorobenzene” OR “γ-Hexachlorocyclohexane” OR “γ-Lindane” OR “δ-Benzene hexachloride” OR “δ-Hexachlorocyclohexane” OR “δ-Lindane” OR “alpha BHC” OR “alpha-BHC” OR “alpha-HCH” OR “beta BHC” OR “beta-BHC” OR “beta-HCH” OR “delta BHC” OR “delta-BHC” OR “delta-HCH” OR “Gamma-BHC” OR “gamma-HCH” OR “Nexit Stark” OR “Nexit-stark” OR “α-BHC” OR “α-HCH” OR “β-666” OR “β-BHC” OR “β-HCH” OR “γ-666” OR “γ-BHC” OR “γ-HCH” OR “δ-BHC” OR “δ-HCH” OR “total BHC” OR “α-666” OR “δ-666” OR “BHC-gamma” OR “α-Benzenehexachloride” OR “Detox 25” OR “Dol Granule” OR “ENT 7,796” OR “TAP 85” OR “Ameisenmittel merck” OR “Arcotal S” OR “Bentox 10” OR “Benzene-1,2,3,4,5,6-hexachloride” OR “beta-Hexachlorobenzene” OR “Detmol Extract” OR “Fenoform forte” OR “Gamma-mean 400” OR “Geolin G 3” OR “Hungaria L7” OR “Mglawik L” OR “Milbol 49” OR “Nexen FB” OR “sang-gamma” OR “sang gamma” OR “Submar” OR “Verindal Ultra” OR “HCH, technical grade” OR “beta-Hexachlorobenzene” OR “β-Hexachlorobenzene” (advanced); Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 673
- Number of records identified from other strategies: 18
- Total number of records to undergo literature screening: 691

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on HCH:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 691
- Number of studies considered relevant and moved to the next step: 129

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 129
- Number of studies cited in the pre-public draft of the toxicological profile: 809
- Total number of studies cited in the profile: 860

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 June 2023 Literature Search Results and Screen for HCH

Figure B-1 description