# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

HCH is a mixture of eight isomers, four of which are of commercial significance: α-HCH (CAS Registry Number 319-84-6), β-HCH (CAS Registry Number 319-85-7), γ-HCH (CAS Registry Number 58-89-9), and δ-HCH (CAS Registry Number 319-86-8). Technical HCH, which is used as an insecticide, is made up of the various isomers at different concentrations. The wide variations in isomer composition of technical HCH preclude the possibility of MRL derivation. MRL derivation was considered for the isomers included in this toxicological profile: α-, β-, γ-, and δ-HCH.

## α-HCH Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for α-HCH.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies of α-HCH in humans or animals were located, precluding derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## α-HCH Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for α-HCH.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies of α-HCH in humans or animals were located, precluding derivation of an intermediate-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## α-HCH Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for α-HCH.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies of α-HCH in humans or animals were located, precluding derivation of a chronic-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## α-HCH Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for α-HCH.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Data on effects in laboratory animals exposed orally to α-HCH for acute durations are limited to a freestanding NOAEL of 20 mg/kg/day for body weight changes during the first 14 days of a 28-day study comparing gene expression profiles for α- and γ-HCH (Sumida et al. 2007). Increased relative liver weight (24%) and decreased serum ALP (19%) were seen at this dose after 14 days, but histopathology was not evaluated at this time, so reliable hepatic effect levels could not be determined for this study. Thus, this study did not provide an adequate basis for MRL derivation.

Agency Contacts (Chemical Managers): Malcolm Williams

## α-HCH Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.002 mg/kg/day (2 µg/kg/day)
Critical Effect: | Increased liver weight and liver histopathology changes
Reference: | Sumida et al. 2007
Point of Departure: | 2 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
Modifying Factor: | 10
LSE Graph Key: | 6
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.002 mg/kg/day (2 µg/kg/day) was derived based on a NOAEL of 2 mg/kg/day for liver effects in a 28-day study in rats (Sumida et al. 2007). The NOAEL was divided by a total uncertainty factor of 100 (10 for human variability and 10 for animal to human extrapolation) and a modifying factor of 10 (for lack of studies examining developmental and immunological effects and limitations in available data on neurotoxicity).

Selection of the Critical Effect: No dose-response data are available for humans. In animal studies, hepatic effects (including cancers) occurred at lower doses than effects on body weight or kidneys. A single study found no effects on motor nerve conduction velocity in rats exposed to 106.2 mg/kg/day for 30 days (Muller et al. 1981). The α-hexachlorocyclohexane database only contains studies with body weight, renal, hepatic, neurological, and cancer endpoints; no other effects were evaluated in the available studies. Table A-1 summarizes the hepatic effects from intermediate-duration oral studies in laboratory animals exposed to doses up to 70 mg/kg/day.

Table A-1 Summary of NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Laboratory Animals Orally Exposed to α-Hexachlorocyclohexane

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Mouse (dd); 20–40 M | 24 weeks (F) | ND | 18 | 33% relative liver weight increase; hepatocellular hypertrophy | Ito et al. 1973
Rat (Fischer-344); 4 M | 28 days (GO) | 2 | 20 | Increased relative liver weight (25%); centrilobular hepatocellular hypertrophy | Sumida et al. 2007
Rat (W strain); 18–24 M | 48 weeks (F) | ND | 35 | Hepatocellular hypertrophy | Ito et al. 1975
Rat (Wistar); 8 M | 24 weeks (F) | ND | 45 | Mild liver cell hypertrophy; 2-fold increase in liver weight | Nagasaki et al. 1975
Hamster (Golden Syrian); 6–10 M | 24 weeks (F) | ND | 45 | 20–38% increase in liver weight; liver cell hypertrophy | Nagasaki et al. 1975
Rat (Wistar); 10 F, 10 M | 6–9 months (F) | ND | 60 M; 70 F; (serious LOAEL for decreased survival) | Decreased survival; moderate histopathology changes (focal necrosis, fatty degeneration); >2-fold increase in liver weight | Fitzhugh et al. 1950

Principal study for the MRL.

(F) = feed; F = female(s); (GO) = gavage in oil vehicle; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: As Table A-1 shows, the lowest effect level (18 mg/kg/day) was associated with a relative liver weight increase of 33% and hepatocellular hypertrophy in mice exposed via diet for 24 weeks (Ito et al. 1973). A NOAEL was not identified for this study. In a study of rats exposed by gavage for only 28 days (Sumida et al. 2007), a slightly higher LOAEL of 20 mg/kg/day was identified for similar hepatic effects; the NOAEL in that study was 2 mg/kg/day. All of the other studies identified hepatic effects at the lowest doses tested (no other NOAEL was identified). The study by Sumida et al. (2007) was selected as the principal study for MRL derivation because the NOAEL identified in the study was lower than the LOAELs identified in all other studies and because a NOAEL was not identified in the study by Ito et al. (1973). Although the LOAEL (18 mg/kg/day) from Ito et al. (1973) is slightly lower than the LOAEL (20 mg/kg/day) identified by Sumida et al. (2007), use of the LOAEL from Ito et al. (1973) as the point of departure (POD) would necessitate the use of an uncertainty factor of 10, while use of the NOAEL (2 mg/kg/day) from Sumida et al. (2007) does not. In addition, if the LOAEL from Ito et al. (1973) were used as the POD, it would be equivalent to the value derived based on the NOAEL from Sumida et al. (2007) (18 mg/kg/day divided by an uncertainty factor of 10 for use of a LOAEL yields 1.8 mg/kg/day, which rounds to 2 mg/kg/day).

Summary of the Principal Study:

Sumida K, Siato K, Oeda K, . 2007. A comparative study of gene expression profiles in rat liver after administration of α-hexachlorocyclohexane and lindane. J Toxicol Sci 32(3):261–288.17785943

Groups of four male F344 rats were administered α-HCH (99% purity, in corn oil) by gavage at doses of 0 (corn oil control), 2, or 20 mg/kg/day for 28 consecutive days. The following parameters were evaluated: body weight, serum clinical chemistry (AST, ALT, ALP, and total bilirubin in blood collected at necropsy), liver weight, hepatic histopathology, and gene expression in the liver. There were no effects on body weight at any dose. After 28 days of exposure, small but statistically significant increases in AST and ALT were seen at 2 mg/kg/day, but not at 20 mg/kg/day. At the high dose, ALP was decreased by 19% at the end of 28 days. At 20 mg/kg/day, liver weights were increased by 20% (absolute) and 25% (relative) compared to controls. At 2 mg/kg/day, relative liver weight was increased by a small, but statistically significant margin of 6%. Hepatocellular hypertrophy was observed in 4/4 animals at 20 mg/kg/day compared to 0/4 in control and 2 mg/kg/day groups. Based on the increase in liver weight and histological changes at 20 mg/kg/day, this dose is a LOAEL. No exposure-related changes occurred at the 2 mg/kg/day, indicating that this dose is a NOAEL.

Selection of the Point of Departure for the MRL: The NOAEL of 2 mg/kg/day was selected as the POD for derivation of the intermediate-duration oral MRL for α-HCH. Although quantitative data on histopathology findings in the liver were reported, the incidence data increased from 0/4 at 2 mg/kg/day to 4/4 at 20 mg/kg/day, so the data were not amenable to benchmark dose (BMD) modeling. BMD modeling of relative liver weight data was undertaken, but that dataset was also not amenable to BMD modeling, as neither the constant nor nonconstant variance models provide an adequate fit to the variance data. Thus, the NOAEL was selected as the POD.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty and Modifying Factor: The NOAEL of 2 mg/kg/day was divided by a total uncertainty factor (UF) of 100 and a modifying factor (MF) of 10:

- 10 for extrapolation from animals to humans
- 10 for human variability

A modifying factor of 10 was applied to the NOAEL to account for lack of data on developmental toxicity and immunotoxicity and limitations in available data on neurotoxicity. These are sensitive endpoints for other HCH isomers.

MRL = NOAEL ÷ ( UF × MF ) 2 mg / kg / day ÷ ( ( 10 × 10 ) × 10 ) = 0.002 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Hepatic effects have been observed in rats, mice, and hamsters after intermediate- and chronic-duration oral exposures to α-HCH. Observed effects include increases in absolute and relative liver weight, hepatocellular hypertrophy and/or hyperplasia, focal necrosis, fatty degeneration, hepatomegaly, bile duct proliferation, oval cells, nodular hyperplasia, and megalocytosis (Fitzhugh et al. 1950; Ito et al. 1973, 1975, 1976; Nagasaki et al. 1975; Sumida et al. 2007; Tryphonas and Iverson 1983). Both rats and mice have also developed liver tumors at higher doses of α-HCH (Hanada et al. 1973; Ito et al. 1973, 1975, 1976; Nagasaki et al. 1975; Tryphonas and Iverson 1983; Tsukada et al. 1979).

There are no studies on the effects of α-HCH on the developing organism or on the immune system. Studies of β- and γ-HCH have shown developmental effects (e.g., Di Consiglio et al. 2009; Hassoun and Stohs 1996a; La Sala et al. 2009; Rivera et al. 1998; Sauviat et al. 2005; Srinivasan et al. 1991), and for γ-HCH, these are the effects occurring at the lowest doses in animal studies. γ-HCH, and to a lesser extent β-HCH, have been demonstrated to induce suppression of the immune system in several species (e.g., Banerjee et al. 1996; Cornacoff et al. 1988; Desi et al. 1978; Dewan et al. 1980; Hong and Boorman 1993; Khurana et al. 1999; Koner et al. 1998; Mediratta et al. 2008; Meera et al. 1992; Van Velsen et al. 1986). Animal studies of γ-HCH indicate that these effects occur at lower doses than hepatic effects. Thus, the lack of developmental and immunotoxicity data for α-HCH is a significant limitation of the existing database for this isomer.

Data on the neurotoxicity of α-HCH are limited to a single study showing no change in motor nerve conduction velocity after 30 days of exposure (Muller et al. 1981). Both β- and γ-HCH have induced neurotoxic effects in laboratory rodents (e.g., Cornacoff et al. 1988; EPA 1999a; Gilbert and Mack 1995; Parmar et al. 2003; Van Velsen et al. 1986), and γ-HCH has been shown to induce neurotoxicity in humans exposed orally (e.g., Davies et al. 1983; Harris et al. 1969; Munk and Nantel 1977; Nordt and Chew 2000; Powell 1980; Starr and Clifford 1972; Storen 1955).

Agency Contacts (Chemical Managers): Malcolm Williams

## α-HCH Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | α-HCH
CAS Number: | 319-84-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.0009 mg/kg/day (0.9 µg/kg/day)
Critical Effect: | Increased liver weight and liver histopathology changes
Reference: | Fitzhugh et al. 1950
Point of Departure: | 0.9 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
Modifying Factor: | 10
LSE Graph Key: | 14
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.0009 mg/kg/day (0.9 µg/kg/day) was derived for α-HCH based on a NOAEL of 0.9 mg/kg/day and a LOAEL of 4 mg/kg/day for increased liver weight and liver histopathology changes in rats exposed to α-HCH in the diet for 107 weeks (Fitzhugh et al. 1950). A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) and a modifying factor of 10 (for lack of immunotoxicity data and limitations in data on potential neurotoxicity) were applied to the NOAEL to derive the MRL.

Selection of the Critical Effect: Two chronic-duration oral studies of α-HCH were located: Fitzhugh et al. (1950) and Ito et al. (1975). While Ito et al. (1975) examined only cancer endpoints, Fitzhugh et al. (1950) evaluated histopathology in a large number of organs and identified the liver as the most sensitive target of chronic-duration oral exposure.

Selection of the Principal Study: Only Fitzhugh et al. (1950) evaluated endpoints other than cancer, so this study was selected for use in derivation of the chronic-duration oral MRL.

Summary of the Principal Study:

Fitzhugh OG, Nelson AA, Frawley JP. 1950. The chronic toxicities of technical benzene hexachloride and its α, β, and γ isomers. J Pharmacol Exp Ther 100:59–66.14774791

Groups of 10 male and 10 female Wistar rats were treated with 0, 10, 50, 100, or 800 ppm α-HCH in food for life. ATSDR calculated doses corresponding to these concentrations using default food intake and body weight values for male and female Wistar rats in chronic studies as reported in EPA (1988b). Estimated doses were 0, 0.7, 4, 7, or 60 mg/kg/day in males and 0, 0.9, 4, 9, or 70 mg/kg/day in females. The lifetime of the animals sacrificed at the end of the experiment was taken as 107 weeks. Endpoints included clinical signs, body weight, food consumption, organ weights (liver, kidney, and spleen), gross pathology, and histopathology (lung, heart, liver, spleen, pancreas, stomach, small intestine, colon, kidney, adrenal, thyroid, leg muscles and bones, bone marrow, and testis or uterus and ovary). The numbers of animals per group evaluated for histopathology were 10, 8, 14, and 10 in the control through 100 ppm groups.

Survival was significantly reduced at the high dose (mean survival 35.9 weeks at 800 ppm [60–70 mg/kg/day] versus 58.3 weeks in controls), so effects in this group are considered to reflect intermediate-duration exposure. The mean age at death in the remaining groups did not differ from controls (58.3, 54.6, 54.9, and 56.2 weeks for control through 100 ppm groups, respectively). Body weight gain through the first 6 months on study was tabulated for the 100 ppm (7–9 mg/kg/day) and 800 ppm (60–70 mg/kg/day) groups, but not for the 10 or 50 ppm groups. However, the text of the publication indicated that “lower experimental dosage levels had no effect on growth.” Additionally, there was no significant difference in body weight gain in the 100 ppm (7–9 mg/kg/day) group, and no effect on food consumption in any group.

Histopathology findings were reported for the kidney, testes, and liver. Kidney pathological effects were not observed in groups receiving 10, 50, or 100 ppm, with the exception of slight brown pigmentation of the convoluted tubular epithelium at 100 ppm (7–9 mg/kg/day). The 800 ppm (60–70 mg/kg/day) group had slight to moderate kidney damage primarily consisting of tubular dilatation and/or atrophy, glomerular fibrosis and/or atrophy, and interstitial cell infiltration. The study authors reported a “questionable” increase in the degree of testicular atrophy in the group exposed to 800 ppm (60–70 mg/kg/day) α-HCH, but no further information was provided.

Significant increases in relative liver weight (both sexes grouped for analysis) were seen at 50 ppm (32%) and 100 ppm (44%). Gross and microscopic pathology findings were limited to the liver in the groups exposed for the full duration; there were no microscopic changes in the controls. Liver histopathology findings in treated animals were described qualitatively as very slight histological changes at 50 ppm (4 mg/kg/day) and slight histological changes at 100 ppm (7–9 mg/kg/day). The lesions were described as “characteristic of certain chlorinated cyclic compounds” with citation to earlier studies of dichloro-diphenyltrichloroethane (DDT). The earlier studies (e.g., Fitzhugh and Nelson 1947; Laug et al. 1950) characterized the histological changes as primarily centrilobular hepatocellular hypertrophy with increased cytoplasmic “oxyphilia” of these cells along with basophilia and margination of cytoplasmic granules and hyalinization of cytoplasm. There was evidence of increased severity in the group exposed to 800 ppm and surviving less than a year; these animals exhibited moderate histological damage including hepatic cell enlargement or atrophy, fatty degeneration, and focal necrosis.

Based on the increase in liver weight and histological changes at 50 ppm, this dose (4 mg/kg/day) is a LOAEL. No exposure-related changes occurred at the low dose in either sex, indicating that the NOAEL is 10 ppm (0.7–0.9 mg/kg/day).

Selection of the Point of Departure for the MRL: The NOAEL of 0.9 mg/kg/day (for females) was selected as the POD for MRL derivation (ATSDR policy is to select the highest NOAEL associated with the lowest LOAEL for the POD). BMD modeling of the liver weight data was not possible because the study did not report the numbers of animals per group evaluated for liver weights. Liver histology findings were reported qualitatively and without incidences, so BMD modeling was not feasible for these effects.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty and Modifying Factor: The NOAEL of 0.9 mg/kg/day was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

A modifying factor of 10 was applied to the NOAEL to account for the limitations (no immune studies, one neurotoxicity study) in the toxicological database for α-HCH. Immune and nervous system effects are sensitive endpoints for other HCH isomers.

MRL = NOAEL ÷ ( UF × MF ) 0.9 mg / kg / day ÷ ( ( 10 × 10 ) × 10 ) = 0.0009 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Hepatic effects have been observed in rats, mice, and hamsters after intermediate- and chronic-duration oral exposures to α-HCH. Observed effects include increases in absolute and relative liver weight, hepatocellular hypertrophy and/or hyperplasia, focal necrosis, fatty degeneration, hepatomegaly, bile duct proliferation, oval cells, nodular hyperplasia, and megalocytosis (Fitzhugh et al. 1950; Ito et al. 1973, 1975, 1976; Nagasaki et al. 1975; Sumida et al. 2007; Tryphonas and Iverson 1983). Both rats and mice have also developed liver tumors at higher doses of α-HCH (Hanada et al. 1973; Ito et al. 1973, 1975, 1976; Nagasaki et al. 1975; Tryphonas and Iverson 1983; Tsukada et al. 1979).

There are no studies on the effects of α-HCH on the immune system. Studies of γ-HCH, and a few studies of β-HCH, have shown suppression of the immune system (e.g., Banerjee et al. 1996; Cornacoff et al. 1988; Desi et al. 1978; Dewan et al. 1980; Hong and Boorman 1993; Khurana et al. 1999; Koner et al. 1998; Mediratta et al. 2008; Meera et al. 1992; Van Velsen et al. 1986) and for γ-HCH, these effects occur at lower doses than hepatic effects in animal studies. Thus, the lack of immunotoxicity data for α-HCH is a significant limitation of the existing database for this isomer.

Data on the neurotoxicity of α-HCH are limited to a single study showing no change in motor nerve conduction velocity after 30 days of exposure (Muller et al. 1981). Both β- and γ-HCH have induced neurotoxic effects in laboratory rodents (e.g., Cornacoff et al. 1988; EPA 1999a; Gilbert and Mack 1995; Parmar et al. 2003; Van Velsen et al. 1986), and γ-HCH has induced neurotoxicity in humans exposed orally (e.g., Davies et al. 1983; Harris et al. 1969; Munk and Nantel 1977; Nordt and Chew 2000; Powell 1980; Starr and Clifford 1972; Storen 1955).

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for β-HCH.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies of β-HCH in humans or animals were located, precluding derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for β-HCH.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies of β-HCH in humans or animals were located, precluding derivation of an intermediate-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for β-HCH.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies of β-HCH in humans or animals were located, precluding derivation of a chronic-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.08 mg/kg/day
Critical Effect: | Ataxia and hypoactivity
Reference: | Van Velsen et al. 1986
Point of Departure: | 8 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
LSE Graph Key: | 2
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.08 mg/kg/day was derived for β-HCH based on a NOAEL of 8 mg/kg/day in the first few weeks of a 13-week study (Van Velsen et al. 1986); the higher dose in this study (38 mg/kg/day) was a serious LOAEL for a neurological endpoint of ataxia and hypoactivity progressing in some animals to coma. A total uncertainty factor of 100 (10 each for extrapolation from animals to humans and for human variability) was applied to the NOAEL to derive the MRL.

Selection of the Critical Effect: Of the three studies reporting acute-duration oral exposure to β-HCH, two studies (Cornacoff et al. 1988; Van Velsen et al. 1986) identified clinical signs of neurotoxicity as the critical effect at doses of ≥38 mg/kg/day for 1–2 weeks. Renal effects were observed in the third study (Srinivasan et al. 1984) at a higher dose (72 mg/kg/day, the only dose tested).

Selection of the Principal Study: The lowest LOAEL for acute-duration oral exposure to β-HCH was 38 mg/kg/day for ataxia and hypoactivity signs observed in rats during for the first 2 weeks of a 13-week study (Van Velsen et al. 1986). At a dose of 8 mg/kg/day, no clinical signs of neurotoxicity were observed throughout the 13 weeks of exposure (NOAEL).

Summary of the Principal Study:

Van Velsen FL, Danse LHJC, Van Leeuwen FXR, . 1986. The subchronic oral toxicity of the β-isomer of hexachlorocyclohexane in rats. Fundam Appl Toxicol 6:697–712.2423406

Groups of 10 male and 10 female Wistar rats were exposed to β-HCH in diets containing 0, 2, 10, 50, or 250 mg/kg feed in a 13-week study. The animals were weanlings at study initiation. For the acute (first 2 weeks) portion of the study, ATSDR calculated dose values using food intake and body weight for male and female weanling Wistar rats from EPA (1988b) to arrive at 0, 0.3, 1.5, 8, and 38 mg/kg/day doses. Clinical signs of toxicity were noted in the first few weeks of the study. At the end of week 2, two male and two female rats receiving 38 mg/kg/day in the diet exhibited ataxia and hypoactivity, progressing to coma within 3 days. The animals were humanely sacrificed, as were five additional males and six additional females that showed similar signs later in the study. No clinical signs were seen at lower doses of β-HCH at any time during the 13-week exposure period, nor were there histopathology changes in the brain, spinal cord, or sciatic nerve at any dose after 13 weeks of exposure.

Selection of the Point of Departure for the MRL: The NOAEL of 8 mg/kg/day was selected as the basis for the MRL. BMD modeling was not considered because the effects at the next highest dose (clinical signs of toxicity) reflected a serious LOAEL.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL of 8 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ ( UF ) 8 mg / kg / day ÷ ( 10 × 10 ) = 0.08 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Mice treated with 60 or 200 mg/kg/day β-HCH in the diet in a 30-day study developed ataxia within the first week of treatment (Cornacoff et al. 1988). The animals receiving 60 mg/kg/day recovered within a few days, while those receiving 200 mg/kg/day became markedly worse, leading to humane sacrifice of 80% of the animals in this group (Cornacoff et al. 1988). Effects on peripheral nerves were reported by Muller et al. (1981), who observed a significant delay in tail nerve conduction velocity in rats fed 66.3 mg β-HCH/kg/day for 30 days.

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.0006 mg/kg/day (0.6 µg/kg/day)
Critical Effect: | Hyalinization of centrilobular cells in the liver
Reference: | Van Velsen et al. 1986
Point of Departure: | 0.18 mg/kg/day (minimal LOAEL)
Uncertainty Factor: | 300
LSE Graph Key: | 10
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.0006 mg/kg/day (0.6 µg/kg/day) was derived for β-HCH based on a minimal LOAEL of 0.18 mg/kg/day for liver histopathology changes (hyalinization of centrilobular cells) in a 13-week study of rats exposed via the diet (Van Velsen et al. 1986). A total uncertainty factor of 300 (10 each for extrapolation from animals to humans and for human variability, and 3 for use of a minimal LOAEL) was applied to the LOAEL to derive the MRL.

Selection of the Critical Effect: Table A-2 provides a summary of the lowest effect levels in intermediate-duration animal studies of oral exposure to β-HCH. The lowest LOAEL was 0.18 mg/kg/day for hyalinization of centrilobular cells in the liver in male rats exposed for 13 weeks (Van Velsen et al. 1986); these effects increased with dose and are supported by the observation of β-HCH-induced liver effects at higher doses in other intermediate-duration oral studies in rats and mice (Hanada et al. 1973; Ito et al. 1973, 1975).

Table A-2 Summary of NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Laboratory Animals Orally Exposed to β-Hexachlorocyclohexane

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Rat (Wistar); 10 M | 13 weeks (F) | ND | 0.18 M; (minimal LOAEL) | Hyalinization of centrilobular cells | Van Velsen et al. 1986
Mouse (dd); 20–40 M | 24 weeks (F) | ND | 18 | 18% increase in relative liver weight | Ito et al. 1973
Rat (W strain); 18–24 M | 24–48 weeks (F) | | 35 | Hepatocellular hypertrophy after 48 weeks | Ito et al. 1975
Mouse (dd); 10–11 M, 10–11 F | 32 weeks (F) | 20 | 60 F; 50 M | Nuclear irregularities in foci of enlarged hepatocytes | Hanada et al. 1973
Developmental effects
Rat (Wistar); 6 F | GDs 0–21; LDs 1–28; (F) | ND | 5; 20; (serious LOAEL) | Increased liver weight in pups exposed during gestation and lactation 48% pup mortality by PND 5 | Srinivasan et al. 1991

Principal study for the MRL.

(F) = feed; F = female(s); GD = gestation day; LD = lactation day; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Selection of the Principal Study: Van Velsen et al. (1986) was selected as the principal study because it identified the lowest LOAEL among intermediate-duration oral studies.

Summary of the Principal Study:

Van Velsen FL, Danse LHJC, Van Leeuwen FXR, . 1986. The subchronic oral toxicity of the β-isomer of hexachlorocyclohexane in rats. Fundam Appl Toxicol 6:697–712.2423406

Groups of 10 male and 10 female Wistar rats were exposed to β-HCH in diets containing 0, 2, 10, 50, or 250 mg/kg feed (>98% pure) for 13 weeks. ATSDR calculated doses corresponding to these concentrations using food factor values for male and female Wistar rats in subchronic studies as reported in EPA (1988b). Estimated dietary doses were 0, 0.18, 0.9, 4.5, or 22.5 mg/kg/day in males, and 0, 0.2, 1.0, 5, or 25 mg/kg/day in females. Clinical signs were monitored daily, and body weights and food intake were measured weekly. At sacrifice at the end of exposure, blood was collected for hematology and clinical chemistry. Necropsy evaluations included organ weights (liver, kidneys, spleen, thymus, adrenals, pituitary, testes, uterus, and ovaries), gross pathology, and comprehensive histopathology.

At the end of week 2, two male and two female rats receiving the highest dose exhibited ataxia and hypoactivity, progressing to coma within 3 days. The animals were humanely sacrificed, as were five additional males and six additional females that showed similar signs later in the study. Terminal body weight was significantly reduced (15.5% relative to controls in both males and females) in the animals from this dose group that survived. Other effects seen at the highest dose (either in the early decedents or in survivors or both), but not at lower doses, included: centrilobular hepatocytic hypertrophy, proliferation of smooth endoplasmic reticulum, increased microsomal activity, and/or increased glycogen content in the livers; hematologic and splenic changes indicative of anemia (decreased red blood cells and hemoglobin, increased extramedullary hematopoiesis); depletion of splenic lymphoid tissue; thymic cortical atrophy; adrenal cortical hypertrophy in both sexes; testicular and ovarian atrophy; and epithelial hyperplasia, metaplasia, and dilation of endometrial glands in the uterus.

No clinical signs, and no reductions in body weight gain or food intake were seen at lower doses of β-HCH. The lower dose groups had increased food intake and increases in body weight, but terminal body weights did not differ significantly from controls. At doses of 0.2–5 mg/kg/day, reduced neutrophil counts were seen in females, but there were no other significant hematology changes. Clinical chemistry did not show any effects of treatment on serum AST, ALT, ALP, urea, IgM, or IgG levels. Dose-related trends in lower serum lactate and pyruvate were seen, but the only significant difference from controls was for serum lactate in 4.5 mg/kg/day males. Relative, but not absolute, testes weights were reduced (~10%) at 4.5 mg/kg/day, but the difference may have resulted from increased body weight (10% higher than controls) at this dose. At the highest dose, both absolute and relative testes weights were markedly reduced and accompanied by testicular atrophy. Kidney weights were significantly increased at all doses in females, but the increase did not show dose-dependence. In males, significant increases were seen only at ≥4.5 mg/kg/day and were accompanied by renal medullary calcinosis at 22.5 mg/kg/day; this lesion was seen in females at ≥5 mg/kg/day. Increased absolute and/or relative liver weights occurred at ≥0.9 mg/kg/day in males and ≥1.0 mg/kg/day in females. Increased incidences of hyalinization of centrilobular cells were observed in the livers of males at all doses, but not in females except in survivors at the highest dose (25 mg/kg/day). At the lowest dose (0.18 mg/kg/day), the hyalinization in males was characterized as slight. Females exhibited a low incidence of increased mitoses at 5 mg/kg/day. One male each in the 4.5 and 22.5 mg/kg/day groups exhibited focal liver cell necrosis. Periportal fat accumulation and/or focal liver cell necrosis occurred in males and females at ≥4.5 mg/kg/day. Based on the slight liver histopathology changes (hyalinization of centrilobular cells) seen in males at the lowest dose level, 0.18 mg/kg/day is considered to be a minimal LOAEL. A NOAEL could not be determined.

Selection of the Point of Departure for the MRL: The minimal LOAEL of 0.18 mg/kg/day was selected as the POD for MRL derivation because these effects occurred at the lowest dose (increased liver weights were seen at the next higher dose of 0.9–1.0 mg/kg/day). The histopathology findings in the liver did not exhibit a monotonic dose-response relationship and were thus not amenable to BMD modeling.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL of 0.18 mg/kg/day was divided by a total uncertainty factor of 300:

- 3 for use of a minimal LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ ( UF ) 0.18 mg / kg / day ÷ ( 3 × 10 × 10 ) = 0.0006 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The liver is an established target of β-HCH in other intermediate- and chronic-duration oral studies in rats and mice (Fitzhugh et al. 1950; Ito et al. 1973).

Agency Contacts (Chemical Managers): Malcolm Williams

## β-HCH Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | β-HCH
CAS Number: | 319-85-7
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for β-HCH.

Rationale for not deriving an MRL: Two chronic-duration oral studies of β-HCH were located: Fitzhugh et al. (1950) and Thorpe and Walker (1973). While Thorpe and Walker (1973) examined only cancer endpoints, Fitzhugh et al. (1950) evaluated histopathology in a large number of organs and identified the liver as the most sensitive target of chronic-duration oral exposure. In this study, the lowest dose (0.7–0.9 mg/kg/day) was identified as a LOAEL based on increased in liver weight and histological changes. A NOAEL was not identified. Thus, the only available chronic LOAEL (0.7–0.9 mg/kg/day) is higher than the LOAEL (0.18 mg/kg/day based on liver effects in a study by Van Velsen et al. 1986) used as the POD for intermediate MRL derivation. Thus, a chronic-duration MRL could not be derived based on the study by Fitzhugh et al. (1950).

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for γ-HCH.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies of γ-HCH in humans were located. Acute-duration inhalation studies in animals are shown in Table A-3, and include two studies of rats exposed for 4 hours (Oldiges et al. 1980; Ullmann 1986b) and data on clinical signs in mice in the first 2 weeks of an intermediate-duration study (Klonne and Kintigh 1988). Klonne and Kintigh (1988) observed 16% mortality in the first week of exposure to 10 mg/m3 γ-HCH (6 hours/day, 5 days/week). Other endpoints were not evaluated in the first few weeks of these studies (Klonne and Kintigh 1988; Oldiges et al. 1983). The rat studies of 4-hour exposures (Oldiges et al. 1980; Ullmann 1986b) identified freestanding LOAELs (101 or 237 mg/m^3^). The available data are not adequate to identify sensitive targets of inhaled γ-HCH, precluding derivation of an acute-duration inhalation MRL for γ-HCH.

Table A-3 Summary of NOAELs and LOAELs from Acute-Duration Studies in Laboratory Animals Exposed to γ-Hexachlorocyclohexane by inhalation

Species | Exposure scenario | NOAEL (mg/m^3^) | LOAEL (mg/m^3^) | Effect | Reference
Mouse (CD-1); 45 M, 45 F | 1 week; 5 days/week; 6 hours/day | ND | 10; (serious LOAEL) | 16% mortality during the first week | Klonne and Kintigh 1988
Rat (Wistar); 5 M, 5 F | 4 hours | ND | 101 | Sedation | Ullmann 1986b
Rat (Wistar); 5 M, 5 F | 4 hours | ND | 237 | Clinical signs of restlessness and hyperactivity | Oldiges et al. 1980

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for γ-HCH.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies of γ-HCH in humans were located. Intermediate-duration inhalation studies in animals are shown in Table A-4, and include one study of rats exposed for 90 days (Oldiges et al. 1983) and a 14-week study of mice (Klonne and Kintigh 1988). The lowest LOAEL (0.5 mg/m^3^) was identified for renal effects in male rats; a NOAEL for this endpoint was not identified (Oldiges et al. 1980). For the 14-week mouse study by Klonne and Kintigh (1988), a serious LOAEL of 1 mg/m^3^ was identified for concentration-related increases in mortality. No deaths were observed at 0.3 mg/m^3^, and there were no treatment-related effects on body weight, food and water intake, clinical chemistry, organ weight, bone marrow evaluations, ophthalmic evaluations, or gross or microscopic pathology (Klonne and Kintigh 1988). No studies evaluating developmental, neurological, immune system, or reproductive effects of γ-HCH in animals exposed by inhalation were located; these have been demonstrated to be sensitive endpoints of γ-HCH toxicity after oral exposure. The available data were not considered adequate for derivation of an intermediate-duration inhalation MRL due to the lack of studies on sensitive endpoints and because the lowest LOAEL (0.5 mg/m^3^ in rats) is only one-half the serious LOAEL of 1 mg/mg^3^ for mortality in mice.

Table A-4 Summary of NOAELs and LOAELs from Intermediate-Duration Studies in Laboratory Animals Exposed to γ-Hexachlorocyclohexane by inhalation

Species | Exposure scenario | NOAEL (mg/m^3^) | LOAEL (mg/m^3^) | Effect | Reference
Rat (Wistar); 5 M, 5 F | 90 days; day/week NS; 6 hours/day | ND | 0.5 | Dilated renal tubules with protein-containing contents; proliferated tubules in males | Oldiges et al. 1983
Mouse (CD-1); 45 M, 45 F | 14 week; 5 days/week; 6 hours/day | 0.3 | 1; (serious LOAEL) | 1/45 males and 1/45 females died at 1 mg/m3; 5/45 males and 15/45 females died at 5 mg/m3 | Klonne and Kintigh 1988
Rat (Wistar); 5 M, 5 F | 90 days; days/week NS; 6 hours/day | 0.5 | 5 | Diarrhea; bone marrow myelogram changes | Oldiges et al. 1983

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for γ-HCH.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies of γ-HCH in humans or animals were located, precluding derivation of a chronic-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.003 mg/kg/day (3 µg/kg/day)
Critical Effect: | Development of male reproductive tract
Reference: | Dalsenter et al. 1997b
Point of Departure: | 1 mg/kg/day (LOAEL)
Uncertainty Factor: | 300
LSE Graph Key: | 6
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.003 mg/kg/day (3 µg/kg/day) was derived for γ-HCH based on a minimal LOAEL of 1 mg/kg/day for developmental effects (effects on developing reproductive system in male rat pups exposed during lactation) (Dalsenter et al. 1997b). A total uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 for use of a minimal LOAEL) was applied to the LOAEL to obtain the MRL.

Selection of the Critical Effect: Table A-5 provides a summary of the lowest effect levels in acute-duration oral studies of γ-HCH exposure in animals. The lowest effect level was a LOAEL of 1 mg/kg/day for effects on the development of the male reproductive tract in rat pups exposed during LDs 9–14 (Dalsenter et al. 1997b). These effects were seen during assessments on PNDs 65 and 140, as follows. At PND 65, there was no significant effect on relative testicular weight; 7% reduction relative epididymis weight; 29% lower spermatid count; 12% lower sperm count; and 30% lower testosterone levels. At PND 140, the differences from control had declined: testicular weight was 6% lower than controls; spermatid and sperm counts were 13% lower than controls; and there were no significant differences in relative epididymal weights or serum testosterone concentration. There were no effects on mating or fertility. There was no NOAEL associated with the study. The findings in this study are consistent with adverse effects on developing male reproductive organs reported in other animal studies (Agrahari et al. 2019; Dalsenter et al. 1997a, 1997b; Di Consiglio et al. 2009; La Sala et al. 2009; Traina et al. 2003).

Table A-5 Summary of NOAELs and LOAELs from Candidate Acute-Duration Studies in Laboratory Animals Orally Exposed to γ-Hexachlorocyclohexane (Doses ≤10 mg/kg/day)

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Developmental effects
Rat (BOR: spf) 9 F | LDs 9–14 (GO) | ND | 1; (minimal LOAEL) | In male pups, reduced relative testicular and epididymis weight (6–7%), spermatid and sperm counts (12–29%), and testosterone levels (8–30%) at maturity with no effect on fertility | Dalsenter et al. 1997b
Rat (BOR: spf) 9 F | LD 9 or 14 once; (GO) | ND | 6 | In male pups, reduced relative testicular and epididymis weight (~10%), spermatid and sperm counts (~8–10%), testosterone levels (~30-50%), Leydig cell numbers, and spermatogenesis at maturity with no effect on fertility | Dalsenter et al. 1997b
Neurological effects
Rat (Sprague-Dawley); 9 M | 6 days; (GO) | ND | 3 | Increased pineal N-acetyl-transferase, decreased serotonin levels | Attia et al. 1991
Rat (Sprague-Dawley); 7–14 M | 4 days; (GO) | 1 | 3 | Increased kindling acquisition | Joy et al. 1982
Rat (Long-Evans); 14 M | Once; (GO) | ND | 5 | Myoclonic jerks and single clonic seizure in kindled animals | Gilbert and Mack 1995
Rat (Wistar) 5 M, 5 F | 3 days; (GO) | ND | 5; (serious LOAEL) | Decreased myelin in developing brain | Serrano et al. 1990
Hepatic effects
Rat (Wistar); 6 M | 3 days; (GO) | ND | 5 | Fatty degeneration, vacuolation, and necrosis of the liver | Hfaiedh et al. 2012
Hematological effects
Mouse (B6C3F1); 7 M | 10 days; (GO) | ND | 10 | Transient decrease in marrow progenitor cell numbers | Hong and Boorman 1993
Immunological effects
Rat (Wistar); 8 M | 14 days; (NS) | ND | 10 | Reduced delayed-type hypersensitivity (43% decrease in foot pad thickness) | Mediratta et al. 2008
Mouse (B6C3F1); 7 M | 10 days; (GO) | ND | 10 | Dose-related decrease in relative thymus and spleen weights | Hong and Boorman 1993

Principal study for the MRL.

F = female(s); (GO) = gavage in oil vehicle; LD = lactation day; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified

Selection of the Principal Study: The study by Dalsenter et al. (1997b) was selected for use in deriving the MRL because the lowest LOAEL (1 mg/kg/day) was identified for developmental effects in this study.

Summary of the Principal Study:

Dalsenter PR, Faqi AS, Webb J, . 1997b. Reproductive toxicity and toxicokinetics of lindane in the male offspring of rats exposed during lactation. Hum Exp Toxicol 16:146–153.9088967

Reproductive toxicity was evaluated in male offspring of groups of nine Bor:spf female rats that were administered γ-HCH in peanut oil by gavage as a single 6 mg/kg dose on day 9 or day 14 of lactation, or as daily 1 mg/kg/day doses on days 9–14 of lactation (Dalsenter et al. 1997b). A group of nine controls was administered the vehicle alone on days 9–14 of lactation. Male offspring (10 or 20/group) were terminated on PND 65 (puberty) or 140 (adulthood) and evaluated for the following endpoints: testis and epididymis weights, spermatid and sperm numbers, serum testosterone level, sexual behavior at 130 days of age during 1:1 mating with unexposed females (mount latency, intromission and ejaculatory latency, number and frequency of intromissions), mating index (number sperm positive females/number males mated ×100), pregnancy index (number of males that made females pregnant/number of males that made females sperm-positive ×100), fertility index (number of days elapsed until males fertilized their female partner), pregnancy endpoints (numbers of litters, implantations/litters, fetuses/litter, resorptions), and testicular histology (6 mg/kg offspring only).

Effects occurred in all treated groups. Findings in the 1 mg/kg/day offspring included statistically significant (p<0.05) reductions in relative testicular weight at PND 140 (6% less than controls), relative epididymis weight at PND 65 (7%), spermatid number at PNDs 65 and 140 (29 and 13%, respectively), sperm number at PND 140 (13%), serum testosterone at PND 65 (30%), and increased number of intromissions per minute up to ejaculation at PND 130 (45%). Effects were generally similar in type and magnitude in the 6 mg/kg offspring following exposure on GDs 9 or 14, including significantly reduced relative testicular weight at PNDs 65 and 140 (~10%), spermatid and sperm numbers at PND 140 (~8–10%), and serum testosterone at PND 140 (~50%). There were no significant effects on sexual behavior or fertility in the 1 or 6 mg/kg/day offspring as shown by the mating, pregnancy, and fertility indices or other pregnancy endpoints. Thus, the statistically significant changes observed for relative organ weights, sperm number, hormone levels, and intromission incidence are considered minimally effective for reproduction; their associated dose levels are considered minimal LOAELs. The testicular histological examinations of the 6 mg/kg/day offspring showed large areas of normal tissue, although some areas had distinct changes ranging from small alterations to a pronounced effect. The most affected areas were the tubules in which the effects included necrotic changes and reductions in Leydig cell numbers and spermatogenesis.

Selection of the Point of Departure for the MRL: The minimal LOAEL of 1 mg/kg/day for effects on the developing male reproductive tract (Dalsenter et al. 1997b) was selected as the POD for derivation of the acute-duration oral MRL for γ-HCH. BMD modeling was not possible as only a single exposed group was included in the experiment.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The changes in relative organ weights, sperm number, hormone levels, and intromission incidence at the LOAEL were not associated with effects on sexual behavior or fertility; thus, the dose is considered a minimal LOAEL. Therefore, the LOAEL of 1 mg/kg/day was divided by a total uncertainty factor of 300:

- 10 for extrapolation from animals to humans
- 10 for human variability
- 3 for use of a minimal LOAEL

MRL = LOAEL ÷ ( UF ) 1 mg / kg / day ÷ ( 3 × 10 × 10 ) ≈ 0.003 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: In male offspring of rats and mice exposed to γ-HCH via oral administration during gestation and/or postnatal development, effects on preputial separation, serum hormone levels, spermatogenesis, reproductive organ weights, and testicular histopathology have been reported (Agrahari et al. 2019; Dalsenter et al. 1997b; Di Consiglio et al. 2009; La Sala et al. 2009; Traina et al. 2003).

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 8×10^−7^ mg/kg/day (0.8 ng/kg/day)
Critical Effect: | Cardiac effects in offspring
Reference: | Sauviat et al. 2005
Point of Departure: | 0.000076 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
LSE Graph Key: | 75
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.0000008 (8×10^−7^) mg/kg/day (0.8 ng/kg/day) was derived for γ-HCH based on a NOAEL of 0.000076 mg/kg/day for a developmental endpoint of cardiac effects in rat pups (Sauviat et al. 2005). A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied to the NOAEL to obtain the MRL.

Selection of the Critical Effect: Table A-6 provides a summary of the lowest effect levels in intermediate-duration studies of animals exposed to γ-HCH by oral administration. The lowest effect level (0.00015 mg/kg/day, minimal LOAEL) was identified for effects on cardiac electrophysiology in rat pups exposed to γ-HCH in drinking water (Sauviat et al. 2005). A NOAEL of 0.000076 mg/kg/day was identified for this study. The effects at the LOAEL in this study were minimal, but additional evidence that the effects were adverse is provided by the serious findings of altered heart morphometry and cardiac histopathology changes at the higher dose of 0.0003 mg/kg/day. Histopathology evaluations were not conducted in rat pups receiving the lower doses.

Table A-6 Summary of NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Laboratory Animals Orally Exposed to γ-Hexachlorocyclohexane (Doses ≤1 mg/kg/day)

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Developmental effects
Rat (Sprague-Dawley); NS F | ~13 weeks (premating, mating, gestation, lactation, and 3 weeks postweaning) (W) | 0.000076 | 0.00015; (minimal LOAEL); 0.0003; (serious LOAEL) | LOAEL: altered ventricular electrophysiology.; Serious LOAEL: 21% decrease in pup body weight; altered heart morphometry and electrophysiology; cardiac histopathology (hypertrophy in left ventricular area, unorganized collagen bundles and layers, fibroblast destruction) | Sauviat et al. 2005
Rat (Wistar); 13–14 F | GDs 5–21; (GO) | 0.125 | 0.25 | Persistent hyperactivity | Johri et al. 2007
Rat (Wistar); 25 F | GDs 5–21; (GO) | ND | 0.25; (serious LOAEL) | Ultrastructural changes in the brain (moderately distorted mitochondria and demyelinated neurons) | Srivastava et al. 2019
Immunological effects
Mouse (Swiss albino); 6 F | 24 weeks (F) | ND | 0.012 | Changes in cell- and humoral-mediated immune system | Meera et al. 1992

Principal study for the MRL.

(F) = feed; F = female(s); GD =gestation day; (GO) = gavage in oil vehicle; (W) = water; LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Selection of the Principal Study: The lowest LOAEL (0.00015 mg/kg/day) and NOAEL (0.000076 mg/kg/day) for any effect of γ-HCH was identified in the study by Sauviat et al. (2005). These doses are much lower than those associated with other effects of γ-HCH.

Summary of the Principal Study:

Sauviat MP, Bouvet S, Godeau G, . 2005. Electrical activity alterations induced by chronic absorption of lindane (gamma-hexachlorocyclohexane) trace concentrations in adult rat heart. Can J Physiol Pharmacol 83:243–251.15870838

Groups of female Sprague-Dawley rats (number not reported) were administered γ-HCH via “beverage” at doses of 0.5, 1, or 2 ppb. ATSDR estimated corresponding maternal doses of 0, 0.000076, 0.00015, and 0.00030 mg/kg/day using water intake and body weight for female Sprague-Dawley rats in subchronic studies as reported in EPA (1988b). Doses were administered prior to mating for four estrous cycles (~2 weeks); throughout mating (~2 weeks), gestation (3 weeks), lactation (3 weeks), and growth (3 weeks) until pups were 6 weeks of age for a total of ~13 weeks. Exposure of the pups after weaning was not described but assumed to occur via water at the same dose as the dams. Offspring were sacrificed at 6 weeks of age. The left ventricular papillary muscles (LVPM) were dissected from 18 control rats from 7 litters; 5 rats from 2 litters in the 0.000076 mg/kg/day group; 7 rats from 2 litters in the 0.00015 mg/kg/day group; and 18 rats from 7 litters in the 0.0003 mg/kg/day group. Dissected LVPMs were evaluated for the following electrophysiologic measurements: resting potential, action potential, plateau, action potential duration, overshoot, end of early repolarization, and end of terminal repolarization. Cardiac weight, lipid content, and morphometry, as well as left ventricular papillary muscle histopathology were evaluated in pups from the 0.0003 mg/kg/day and control groups only.

The study authors indicated that the high-dose offspring were less sensitive to anesthesia and more sensitive to noise than other groups, but details of these assessments and findings were not provided. Body weights of pups were significantly decreased by 21% in the 0.0003 mg/kg/day group, compared to controls; no significant body weight changes were observed in other groups.

Morphometry analysis showed that hearts from pups in the 0.0003 mg/kg/day group had a 9% increase in heart width (relative to controls), but no significant change in length, with a corresponding 9% decrease in length-to-width ratio. Heart weights and total lipid content were not significantly different in the 0.0003 mg/kg/day group compared to control. At 0.0003 mg/kg/day, offspring heart morphology was described as more round and “cherry like.” The study authors reported that hearts of treated offspring showed hypertrophied areas with thinning of the left ventricular wall and few developed papillary muscles. Histopathological examination in 0.0003 mg/kg/day offspring showed that the heart tissue muscle bundles and layers were unorganized and dissociated, with large hemorrhagic interspaces and dispersion of cell nuclei, destruction of fibroblasts, and dispersion and disorganization of collagen bundles, compared to control heart muscle. Incidences of changes were not reported, and these parameters were not assessed in pups from the 0.5 and 0.00015 mg/kg/day groups.

Electrophysiology changes were evident in LVPMs from animals exposed to 0.00015 mg/kg/day and 0.0003 mg/kg/day γ-HCH. Action potential durations were unchanged at 0.000076 mg/kg/day, but the plateau was shortened moderately at 0.00015 mg/kg/day, and significantly shortened at 0.0003 mg/kg/day. At 0.0003 mg/kg/day, the slow repolarizing phase was also significantly shortened.

The effects at the high dose (0.0003 mg/kg/day) represent a serious LOAEL for cardiac effects (histopathology and electrophysiology changes) and significant body weight decrements (21% decrease) in the developing rat. The only effect at the middle dose (0.00015 mg/kg/day) was shortened action potential duration at the initial plateau phase (measured at 0 millivolts); similar results were not observed in the early repolarization or terminal repolarization phases (measured at 40 and 10 millivolts, respectively). However, at the high dose (0.0003 mg/kg/day), there were effects in all three phases, suggesting a dose-response relationship. There was no assessment of cardiac morphometry or histopathology in offspring from the middle dose group. The electrophysiology changes observed at 0.00015 mg/kg/day are considered to represent a minimal LOAEL. The lowest dose (0.000076 mg/kg/day) was not associated with electrophysiology changes and is considered to be a NOAEL.

Selection of the Point of Departure for the MRL: The data on electrophysiology changes in the study by Sauviat et al. (2005) are not amenable to BMD modeling, as the authors did not report variability measures. Thus, the NOAEL of 0.000076 mg/kg/day was selected as the POD for MRL derivation.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL of 0.000076 mg/kg/day was divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ ( UF ) 0.000076 mg / kg / day ÷ ( 10 × 10 ) ≈ 0.0000008 mg / kg / day ( 8 × 10^− 7^ mg / kg / day )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Sauviat et al. (2007) conducted a related study examining whether the cardiac effects seen after maternal exposure could be induced by paternal exposure to γ-HCH in drinking water. In this study, male rats were exposed to a concentration of 2 μg/L for an unspecified “chronic” duration prior to mating with untreated females. The lack of information on exposure duration in the males precluded estimation of doses. In offspring sacrificed at 6 weeks of age, there were no effects on pup heart weight or shape or electrophysiology, but there were histopathology changes in the hearts similar to those reported by Sauviat et al. (2005) at the same drinking water concentration.

Agency Contacts (Chemical Managers): Malcolm Williams

## γ-HCH Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | γ-HCH
CAS Number: | 58-89-9
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for γ-HCH.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Chronic-duration oral studies of γ-HCH that evaluated noncancer endpoints include a 2-year dog study (Rivett et al. 1978), 18-month and 2-year studies in rats (Ali and Shakoori 1998; Fitzhugh et al. 1950); and 78–80-week studies in mice (EPA 2000a; Herbst et al. 1975; Weisse and Herbst 1977). Table A-7 summarizes effect levels from these chronic studies. As the table shows, all of the effect levels are much higher than the POD (0.000076 mg/kg/day) used for derivation of the intermediate oral MRL for γ-HCH. Thus, the available oral chronic data were not considered adequate for MRL derivation.

Table A-7 Summary of NOAELs and LOAELs from Candidate Chronic-Duration Studies in Laboratory Animals Orally Exposed to γ-Hexachlorocyclohexane

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Dog (Beagle); 4 M, 4 F | 104 weeks (F) | 2.92 | ND | No body weight, hepatic, hematological, or ocular effects | Rivett et al. 1978
Rat (Wistar); 10 M, 10 F | 107 weeks (F) | 4 | 7 M | Increased liver weight (35%); very slight microscopic liver damage; very slight microscopic kidney damage | Fitzhugh et al. 1950
Rat (Sprague-Dawley); 3–5 NS | 18 month (F) | ND | 9 | Increased cell, nucleus, and nucleolus size; extensive cytoplasmolysis; slight cytoplasmic degeneration; increasing nuclear distortion | Ali and Shakoori 1998
Mouse (CD-1); 50 M, 50 F | 78 weeks (F) | 5.2 M | 20.5 M | Centrilobular hepatocyte hypertrophy | EPA 2000a
Mouse (NMRI); 50 M, 50 F | 80 weeks (F) | 8.2 M | ND | No body weight or liver effects | Herbst et al. 1975; Weisse and Herbst 1977

(F) = feed; F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Number: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for δ-HCH.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies of δ-HCH in humans or animals were located, precluding derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Number: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for δ-HCH.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies of δ-HCH in humans or animals were located, precluding derivation of an intermediate-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Number: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for δ-HCH.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies of δ-HCH in humans or animals were located, precluding derivation of a chronic-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Number: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for δ-HCH.

Rationale for Not Deriving an MRL: No acute-duration oral studies of δ-HCH in humans or animals were located, precluding derivation of an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Numbers: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for δ-HCH.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies of δ-HCH in humans were located. Two intermediate-duration oral studies of δ-HCH administered in feed were identified: a 48-week study in rats (Ito et al. 1975) and a 24-week study in mice (Ito et al. 1973). Both studies were focused on the evaluation of liver cancer, and only the liver was evaluated (organ weight and histopathology). Due to the lack of data pertaining to other potential target organs, these data are not considered adequate for derivation of an intermediate-duration oral MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## δ-HCH Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | δ-HCH
CAS Number: | 319-86-8
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for δ-HCH.

Rationale for Not Deriving an MRL: No chronic-duration oral studies of δ-HCH in humans or animals were located, precluding derivation of a chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Malcolm Williams