# 9 REFERENCES

* Not cited in text

ACGIH. 1986. Documentation of the threshold limit valves and biological exposure indices. 5th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 296.
ACGIH. 2004. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adeshina F, Todd EL. 1990. Organochlorine compounds in human adipose tissue from north Texas. J Toxicol Environ Health 29:147–156.1688952
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989a. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA. Fed Regist 54(174):37618–37634.
Ahmed FE, Hart RW, Lewis NJ. 1977. Pesticide induced DNA damage and its repair in cultured human cells. Mutat Res 42:161–174.190533
Akay MT, Alp U. 1981. The effects of BHC and heptachlor on mice. Hacettepe Bull Nat Sci Eng 10:11–22.
Akay MT, Kolankaya D, Ozgur KC. 1982. Histological changes in adrenal glands of female mice treated by heptachlor. Hacettepe Bull Nat Sci Eng 11:1–7.
Akhtar N, Kayani SA, Ahmad MM, 1996. Insecticide-induced changes in secretory activity of the thyroid gland in rats. J Appl Toxicol 16(5):397–400.8889791
*Albrecht WN. 1987. Central nervous system toxicity of some common environmental residues in the mouse. J Toxicol Environ Health 21:405–421.3599086
Alford-Stevens AL, Eichelberger JW, Budde WL. 1988. Multilaboratory study of automated determinations of polychlorinated biphenyls and chlorinated pesticides in water soil and sediment by gas chromatography-mass spectrometry. Environ Sci Technol 22:304–312.22288865
Al-Omar MA, Abdul-Jalil FH, Al-Ogaily NH, 1986. A follow-up study of maternal milk contamination with organochlorine insecticide residues. Environ Pollut 42:79–91.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amita Rani BE, Krishnakumari MK. 1995. Prenatal toxicity of heptachlor in albino rats. Pharmacol Toxicol 76(2):112–114.7746793
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson DJ, Hites RA. 1989. Indoor air: Spatial variations of chlorinated pesticides. Atmos Environ 23:2063–2066.
Armendariz C, Perez de Ciriza JA, Farre R. 2004. Gas chromatography determination of organochlorine pesticides in cow milk. Int J Food Sci Nutr 55(3):215–221.15223598
Arnold DW, Kennedy GL Jr, Keplinger ML, 1977. Dominant lethal studies with technical chlordane, HCS-3260, and heptachlor: Heptachlor epoxide. J Toxicol Environ Health 2:547–555.846003
Arthur RD, Cain JD, Barrentine BF. 1975. The effect of atmospheric levels of pesticides on pesticide residues in rabbit adipose tissue and blood sera. Bull Environ Contam Toxicol 14(6):760–764.1203590
Aulerich RJ, Bursian GJ, Napolitano AC. 1990. Subacute toxicity of dietary heptachlor to mink (Mustela vison). Arch Environ Contam Toxicol 19(6):913–916.2256705
Baker DB, Yang H, Crinella F. 2004b. Neurobehavioral study of 18 year olds exposed to heptachlor epoxide during gestation. Neurotoxicology 25(4):700–701.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barquet A, Morgade C, Pfaffenberger CD. 1981. Determination of organochlorine pesticides and metabolites in drinking water, human blood serum, and adipose tissue. J Toxicol Environ Health 7:469–479.7288899
Baum JJ, Datta S, Young TM. 2001. Trace organic contaminants in San Pablo Bay sediments and their bioavailability. Am Chem Soc Abstr Pap 41(2):162–166.
Ben-Dyke R, Sanderson DM, Noakes DN. 1970. Acute toxicity data for pesticides. World Rev Pestic Control 9:119–127.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berman E, Schlicht M, Moser VC, 1995. A multidisciplinary approach to toxicological screening: I. Systemic toxicity. J Toxicol Environ Health 45:127–143.7783250
Blair A, Grauman DJ, Lubin JH, 1983. Lung cancer and other causes of death among licensed pesticide applicators. J Natl Cancer Inst 71:31–37.6575207
*Blisard KS, Kornfeld M, McFeeley PJ, 1986. The investigation of alleged insecticide toxicity: A case involving chlordane exposure, multiple sclerosis, and peripheral neuropathy. J Forensic Sci 31:1499–1504.3023524
Boyd EM. 1969. Dietary protein and pesticide toxicity in male weanling rats. Bull WHO 40:801–805.4898389
Brock JW, Melnyk LJ, Caudill SP, 1998. Serum levels of several organochlorine pesticides in farmers correspond with dietary exposure and local use history. Toxicol Ind Health 14(1/2):275–289.9460180
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company, 145, 146.
Burns JE. 1974. Pesticides in people. Organochlorine pesticide and polychlorinated biphenyl residues in biopsied human adipose tissue: Texas 1969–72. Pestic Monit J 7(3–4):122–126.
Burse VW, Head SL, Korver MP, 1990. Determination of selected organochloride pesticides and polychlorinated biphenyls in human serum. J Anal Toxicol 14:137–142.1695698
Butler Walker J, Seddon L, McMullen E. 2003. Organochlorine levels in maternal and umbilical cord blood plasma in Arctic Canada. Sci Total Environ 302:27–52.12526896
Buyuksonmez F, Rynk R, Hess TF, 2000. Occurrence, degradation and fate of pesticides during composting. Compost Sci Util 5(1):61–81.
Canadian Ministry of the Environment. 2003. Protocol of accepted drinking water testing methods. Ontario, Canada: Laboratory Services Branch. http://www.ene.gov.on.ca/gp/4465e.htm. August 21, 2005.
Cantoni C, Comi G. 1997. Changes in the concentrations of pesticide residues in foods and in human tissues between 1960 and 1996. Outlook Agric 26(1):47–52.
Cantor KP, Stickland PT, Brock JW, 2003. Risk of non-Hodgkin's lymphoma and prediagnostic serum orgochlorines: β-hexachlorocyclohexane, chlordane/heptachlor-related compounds, dieldrin, and hexachlorobenzene. Environ Health Perspect 111:179–183.12573902
Carey AE, Gowen JA, Tai H, 1978. Pesticide residue levels in soils and crops, 1971: National Soils Monitoring Program (III). Pestic Monit J 12:117–136.740515
Carter FL, Stringer CA. 1970. Residues and degradation products of technical heptachlor in various soil types. J Econ Entomol 63:625–628.5441236
Cassidy RA, Natarajan S, Vaughan GM. 2005. The link between the insecticide heptachlor epoxide, estradiol, and breast cancer. Breast Cancer Res Treat 90:55–64.15770527
Chadduck WM, Gollin SM, Gray BA, 1987. Gliosarcoma with chromosome abnormalities in a neonate exposed to heptachlor. Neurosurgery 21:557–559.3683793
Chan CH, Perkins LH. 1989. Monitoring of trace organic contaminants in atmospheric precipitation. J Great Lakes Res 15(3):465–475.
Chandramouli B, Harvan D, Brittain S, 2004. A gas/liquid chromatographic-mass spectrometric method for the rapid screening of 250 pesticides in aqueous matrices. Organohalogen Compounds 66:246–252.
Chapman PM. 1989. Current approaches to developing sediment quality criteria. Environ Toxicol Chem 8:589–600.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen S, Svrjcek A, Durborrow T, 1999. Ground water quality: Water quality impacts by golf courses. J Environ Qual 28:798–809.
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoffprogram. J Water Pollut Control Fed 56:898–908.
Connell DW, Miller G, Anderson S. 2002. Chlorohydrocarbon pesticides in the Australian marine environment after banning in the period from the 1970s to 1980s. Mar Pollut Bull 45:78–83.12398370
Corrigan PJ, Seneviratna P. 1989. Pesticide residues in Australian meat. Vet Rec 125(8):180–181.2678724
Craan AG, Haines DA. 1998. Twenty-five years of surveillance for contaminants in human breast milk. Arch Environ Contam Toxicol 35:702–710.9776790
Crebelli R, Bellincampi D, Conti G, 1986. A comparative study on selected chemical carcinogens for chromosome malsegregation, mitotic crossing-over and forward mutation induction in Aspergillus nidulans. Mutat Res 172:139–149.3531838
Crum JA, Bursian SJ, Aulerich RJ, 1993. The reproductive effects of dietary heptachlor in mink (Mustela vison). Arch Environ Contam Toxicol 24(2):156–164.8466297
Cullen MC, Connell DW. 1994. Pesticide bioaccumulation in cattle. Ecotoxicol Environ Saf 28:221–231.7525218
Curley A, Copeland MF, Kimbrough RD. 1969. Chlorinated hydrocarbon insecticides in organs of stillborn and blood of newborn babies. Arch Environ Health 19:628–632.4187028
Davidson DA, Wilkinson AC, Blais JM. 2003. Orographic cold-trapping of persistent organic pollutants by vegetation in mountains of western Canada. Environ Sci Technol 37:209–215.12564889
*Den Tonkelaar EM, Van Esch GJ. 1974. No-effect levels of organochlorine pesticides based on induction of microsomal liver enzymes in short-term toxicity experiments. Toxicology 2:371–380.4137085
DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
Di Muccio A, Rizzica M, Ausili A, 1988. Selective, on-column extraction of organochlorine pesticide residues from milk. J Chromatogr 456(1):143–148.3243863
Dvorak M, Halacka K. 1975. Ultrastructure of liver cells in pig at normal conditions and after administration of small doses of heptachlorine. Folia Morphol 23:71–76.
Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5:541–544.
Eisler M. 1968. Heptachlor: Toxicology and safety evaluation. Ind Med Surg 37(11):840–844.
Elder JF, Mattraw HC Jr. 1984. Accumulation of trace elements, pesticides, and polychlorinated biphenyls in sediments and the clam corbicula manilensis of the Apalachicola River, Florida. Arch Environ Contam Toxicol 13:453–469.6431912
Enan EE, El-Sebae AH, Enan OH. 1982. Effect of liver functions by some chlorinated hydrocarbon insecticides in white rats. Meded Fac Landbouwet Rijksuniv Gent 47(1):447–457.
EPA. 1986a. Guidance for the reregistration of pesticide products containing heptachlor as the active ingredient. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide and Toxic Substances. EPA540RS87018.
EPA. 1986b. Superfund record of decision (EPA Region 4): Gallaway Ponds Site, Gallaway, Tennessee, September 1986. Washington, DC: U.S. Environmental Protection Agency. PB87189080.
EPA. 1987. Determination of Henry's Law constants of selected priority pollutants. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600D87229. PB87212684.
EPA. 1990a. Suspended, canceled, and restricted pesticides. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
EPA. 1990b. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1992. Pesticides in ground water database a compilation of monitoring studies: 1971–1991 national summary. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances. EPA7341292001.
EPA. 1994a. Method 8080A: Organochlorine pesticides and polychlorinated biphenyls by gas chromatography. Test methods for evaluating solid waste. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1994b. Method 8250A: Semivolatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Test methods for evaluating solid waste. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999a. Cancellation of pesticides for non-payment of 1999 registration maintenance fees. U.S. Environmental Protection Agency. Fed Regist 64(154):43820–43832.
EPA. 1999b. Recognition and management of pesticide poisonings. 5th. Washington, DC: U.S. Environmental Protection Agency. EPA735R98003. PB99149551.
EPA. 2002a. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F02013. http://www.epa.gov/safewater/mcl.html. February 15, 2005.
EPA. 2002b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. EPA822R02047. http://www.epa.gov/waterscience/pc/revcom.pdf. February 15, 2005.
EPA. 2004a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf. February 15, 2005.
EPA. 2004b. Hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005a. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005b. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005c. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005d. Superfund, emergency planning, and community right-to-know programs. Lower thresholds for chemicals of special concern. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.28. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005e. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005f. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2007. Heptachlor/heptachlor epoxide. 2003–2005. Storet. STOrage & RETrieval. Washington, DC: http://www.epa.gov/storet. April 25, 2007.
Epstein SS, Ozonoff D. 1987. Leukemias and blood dyscrasias following exposure to chlordane and heptachlor. Teratog Carcinog Mutagen 7:527–540.2893466
Epstein SS, Arnold E, Andrea J, 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
FDA. 1989. Current action levels and recommended replacement action levels for heptachlor and heptachlor epoxide. U.S. Department of Health and Human Services. Food and Drug Administration Fed Regist 54:33692–33693.
FDA. 2000. Action levels for poisonous or deleterious substances in human food and animal feed. Washington, DC: Food and Drug Administration. http://www.cfsan.fda.gov/~lrd/fdaact.html. February 15, 2005.
FDA. 2004. Beverages. Bottled water Washington, DC: Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. February 15, 2005.
FEDRIP. 2006. Federal Research in Progress: Heptachlor. National Technical Information Service. October 26, 2006.
Feroz M, Podowski AA, Khan MA Q. 1990. Oxidative dehydrochlorination of heptachlor by Daphnia magna. Pestic Biochem Physiol 36(2)101–105.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Formánek J, Vanickova M, Plevova J, 1976. The effect of some industrial toxic agents on EEG frequency spectra in rats. Adv Eff Environ Chem Psychotropic Drugs 2:257–268.
Fytianos K, Vasilikiotis G, Weil L, 1985. Preliminary study of organochlorine compounds in milk products, human milk, and vegetables. Bull Environ Contam Toxicol 34:504–508.3986388
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14:515–534.5787520
Gak JC, Grillot C, Truhaut R. 1976. Use of the golden hamster in toxicology. Lab Anim Sci 26(2):274–280.775193
Gannon N and Decker GC. 1960. The excretion of dieldrin, DDT, and heptachlor epoxide in milk of dairy cows fed on pastures treated with dieldrin, DDT, and heptachlor. J Econ Entomol 53(3):411–415.
Gartrell MJ, Craun JC, Podrebarac DS, 1986b. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69:123–145.3949685
Gentile JM, Gentile GJ, Bultman J, 1982. An evaluation of the genotoxic properties of insecticides following plant and animal activation. Mutat Res 101:19–29.7043246
Geyer H, Sheehan P, Kotzias D, 1982. Prediction of ecotoxicological behavior of chemicals: Relationship between physicochemical properties and bioaccumulation of organic chemicals in the mussel Mytilus edulis. Chemosphere 11:1121–1134.
Gillett JW, Chan TM. 1968. Cyclodiene insecticides as inducers, substrates, and inhibitors of microsomal epoxidation. J Agric Food Chem 16:590–593.
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Gladen BC, Shkiryak-Nyzhnyk ZA, Zadorozhnaja CN, 2003. Persistent organochlorine compounds and birth weight. Ann Epidemiol 13(3):151–157.12604157
Glatt H, Jung R, Oesch F. 1983. Bacterial mutagenicity investigation of epoxides: Drugs, drug metabolites, steroids, and pesticides. Mutat Res 111:99–118.6355833
Gonzalez M, Miglioranza KS B, Aizpun De Moreno JE, 2003. Occurrence and distribution of organochlorine pesticides (OCPs) in tomato (Lycopersicon esculentum) crops from organic production. J Agric Food Chem 51:1353–1359.12590481
Graham RE, Burson KR, Hammer CF, 1973. Photochemical decomposition of heptachlor epoxide. J Agric Food Chem 21:824–834.4733373
Green VA. 1970. Effects of pesticides on rat and chick embryo. In: Hemphill D, ed. Trace substances in environmental health, III: Proceedings. Columbia, MO: University of Missouri, 183–209.
Greer ES, Miller DJ, Burscato FN, 1980. Investigation of pesticide residues in human adipose tissue in the northeast Louisiana area. J Agric Food Chem 28:76–78.7358938
Gregor DJ, Gummer WD. 1989. Evidence of atmospheric transport and deposition of organochlorine pesticides and polychlorinated biphenyls in Canadian Arctic snow. Environ Sci Technol 23:561–565.
Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements and other chemicals. J Assoc Off Anal Chem 71:1200–1209.3240978
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Saunders Company.
Halacka K, Dvorak M, Rysanek K, 1974. Influence of low perorally administered doses of heptachlor on liver tissue of experimental animals. Scr Med Fac Med Univ Brun Purkynianae 47(6):365–372.
Hamers T, Smit MG D, Murk AJ, 2001. Biological and chemical analysis of the toxic potency of pesticides in rainwater. Chemosphere 45:609–624.11680757
Harbison RD. 1975. Comparative toxicity of some selected pesticides in neonatal and adult rats. Toxicol Appl Pharmacol 32:443–446.1154405
Harner T, Wideman JL, Jantunen LM M, 1999. Residues of organochlorine pesticides in Alabama soils. Environ Pollut 106(3):323–332.15093028
Harradine IR, McDougall KW. 1986. Residues in cattle grazed on land contaminated with heptachlor. Aust Vet J 63:419–422.3800797
Hartley DM, Johnston JB. 1983. Use of the fresh water clam Corbicula manilensis as a monitor for organochlorine pesticides. Bull Environ Contam Toxicol 31:33–40.6882939
Hawker DW, Connell DW. 1986. Bioconcentration of lipophilic compounds by some aquatic organisms. Ecotoxicol Environ Safety 11:184–197.3709407
HazDat. 2006. Heptachlor. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. www.atsdr.cdc.gov/hazdat.html. December 21, 2006.
Hertz-Picciotto I, Greenfield T, Teplin S, 2004. Prenatal exposure to heptachlor epoxide and early childhood development. Neurotoxicology 25(4):701.
Hill DW, McCarty PL. 1967. Anaerobic degradation of selected chlorinated hydrocarbon pesticides. J Water Pollut Contr Fed 39(8):1259–1277.
Hochstedler ME, Larabee-Zierath D, Hallberg GR. 2000. Pesticides in ambient air and precipitation in rural, urban, and isolated areas of eastern Iowa. In: Steinheimer T, ed. Agrochemical fate and movement. Washington, DC: American Chemical Society, 217–231.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Holsapple MP, Burns-Naas L, Hastings KL, 2005. A proposed testing framework for developmental immunotoxicology (DIT). Toxicol Sci 83:18–24.15456913
Holt RL, Cruse S, Greer ES. 1986. Pesticide and polychlorinated biphenyl residues in human adipose tissue from northeast Louisiana. Bull Environ Contam Toxicol 36:651–655.2423161
Hopper ML, Griffitt KR. 1987. Evaluation of an automated gel permeation cleanup and evaporation systems from determining pesticide residues in fatty samples. J Assoc Off Anal Chem 70:724–726.3624184
HSDB. 2007a. Heptachlor. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 25, 2007.
HSDB. 2007b. Heptachlor epoxide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 25, 2007.
IARC. 1974. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to man: Some organic pesticides. Vol. 5: Heptachlor. Lyon, France: World Health Organization, International Agency for Research on Cancer, 173–191.
IARC. 1979. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 20: Heptachlor and Heptachlor Epoxide. Lyon, France: World Health Organization, International Agency for Research on Cancer, 129–154.
IARC. 2001. IARC monographs on the evaluation of carcinogenic risk to humans. Vol 79: Chlordane and heptachlor. Lyon, France: World Health Organization, International Agency for Research on Cancer, 411–419.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. February 15, 2005.
Infante PF, Epstein SS, Newton WA Jr. 1978. Blood dyscrasias and childhood tumors and exposure to chlordane and heptachlor. Scand J Work Environ Health 4:137–150.278225
IRIS. 2005. Heptachlor. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. April 1, 2005.
IRIS. 2006. Heptachlor and heptachlor epoxide. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. March 08, 2006.
Ivie GW, Knox JR, Khalifa S, 1972. Novel photoproducts of heptachlor epoxide, trans-chlordane, and trans-nonachlor. Bull Environ Contam Toxicol 7:376–382.4677557
Izushi F, Ogata M. 1990. Hepatic and muscle injuries in mice treated with heptachlor. Toxicol Lett 54:47–54.2244340
Jain AK, Sarbhoy RK. 1987a. Cytogenetical studies on the effect of some chlorinated pesticides. I. Effect on somatic chromosomes of Lens and Pisum. Cytologia 52:47–54.
Jain AK, Sarbhoy RK. 1987b. Cytogenetical studies on the effect of some chlorinated pesticides. II. Effect on meiotic chromosomes of Lens and Pisum. Cytologia 52:55–62.
Jantunen LM M, Bidlemann TF, Harner T, 2000. Toxaphene, chlordane, and other organochlorine pesticides in Alabama air. Environ Sci Technol 34(24):5097–5105.
Jitunari F, Asakawa F, Takeda N, 1995. Chlordane compounds and metabolite residues in termite control workers' blood. Bull Environ Contam Toxicol 54:855–862.7647501
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190:3–16.6769537
Jonsson V, Liu GJ K, Armbruster J, 1977. Chlorohydrocarbon pesticide residues in human milk in greater St. Louis, Missouri 1977. Am J Clin Nutr 30:1106–1109.69397
Jury WA, Winer AM, Spencer WF, 1987. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Environ Contam Toxicol 99:119–164.
Kacew S, Singhal RL. 1973. The influence of p,p-DDT, α-chlordane, heptachlor, and endrin on hepatic and renal carbohydrate metabolism and cyclic AMP-adenyl cyclase system. Life Sci 13:1363–1371.4357693
*Kacew S, Sutherland DJ B, Singhal RL. 1973. Biochemical changes following chronic administration of heptachlor, heptachlor epoxide and endrin to male rats. Environ Physiol Biochem 3:221–229.
Kamble ST, Ogg CL, Gold RE, 1992. Exposure of applicators and residents to chlordane and heptachlor when used for subterranean termite control. Arch Environ Contam Toxicol 22:253–259.1616308
Kennicutt MC, Wade TL, Presley BJ, 1994. Sediment contaminants in Casco Bay, Maine: Inventories, sources, and potential for biological impact. Environ Sci Technol 28:1–15.22175827
Klemmer HW, Budy AM, Takahashi W. 1977. Human tissue distribution of cyclodiene pesticides--Hawaii 1964–1973. Clin Toxicol 11(1):71–82.872543
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Korfmacher WA, Rushing LG, Siitonen PH, 1987. Confirmation of heptachlor epoxide and octachlor epoxide in milk via fused silica gas chromatography/negative ion chemical ionization mass spectrometry. J High Resolut Chromatogr Commun 10:332–336.
Krampl V. 1971. Relationship between serum enzymes and histological changes in liver after administration of heptachlor in the rat. Bull Environ Contam Toxicol 5:529–536.
Krapac G, Roy W, Smyth CA, 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4(3):209–226.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ II I, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kroger M. 1972. Insecticide residues in human milk. J Pediatr 80(3):401–405.4110556
Larsen AA, Robinson JM, Schmitt N, 1971. Pesticide residues in mother's milk and human fat from intensive use of soil insecticides. HSMHA Health Reports 86(5): 477–481.5108772
Lawson G, Luderer U. 2004. Gestational and lactational exposure to heptachlor does not alter reproductive system development in rats. Vet Hum Toxicol 46(3):113–118.15171484
LeBel GL, Williams DT. 1986. Determination of halogenated contaminants in human adipose tissue. J Assoc Off Anal Chem 69:451–458.3722093
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehman AJ. 1951. Chemicals in foods: A report to the Association of Food and Drug Officials on current developments. Part II. Pesticides. U S Q Bull 15:122–133.
Leland HV, Bruce WN, Shimp NF. 1973. Chlorinated hydrocarbon insecticides in sediments of southern Lake Michigan. Environ Sci Tech 7:833–838.
Le Marchand L, Kolonel LN, Siegel BZ, 1986. Trends in birth defects for a Hawaiian population exposed to heptachlor and for the United States. Arch Environ Health 41(3):145–148.3740952
Leone AD, Ulrich EM, Bodnar CE, 2000. Organochlorine pesticide concentrations and enantiomer fractions for chlordane in indoor air from the US cornbelt. Atmos Environ 34:4131–4138.
Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RG, Bond AE, Fitz-Simons TR, 1986. Monitoring for non-occupational exposure to pesticides in indoor and personal respiratory air. In: Proceedings of the 79th Annual meeting of the air pollution control association, June 22–27, 1986. Minneapolis, MN: Air Pollution Control Association, 1–15.
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26:37–46.8110022
Lichtenstein EP, Schultz KR, Fuhremann TW, 1970. Degradation of aldrin and heptachlor in field soils during a ten-year period translocation into crops. J Agric Food Chem 18:100–106.5002994
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Lopez-Avila V, Wesselman R, Edgell K. 1990. Gas chromatographic-electron capture detection method for determination of 29 organochlorine pesticides in finished drinking water: Collaborative study. J Assoc Off Anal Chem 73(2):276–286.2324039
Lu PY, Metcalf RL, Hirwe AS, 1975. Evaluation of environmental distribution and fate of hexachlorocyclopentadiene, chlordene, heptachlor, and heptachlor epoxide in a laboratory model ecosystem. J Agric Food Chem 23(5):967–973.1174135
Luster MI, Portier C, Pait DG, 1992. Risk Assessment in Immunotoxicology. I. Sensitivity and Predictability of Immune Tests. Fund Appl Toxicol 18:200–210.
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co, 15–29.
MacDonald RW, Barrie LA, Bidleman TF, 2000. Contaminants in the Canadian Arctic: 5 years of progress in understanding sources, occurrence and pathways. Sci Total Environ 254:93–234.10885446
MacIntosh DL, Spengler JD, Ozkaynak H, 1996. Dietary exposures to selected metals and pesticides. Environ Health Perspect 104:202–209.8820589
Mackay D. 1982. Correlation of bioconcentration factors. Environ Sci Technol 16:274–278.22257252
MacMahon B, Monson RR, Wang HH, 1988. A second follow-up of mortality in a cohort of pesticide applicators. J Occup Med 30:429–432.3373347
MacMonegle CW Jr, Steffey KL, Bruce WN. 1984. Dieldrin, heptachlor, and chlordane residues in soybeans in Illinois 1974, 1980. J Environ Sci Health B 19:39–48.6538889
Marshall TC, Dorough HW, Swim HE. 1976. Screening of pesticides for mutagenic potential using Salmonella typhimurium mutants. J Agric Food Chem 24(3):560–563.818141
Martinez MP, Angulo R, Pozo R, 1997. Organochlorine pesticides in pasteurized milk and associated health risks. Food Chem Toxicol 35:621–624.9225021
Maslansky CJ, Williams GM. 1981. Evidence of an epigenetic mode of action in organochlorine pesticide hepatocarcinogenicity: A lack of genotoxicity in rat, mouse, and hamster hepatocytes. J Toxicol Environ Health 8:121–130.7328699
Matsumura F, Ghiasuddin SM. 1983. Evidence for similarities between cyclodiene type insecticides and picrotoxinin in the action mechanisms. J Environ Sci Health B 18:1–14.6187794
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McDougall KW, Singh G, Harris CR, 1987. Organochlorine insecticide residues in some agricultural soils on the north coast region of New South Wales. Bull Environ Contam Toxicol 39:286–293.3663983
McFall JA, Antoine SR, DeLeon IR. 1985. Organics in the water column of Lake Pontchartrain. Chemosphere 14:1253–1265.
McGregor DB, Brown A, Cattanach P, 1988. Response of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay: III. 72 Coded chemicals. Environ Mol Mutagen 12:85–154.3383842
McLean JE, Sims RC, Doucette WJ, 1988. Evaluation of mobility of pesticides in soil using U.S. EPA methodology. J Environ Eng 114(3):689–703.
Mes J, Davies DJ, Turton D, 1986. Levels and trends of chlorinated hydrocarbon contaminants in the breast milk of Canadian women. Food Addit Contam 3:313–322.3803638
Mestitzova M. 1967. On reproduction studies and the occurrence of cataracts in rats after long-term feeding of the insecticide heptachlor. Experientia 23:42–43.6031568
Miersma NA, Pepper CB, Anderson TA. 2003. Organochlorine pesticides in elementary school yards along the Texas-Mexico border. Environ Pollut 126:65–71.12860103
Miles JR W, Tu CM, Harris CR. 1971. Degradation of heptachlor epoxide and heptachlor by a mixed culture of soil microorganisms. J Econ Entomol 64:839–841.5158348
Mills PK, Yang R. 2003. Prostate cancer risk in California farm workers. J Occup Environ Med 45 (3):249–258.12661182
Moore VK, Zabik ME, Zabik MJ. 2000. Evaluation of conventional and "organic" baby food brands from eight organochlorine and five botanical pesticides. Food Chem 71:443–447.
Morgan DP. 1989. Recognition and management of pesticide poisonings. 4^th^ ed. Washington, DC: U.S. Environmental Protection Agency. EPA540988001.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Moser VC, Cheek BM, MacPhail RC. 1995. A multidisciplinary approach to toxicological screening: III. Neurobehavioral toxicity. J Toxicol Environ Health 45:173–210.7783252
Moser VC, MacPhail RC, Gennings C. 2003. Neurobehavioral evaluations of mixtures of trichloroethylene, heptachlor, and di(2-ethylhexyl)phthlate in a full-factorial design. Toxicology 188:125–137.12767685
Moser VC, Shafer TJ, Ward TR, 2001. Neurotoxicological outcomes of perinatal heptachlor exposure in the rat. Toxicol Sci 60(2):315–326.11248144
*Mossing ML, Redetzke KA, Applegate HG. 1985. Organochlorine pesticides in blood of persons from El Paso, Texas. J Environ Health 47:312–313.
Murray HE, Beck JN. 1990. Concentrations of selected chlorinated pesticides in shrimp collected from the Calcasieu River/Lake Complex Louisiana. Bull Environ Contam 44:798–804.
Mussalo-Rauhamaa H, Pyysalo H, Antervo K. 1988. Relation between the content of organochlorine compounds in Finnish human milk and characteristics of the mothers. J Toxicol Environ Health 25:1–19.3418740
Narotsky MG, Kavlock RJ. 1995. A multidisciplinary approach to toxicological screening: II. Developmental toxicity. J Toxicol Environ Health 45:145–171.7783251
Narotsky MG, Weller EA, Chinchilli VM, 1995. Nonadditive developmental toxicity in mixtures of trichloroethylene, di(2-ethylhexyl) phthalate, and heptachlor in a 5×5×5 design. Fundam Appl Toxicol 27(2):203–216.8529815
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nash RG. 1983. Comparative volatilization and dissipation rates of several pesticides from soil. J Agric Food Chem 31:210–217.
NCI. 1977. Bioassay of heptachlor for possible carcinogenicity. CAS No. 76–44-8. Technical Report Series 9. Bethesda, MD: U.S. Department of Health, Education, and Welfare, National Institute of Health, National Cancer Institute. DHEW Publication (NIH) 77–809.
Netzel NR. 1981. Industrial hygiene survey: Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0200501.
NIOSH. 2005. Heptachlor. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdname.html. February 15, 2004.
NPIRS. 2007. Heptachlor. OPP's registered and cancelled pesticide product database (product name search). National Pesticide Information Retrieval System. Purdue Research Foundation. http://ppis.ceris.purdue.edu/ April 20, 2007.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press, National Research Council.
NTP. 1987. Toxicology and carcinogenesis studies of chlorendic acid (CAS No. 115-28-6) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program U.S. Department of Health and Human Services.
NTP. 2005. Report on carcinogens. 11 ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2005.
Ober AG, Santa Maria I, Carmi JD. 1987. Organochlorine pesticide residues in animal feed by cyclic steam distillation. Bull Environ Contam Toxicol 38:404–408.2434167
Offenberg JH, Eisenreich SJ, Chen LC, 2003. Persistent organic pollutants in the dusts that settled across lower Manhattan after September 11, 2001. Environ Sci Technol 37:502–508.12630465
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005c. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
PAN Pesticides Database. 2004. Heptachlor: Registration, import consent and bans. San Francisco, CA: Pesticide Action Network. http://www.pesticideinfo.org/Detail_ChemReg.jsp?Rec_Id=PC35098. March 1, 2005.
Park JS, Wade TL, Sweet S. 2001. Atmospheric deposition of organochorine contaminants to Galveston Bay, Texas. Atmos Environ 35:3315–3324.
Park JS, Wade TL, Sweet ST. 2002. Atmospheric deposition of PAHs, PCBs, and organochlorine pesticides to Corpus Christi Bay, Texas. Atmos Environ 36:1707–1720.
Pelikan Z. 1971. Short-term intoxication of rats by heptachlor administered in diet. Arch Belg Med Soc Hyg Med Trav Med Leg 29(7):462–470.
Petty JD, Huckins JN, Orazio CE, 1995. Determination of waterborne bioavailable organochlorine pesticide residues in the lower Missouri River. Environ Sci Technol 29:2561–2566.22191955
Pines A, Cucos S, Ever-Hadani P, 1986. Levels of some organochlorine residues in blood of patients with arteriosclerotic disease. Sci Total Environ 54:135–156.3101173
*Pines A, Cucos S, Ever-Hadani P, 1987. Some organochlorine insecticide and polychlorinated biphenyl blood residues in infertile males in the general Israeli population of the middle 1980's. Arch Environ Contam Toxicol 16:587–598.3115197
Podowski AA, Banerjee BC, Feroz M, 1979. Photolysis of heptachlor and cis-chlordane and toxicity of their photoisomers to animals. Arch Environ Contam Toxicol 8:509–518.539835
Polishuk ZW, Ron M, Wassermann M, 1977a. Organochlorine compounds in mother and fetus during labor. Environ Res 13:278–294.405211
Polishuk ZW, Ron M, Wassermann M, 1977b. Pesticides in people: Organochlorine compounds in human blood plasma and milk. Pestic Monit J 10(4):121–129.857240
Probst GS, McMahon RE, Hill LE, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–23.7021142
Purkerson-Parker S, McDaniel KL, Moser VC. 2001b. Neurobehavioral effects of gestational and perinatal exposure to heptachlor in rats. Neurotoxicology 22(1):148.
Quandt SA, Arcury TA, Rao P, 2004. Agricultural and residential pesticides in wipe samples from farm worker family residences in North Carolina and Virginia. Environ Health Perspect 112(3):382–387.14998757
Quintana PJ E, Delfino RJ, Korrick S, 2004. Adipose tissue levels in organochlorine pesticides and polychlorinated biphenyls and risk of non-Hodgkin's lymphoma. Environ Health Perspect 112(8):854–861.15175172
Radomski JL, Davidow B. 1953. The metabolite of heptachlor, its estimation, storage and toxicity. J Pharmacol Exp Ther 107:266–272.13035665
Radomski JL, Astolfi E, Deichmann WB, 1971a. Blood levels of organochlorine pesticides in Argentina: Occupationally and nonoccupationally exposed adults, children, and newborn infants. Toxicol Appl Pharmacol 20:186–193.4109070
Radomski JL, Deichmann WB, Rey AA, 1971b. Human pesticide blood levels as a measure of body burden and pesticide exposure. Toxicol Appl Pharmacol 20:175–185.4109069
Radomski JL, Deichmann WB, Clizer EE, 1968. Pesticide concentrations in the liver, brain, and adipose tissue of terminal hospital patients. Food Cosmet Toxicol 6:209–220.5671152
Rashid KA, Mumma RO. 1986. Screening pesticides for their ability to damage bacterial DNA. J Environ Sci Health Part [B] 21:319–334.
Ritcey WR, Savary G, McCully KA. 1972. Organochlorine insecticide residues in human milk, evaporated milk and some milk substitutes in Canada. Can J Publ Health 63:125–132.
Roberts JW, Camann DE. 1989. Pilot study of a cotton glove press test for assessing exposure to pesticides in house dust. Bull Environ Contam Toxicol 43:717–724.2804410
*Saito I, Kawamura N, Uno K, 1986. Relationship between chlordane and its metabolites in blood of pest control operators and spraying conditions. Int Arch Occup Environ Health 58:91–97.3744571
Sandhu SS, Ma TH, Peng Y, 1989. Clastogenicity evaluation of seven chemicals commonly found at hazardous industrial waste sites. Mutat Res 224:437–445.2586542
Santa Maria I, Carmi JD, Valdivia M. 1986. Recovery studies of organochlorine insecticides in fruits and vegetables using cyclic steam-distillation. Bull Environ Contam Toxicol 36:41–46.3940565
Savage EP. 1989. Termiticide use and indoor air quality in the United States. Rev Environ Contam Toxicol 110:117–130.2692087
Savage EP, Keefe TJ, Tessari JD, 1981. National study of chlorinated hydrocarbon insecticide residues in human milk, USA. I. Geographic distribution of dieldrin, heptachlor, heptachlor epoxide, chlordane, oxychlordane and mirex. Am J Epidemiol 113:413–422.7211826
Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in USA freshwater fish, 1976–1984. Arch Environ Contam Toxicol 19(5):748–781.21318506
Selby LA, Newell KW, Hauser GA, 1969. Comparison of chlorinated hydrocarbon pesticides in maternal blood and placental tissue. Environ Res 2:247–255.5353588
Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shakman RA. 1974. Nutritional influences on the toxicity of environmental pollutants. Arch Environ Health 28:105–113.4589147
Sheweita SA. 2004. Carcinogen-metabolizing enzymes and insecticides. J Environ Sci Health B 39(5–6):805–818.15620088
Shindell and Associates. 1981. Report on epidemiologic study of the employees of Velsicol Chemical Corporation Plant in Memphis, Tennessee: January 1952–December 1979. Velsicol Chemical Corporation.
Shivankar VJ, Kavadia VS. 1989. Effects of temperature and humidity on the degradation of heptachlor residues in clay loam soil. Indian J Entomol 51(2):205–210.
Sim M, Forbes A, McNeil J, 1998. Termite control and other determinants of high body burdens of cyclodiene insecticides. Arch Environ Health 53(2):114–121.9577934
Sittig M. 1980. Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 165–171, 445–448.
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Publication, 480–482.
Smialowicz RJ, Williams WC, Copeland CB, 2001. The effects of perinatal/juvenile heptachlor exposure on adult immune and reproductive system function in rats. Toxicol Sci 61(1):164–175.11294987
Smith JA, Harte PT, Hardy MA. 1987. Trace-metal and organochlorine residues in sediments of upper Rockaway River, New Jersey. Bull Environ Contam Toxicol 39:465–473.3117146
Sperling F, Ewenike HK U, Farber T. 1972. Changes in LD_50_ of parathion and heptachlor following turpentine pretreatment. Environ Res 5:164–171.5036962
SRI. 1990. 1990 directory of chemical producers. Menlo Park, CA: SRI International, 843.
*Staples CA, Werner A, Hoogheem T. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Stehr-Green PA, Schilling RJ, Burse VW, 1986. Evaluation of persons exposed to dairy products contaminated with heptachlor. JAMA 256(24):3350–3351.
Stehr-Green PA, Wohlleb JC, Royce W, 1988. An evaluation of serum pesticide residue levels and liver function in persons exposed to dairy products contaminated with heptachlor. JAMA 259(3):374–377.3336161
Steichen J, Koelliker J, Grosh D, 1988. Contamination of farmstead wells by pesticides, volatile organics and inorganic chemicals in Kansas. GWMR 8:153–160.
Strachan WM J. 1988. Toxic contaminants in rainfall in Canada: 1984. Environ Toxicol Chem 7:871–877.
*Strassman SC, Kutz FW. 1977. Insecticide residues in human milk from Arkansas and Mississippi 1973–74. Pestic Monit J 10(4):130–133.854395
Stubin AI, Brosnan TM, Porter KD, 1996. Organic priority pollutants in New York City municipal wastewaters: 1989–1993. Water Environ Res 68:1037–1044.
Sturgeon SR, Brock JW, Potischman N, 1998. Serum concentrations of organochlorine compounds and endometrial cancer risk (United States). Cancer Causes Control 9:417–424.9794174
Sun YP. 1972. Correlation of toxicity of insecticides to the house fly and to the mouse. J Econ Entomol 65(3)632–635.5036668
Takei GH, Kauahikaua SM, Leong GH. 1983. Analyses of human milk samples collected in Hawaii for residues of organochlorine pesticides and polychlorobiphenyls. Bull Environ Contam Toxicol 30:606–613.6407553
Tashiro S, Matsumura F. 1978. Metabolism of trans-nonachlor and related chlordane components in rat and man. Arch Environ Contam Toxicol 7:113–127.666363
Telang S, Tony C, Williams GM. 1982. Epigenetic membrane effects of a possible tumor promoting type on cultured liver cells by the non-genotoxic organochlorine pesticides chlordane and heptachlor. Carcinogenesis 3:1175–1178.6293735
TRI04. 2006. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. August 29, 2006.
USGS. 2003. Organochlorine pesticides and PCBs in bed sediment and whole fish from United States rivers and streams: Summary statistics; preliminary results from cycle 1 of the National Water Quality Assessment Program (NAWQA), 1992–2001. U.S. Geological Survey. http://ca.water.usgs.gov/pnsp/ocdoc.html. March 26, 2007.
USITC. 1982a. Imports of benzenoid chemicals and products 1981. Washington, DC: U.S. International Trade Commission. Publication 1272.
USITC. 1982b. Synthetic organic chemicals: United States production and sales 1981. Washington, DC: U.S. International Trade Commission. Publication 1292.
USITC. 1983a. Imports of benzenoid chemicals and products 1982. Washington, DC: U.S. Government Printing Office. Publication 1401.
USITC. 1983b. Synthetic organic chemicals, United States production and sales 1982. Washington, DC: U.S. International Trade Commission. Publication 1422.
USITC. 1984a. Imports of benzenoid chemicals and products 1983. Washington, DC: U.S. International Trade Commission. Publication 1548.
USITC. 1984b. Synthetic organic chemicals, United States production and sales 1983. Washington, DC: U.S. International Trade Commission. Publication 1588.
USITC. 1985. Synthetic organic chemicals, United States production and sales 1984. Washington, DC: U.S. International Trade Commission. Publication 1745.
USITC. 1986. Synthetic organic chemicals, United States production and sales 1985. Washington, DC: U.S. International Trade Commission. Publication 1892, 235, 241.
USITC. 2007. HTS: 29035200. Aldrin (150), chlordane (150), heptachlor (150); Custom value by custom value for all countries. U.S. International Trade Commission. http://dataweb.usitc.gov/. April 26, 2007.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Wang HH, Grufferman S. 1981. Aplastic anemia and occupational pesticide exposure: A case-control study. J Occup Med 23(5):364–366.7241250
Wang HH, MacMahon B. 1979a. Mortality of pesticide applicators. J Occup Med 21(11):741–744.512718
Wang HH, MacMahon B. 1979b. Mortality of workers employed in the manufacture of chlordane and heptachlor. J Occup Med 21(11):745–748.556268
Ward EM, Schulte P, Grajewski B, 2000. Serum organochlorine levels and breast cancer: A nested case-control study of Norwegian women. Cancer Epidemiol Biomarkers Prev 9:1357–1367.11142422
Wassermann M, Ron M, Bercovici B, 1982. Premature delivery and organochlorine compounds: Polychlorinated biphenyls and some organochlorine insecticides. Environ Res 28:106–112.6179776
Wassermann M, Tomatis L, Wassermann D, 1974. Pesticides in people: Epidemiology of organochlorine insecticides in the adipose tissue of Israelis. Pestic Monit J 8(1):1–7.4140494
Weatherholtz WM, Campbell TC, Webb RE. 1969. Effect of dietary protein levels on the toxicity and metabolism of heptachlor. J Nutr 98:90–94.5784260
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whitmore RW, Immerman FW, Camann DE, 1994. Non-occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contam Toxicol 36:47–59.
WHO. 1984. Environmental health criteria 38: Heptachlor. Geneva, Switzerland: World Health Organization.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. February 15, 2005.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. February 15, 2005.
Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Williams GM, Numoto S. 1984. Promotion of mouse liver neoplasms by the organochlorine pesticides chlordane and heptachlor in comparison to dichlorodiphenyltrichloroethane. Carcinogenesis 5(12):1689–1696.6499120
Worthing CR, Walker SB, eds. 1987. The pesticide manual: A world compendium. 8th ed. Suffolk, Great Britain: The British Crop Protection Council, 455–456.
Wright CG, Leidy RB. 1982. Chlordane and heptachlor in the ambient air of houses treated for termites. Bull Environ Contam Toxicol 28:617–623.7093559
Yamaguchi I, Matsumura F, Kadous AA. 1979. Inhibition of synaptic ATPases by heptachlor epoxide in rat brain. Pestic Biochem Physiol 11:285–293.
Yamaguchi I, Matsumura F, Kadous AA. 1980. Heptachlor epoxide: Effects on calcium-mediated transmitter release from brain synaptosomes in rat. Biochem Pharmacol 29(12):1815–1823.6105872
Zavon MR, Tye R, Latorre L. 1969. Chlorinated hydrocarbon insecticide content of the neonate. Ann NY Acad Sci 160:196–200.5257397
Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9:1–110.
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zimmerman LR, Thurman EM, Bastian KC. 2000. Detection of persistent organic pollutants in the Mississippi Delta using semipermeable membrane devices. Sci Total Environ 248:169–179.10805237