# PEER REVIEW

A peer review panel was assembled for heptachlor and heptachlor epoxide. The panel consisted of the following members:

1. Richard Dickerson, Ph.D., DABT, Department of Pharmacology and Neuroscience and Department of Environmental Toxicology, Texas Tech University Health Sciences Center, Lubbock, TX;
2. Sam Kacew, Ph.D., Department of Cellular and Molecular Medicine, University of Ottawa, Ottawa, Ontario, Canada; and
3. James Klaunig, Ph.D., Department of Pharmacology and Toxicology, Indiana University School of Medicine, Indianapolis, IN.

These experts collectively have knowledge of heptachlor and heptachlor epoxide's physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.