# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding heptachlor and heptachlor epoxide in air, water, and other media are summarized in Table 8-1.

ATSDR derived an acute-duration oral MRL of 0.0006 mg/kg/day for heptachlor. This MRL was based on a LOAEL of 1.8 mg/kg/day for impaired reproductive performance in female rats mated with unexposed males (Amita Rani and Krishnakumari 1995), an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability), and a modifying factor of 3 for the use of a serious end point.

ATSDR derived an intermediate-duration oral MRL of 0.0001 mg/kg/day for heptachlor. This MRL was based on a minimal LOAEL of 0.03 mg/kg/day for developmental immunological and neurological effects in rats (Moser et al. 2001; Smialowicz et al. 2001) and an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

EPA (IRIS 2005) has derived an oral reference dose (RfD) for heptachlor of 5×10^−4^ mg/kg/day based on NOAEL of 0.15 mg/kg/day and LOAEL of 0.25 mg/kg/day for increased liver weight in rats exposed to heptachlor for 2 years and an uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 to account for limitations in the database particularly the lack of a chronic study in a second species).

EPA (IRIS 2005) also derived an RfD of 1.3×10^−5^ mg/kg/day for heptachlor epoxide. This RfD is based on a LOAEL of 0.0125 mg/kg/day for increased relative liver weight identified in a dog study submitted to EPA by Dow Chemical Company and an uncertainty factor of 1,000 to account for inter and intraspecies extrapolation and because a NOAEL was not attained. The studies which serve as the basis of the RfDs for heptachlor and heptachlor epoxide were not discussed in the toxicological profile because they were submitted to EPA under FIFRA and are not publicly available.

Table 8-1 Regulations and Guidelines Applicable to Heptachlor and Heptachlor Epoxide

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2004
| Heptachlor | Group 2B^a^
WHO | Air quality guidelines | No data | WHO 2000
| Drinking water quality guidelines | Guideline values have not been established^b^ | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA | | ACGIH 2004
| Heptachlor^c^ | 0.05 mg/m^3^
| Heptachlor epoxide^c^ | 0.05 mg/m^3^
EPA | Hazardous air pollutant | | EPA 2004b
| Heptachlor | Yes | 42 USC 7412
NIOSH | REL (10-hour TWA) | | NIOSH 2005
| Heptachlor^d,e^ | 0.5 mg/m^3^
| IDLH
| Heptachlor | 35 mg/m^3^
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2005c
| Heptachlor^f^ | 0.5 mg/m^3^ | 29 CFR 1910.1000
| PEL (8-hour TWA) for construction industry | | OSHA 2005b
| Heptachlor^f^ | 0.5 mg/m^3^ | 29 CFR 1926.55
| PEL (8-hour TWA) for shipyard industry | | OSHA 2005a
| Heptachlor^f^ | 0.5 mg/m^3^ | 29 CFR 1915.1000
b. Water
EPA | Designated as hazardous substances in accordance with Section 311 of the Clean Water Act | | EPA 2005a; 40 CFR 116.4
| Heptachlor | Yes
| Drinking-water health advisories | | EPA 2004a
| Heptachlor
| 1-day health advisory for a 10-kg child^g^ | 0.01 mg/L
| 10-day health advisory for a 10-kg child^h^ | 0.01 mg/L
| DWEL^i^ | 0.02 mg/L
| 10^−4^ Cancer risk^j^ | 0.0008 mg/L
EPA | Drinking-water health advisories | | EPA 2004a
| Heptachlor epoxide
| 1-day health advisory for a 10-kg child^g^ | 0.01 mg/L
| 10-day health advisory for a 10-kg child^h^ | No data
| DWEL^i^ | 0.0004 mg/L
| 10^−4^ Cancer risk^j^ | 0.0004 mg/L
| National primary drinking water regulations^k^ | | EPA 2002a
| Heptachlor
| MCL | 0.0004 mg/L
| MCLG | Zero
| Heptachlor epoxide
| MCL | 0.0002 mg/L
| MCLG | Zero
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2005b; 40 CFR 117.3
| Heptachlor | 1 pound
| Water quality criteria for human health consumption of: | | EPA 2002b
| Heptachlor^l^
| Water + organism | 7.9×10^−5^
| Organism only | 7.9×10^−5^
| Heptachlor epoxide^l^
| Water + organism | 3.9×10^−5^
| Organism only | 3.9×10^−5^
c. Food
FDA | Action level | | FDA 2000
| Heptachlor
| Artichokes; asparagus; Brassica (cole) leafy vegetables; bulb vegetables; cereal grains; citrus fruits; eggs; figs; fruiting vegetables; leafy vegetables; legume vegetables; peanuts; pome fruits; root and tuber vegetables; salsify tops; small fruits and berries; stone fruits; and sugarcane | 0.01 ppm
| Cottonseed, cucurbit vegetables, pineapple, and rabbit (fat basis) | 0.02 ppm
| Fish (edible portion) | 0.3 ppm
| Milk (fat basis) | 0.1 ppm
FDA | Bottled water | | FDA 2004
| Heptachlor | 0.0004 mg/L | 21 CFR 165.110
| Heptachlor epoxide | 0.0002 mg/L
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2004
| Heptachlor | A3^m^
| Heptachlor epoxide | A3^m^
EPA | Carcinogenicity classification | | IRIS 2005
| Heptachlor | B2^n^
| Heptachlor epoxide | B2^n^
| RfC
| Heptachlor | Not available at this time
| Heptachlor epoxide | Not available at this time
| RfD
| Heptachlor | 5.0×10^−4^ mg/kg/day
| Heptachlor epoxide | 1.3×10^−5^ mg/kg/day
| Inhalation unit risk
| Heptachlor | 1.3×10^−3^ per ug/m^3^
| Heptachlor epoxide | 2.6×10^−3^ per ug/m^3^
| Oral slope factor
| Heptachlor | 4.5 per mg/kg-day
| Heptachlor epoxide | 9.1 per mg/kg-day
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance | | EPA 2005c
| Heptachlor^o^ | | 40 CFR 302.4
| Reportable quantity | 1 pound
| RCRA waste number | P059
| Heptachlor epoxide^p^
| Reportable quantity | 1 pound
| RCRA waste number | No data
| Effective date of toxic chemical release reporting | | EPA 2005e; 40 CFR 372.65
| Heptachlor | 01/01/87
| Threshold amounts for manufacturing (including importing), processing, and otherwise using such toxic chemicals | | EPA 2005d; 40 CFR 372.28
| Heptachlor | 10 pounds
NTP | Carcinogenicity classification | No data | NTP 2005

a Group 2B: possibly carcinogenic to humans

b Guideline values have not been established: heptachlor and heptachlor epoxide occurs in drinking water at concentrations well below those at which heptachlor epoxide toxic effects may occur.

c Skin notation: refers to the potential significant contribution to the overall exposure by the cutaneous route, including mucous membranes and the eyes, either by contact with vapors or, of probable greater significance, by direct skin contact with the substance.

d Potential occupational carcinogen

e Skin designation: indicates the potential for dermal absorption; skin exposure should be prevented as necessary through the use of good work practices and gloves, coveralls, goggles, and other appropriate equipment.

f Skin designation

g 1-Day health advisory: the concentration of a chemical in drinking water that is not expected to cause any adverse noncarcinogenic effects for up to 1 day of exposure. The 1-day health advisory is normally designed to protect a 10-kg child consuming 1 liter of water per day.

h 10-Day health advisory: the concentration of a chemical in drinking water that is not expected to cause any adverse noncarcinogenic effects for up to 10 days of exposure. The 10-day health advisory is also normally designed to protect a 10-kg child consuming 1 liter of water per day.

i DWEL: a lifetime exposure concentration protective of adverse, noncancer health effects that assumes all of the exposure to a contaminant is from drinking water.

j 10^−4^ Cancer risk: the concentration of a chemical in drinking water corresponding to an excess estimated lifetime cancer risk of 1 in 10,000.

k Potential health effects from ingestion of water include liver damage and increased risk of cancer. The contaminant in drinking water is the residue of a banned termiticide (heptachlor) and the breakdown of heptachlor from epoxide heptachlor.

l This criterion is based on carcinogenicity of 10^−6^ risk.

m A3: not classifiable as a human carcinogen

n B2: probable human carcinogen

o Heptachlor: designated CERCLA hazardous substance pursuant to Section 311(b)(2) and 307(a) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

p Heptachlor epoxide: designated CERCLA hazardous substance pursuant to Section 307(a) of the Clean Water Act.

ACGIH = American Conference of Governmental Industrial Hygienists; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking-water equivalent level; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminat level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization